# Stakeholders

- Kathy Frisbee, PhD
  Director
  Connected Health Office of Analytics & Business Intelligence
  VHA
- Sally Haskell, MD
  Deputy Chief Consultant for Clinical Operations and Director of Comprehensive Health
  Office of Patient Care Services, Women’s Health Services
  VHA
- Nancy Maher, PhD
  Program Analyst
  Office of Patient Care Services, Women’s Health Services
  VHA
- Alan West, PhD
  Deputy Director
  Office of Rural Health
  VHA