# Stakeholder and Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the ESP consulted several technical and content experts. We sought broad expertise and perspectives. Divergent and conflicting opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

The list of stakeholders and members of the Technical Expert Panel (TEP) who provided input to this report follows.