# Technical Expert Panel

- Lori A. Bastian, MD, MPH
  Director, Pain Research, Informatics, Multimorbidities, and Education Center
  VA Connecticut Healthcare System
- Alicia Christy, MD
  Deputy Director, Reproductive Health, Patient Care Services, Women’s Health Services
  VHA
- Jan Lindsay, PhD
  Investigator, Center for Innovations in Quality, Effectiveness and Safety
  Michael E. DeBakey VAMC & South Central MIRECC
- Carolyn Turvey, PhD
  Core Investigator
  Comprehensive Access & Delivery Research & Evaluation (CADRE)
  Iowa City VA Health Care System