# References

1 Heckenlively JR. (1988). Retinitis pigmentosa.
2 Bunker CH, Berson EL, Bromley WC, et al. (1984). Prevalence of retinitis pigmentosa in Maine. Am J Ophthalmol.
3 Grondahl J. (1987). Estimation of prognosis and prevalence of retinitis pigmentosa and Usher syndrome in Norway. Clin Genet.
4 Hartong DT, Berson EL, Dryja TP. (2006). Retinitis pigmentosa. Lancet.
5 Haim M. (2002). Epidemiology of retinitis pigmentosa in Denmark. Acta Ophthalmol Scand Suppl.
6 Guadagni V, Novelli E, Piano I, Gargini C, Strettoi E. (2015). Pharmacological approaches to retinitis pigmentosa: A laboratory perspective. Prog Retin Eye Res.
7 Tanino T, Ohba N. (1976). Studies on pigmentary retinal dystrophy. II. Recordability of electroretinogram and the mode of inheritance. Jpn J Ophthalmol.
8 Taylor HR. (2007). LXIII Edward Jackson Memorial Lecture: Eye care: dollars and sense. Am J Ophthalmol.
9 Hahm BJ, Shin YW, Shim EJ, et al. (2008). Depression and the vision-related quality of life in patients with retinitis pigmentosa. Br J Ophthalmol.
10 Second Sight Medical Products. (2000). Argus II retinal prosthesis system dry AMD feasibility study protocol. ClinicalTrials.gov.
11 Bowling B. Acquired macular disorders. Kanski's Clinical Ophthalmology: A Systematic Approach.
12 American Academy of Ophthalmology Retina/Vitreous Panel. (2015). Preferred practice pattern guidelines. Age-related macular degeneration.
13 Ferris FL, Wilkinson CP, Bird A, et al. (2013). Clinical classification of age-related macular degeneration. Ophthalmology.
14 Zrenner E, Bartz-Schmidt KU, Benav H, et al. (2011). Subretinal electronic chips allow blind patients to read letters and combine them to words. Proc Biol Sci.
15 Humayun MS, Dorn JD, da Cruz L, et al. (2012). Interim results from the international trial of Second Sight's visual prosthesis. Ophthalmology.
16 Dobelle WH, Quest DO, Antunes JL, et al. (1979). Artificial vision for the blind by electrical stimulation of the visual cortex. Neurosurgery.
17 Veraart C, Raftopoulos C, Mortimer JT, et al. (1998). Visual sensations produced by optic nerve stimulation using an implanted self-sizing spiral cuff electrode. Brain Res.
18 Ayton LN, Blamey PJ, Guymer RH, et al. (2014). First-in-human trial of a novel suprachoroidal retinal prosthesis. PLoS ONE.
19 U.S. Food and Drug Administration (FDA), Center for Devices and Radiological Health (CDRH). (2013). Drug Administration (FDA), Center for Devices and Radiological Health (CDRH) Investigational Device Exemption (IDE) guidance for retinal prostheses.
20 Keseru M, Feucht M, Bornfeld N, et al. (2012). Acute electrical stimulation of the human retina with an epiretinal electrode array. Acta Ophthalmol.
21 Stingl K, Bartz-Schmidt KU, Gekeler F, et al. (2013). Functional outcome in subretinal electronic implants depends on foveal eccentricity. Invest Ophthalmol Vis Sci.
22 Chow AY, Chow VY, Packo KH, et al. (2004). The artificial silicon retina microchip for the treatment of vision loss from retinitis pigmentosa. Arch Ophthalmol.
23 Fujikado T, Kamei M, Sakaguchi H, et al. (2011). Testing of semichronically implanted retinal prosthesis by suprachoroidal-transretinal stimulation in patients with retinitis pigmentosa. Invest Ophthalmol Vis Sci.
24 Rizzo JF, Shire DB, Kelly SK, et al. (2011). Overview of the Boston retinal prosthesis: challenges and opportunities to restore useful vision to the blind. Conf Proc IEEE Eng Med Biol Soc.
25 Mandel Y, Goetz G, Lavinsky D, et al. (2013). Cortical responses elicited by photovoltaic subretinal prostheses exhibit similarities to visually evoked potentials. Nat Commun.
26 Alamusi, Matsuo T, Hosoya O, et al. (2015). Vision maintenance and retinal apoptosis reduction in RCS rats with Okayama University-type retinal prosthesis (OUReP^TM^) implantation. J Artif Organs.
27 Dodson B. (2012). Bio-Retina to enter clinical trials in 2013. Gizmag.
28 Fan LS. (2015). Flexible artificial retina devices. United States patent US 9114004.
29 Yue L, Falabella P, Christopher P, et al. (2015). Ten-year follow-up of a blind patient chronically implanted with epiretinal prosthesis Argus I. Ophthalmology.
30 Ho AC, Humayun MS, Dorn JD, et al. (2015). Long-term results from an epiretinal prosthesis to restore sight to the blind. Ophthalmology.
31 Geruschat DR, Flax M, Tanna N, et al. (2015). FLORA: Phase I development of a functional vision assessment for prosthetic vision users. Clin Exp Optom.
32 (2016). Personal communication.
33 Hoffman DR, Locke KG, Wheaton DH, et al. (2004). A randomized, placebo-controlled clinical trial of docosahexaenoic acid supplementation for X-linked retinitis pigmentosa. Am J Ophthalmol.
34 Wheaton DH, Hoffman DR, Locke KG, et al. (2003). Biological safety assessment of docosahexaenoic acid supplementation in a randomized clinical trial for X-linked retinitis pigmentosa. Arch Ophthalmol.
35 Aleman TS, Duncan JL, Bieber ML, et al. (2001). Macular pigment and lutein supplementation in retinitis pigmentosa and Usher syndrome. Invest Ophthalmol Vis Sci.
36 Berson EL, Rosner B, Sandberg MA, et al. (1993). A randomized trial of vitamin A and vitamin E supplementation for retinitis pigmentosa. Arch Ophthalmol.
37 Berson EL, Rosner B, Sandberg MA, et al. (2004). Further evaluation of docosahexaenoic acid in patients with retinitis pigmentosa receiving vitamin A treatment: subgroup analyses. Arch Ophthalmol.
38 Berson EL, Rosner B, Sandberg MA, et al. (2010). Clinical trial of lutein in patients with retinitis pigmentosa receiving vitamin A. Arch Ophthalmol.
39 Bendich A, Langseth L. (1989). Safety of vitamin A. Am J Clin Nutr.
40 Evans K, HickeyDwyer MU. (1991). Cleft anterior segment with maternal hypervitaminosis A. Br J Ophthalmol.
41 Rothman KJ, Moore LL, Singer MR, et al. (1995). Teratogenicity of high vitamin A intake. New Eng J Med.
42 Melhus H, Michaelsson K, Kindmark A, et al. (1998). Excessive dietary intake of vitamin A is associated with reduced bone mineral density and increased risk for hip fracture. Ann Intern Med.
43 Feskanich D, Singh V, Willett WC, et al. (2002). Vitamin A intake and hip fractures among postmenopausal women. JAMA.
44 Schatz A, Rock T, Naycheva L, et al. (2011). Transcorneal electrical stimulation for patients with retinitis pigmentosa: a prospective, randomized, sham-controlled exploratory study. Invest Ophthalmol Vis Sci.
45 Birch DG, Weleber RG, Duncan JL, et al. (2013). Randomized trial of ciliary neurotrophic factor delivered by encapsulated cell intraocular implants for retinitis pigmentosa. Am J Ophthalmol.
46 Ferrari MP, Mantelli F, Sacchetti M, et al. (2014). Safety and pharmacokinetics of escalating doses of human recombinant nerve growth factor eye drops in a double-masked, randomized clinical trial. Biodrugs.
47 Maguire AM, High KA, Auricchio A, et al. (2009). Age-dependent effects of RPE65 gene therapy for Leber's congenital amaurosis: a phase 1 dose-escalation trial. Lancet.
48 Maguire AM, Simonelli F, Pierce EA, et al. (2008). Safety and efficacy of gene transfer for Leber's congenital amaurosis. N Engl J Med.
49 Hauswirth WW, Aleman TS, Kaushal S, et al. (2008). Treatment of leber congenital amaurosis due to RPE65 mutations by ocular subretinal injection of adeno-associated virus gene vector: short-term results of a phase I trial. Hum Gene Ther.
50 Bainbridge JW, Smith AJ, Barker SS, et al. (2008). Effect of gene therapy on visual function in Leber's congenital amaurosis. N Engl J Med.
51 MacLaren RE, Groppe M, Barnard AR, et al. (2014). Retinal gene therapy in patients with choroideremia: initial findings from a phase 1/2 clinical trial. Lancet.
52 Russell SR, Bennett J, High KA, et al. (2015). Phase 3 trial of AAV2- hRPE65v2 (SPK-RPE65) to treat RPE65-mediated inherited retinal dystrophies (IRDs): top-line safety and efficacy results.
53 Maguire AM, Russell SR, Bennett J, et al. (2015). Phase 3 trial of AAV2-hRPE65v2 (SPK-RPE65) to treat RPE65-mediated inherited retinal degenerations.
54 Cideciyan AV, Jacobson SG, Beltran WA, et al. (2013). Human retinal gene therapy for Leber congenital amaurosis shows advancing retinal degeneration despite enduring visual improvement. Proc Natl Acad Sci U S A.
55 Koenekoop RK, Sui R, Sallum J, et al. (2014). Oral 9-cis retinoid for childhood blindness due to Leber congenital amaurosis caused by RPE65 or LRAT mutations: an open-label phase 1b trial. Lancet.
56 Zheng A, Li Y, Tsang SH. (2015). Personalized therapeutic strategies for patients with retinitis pigmentosa. Expert Opin Biol Ther.
57 Blenkinsop TA, Corneo B, Temple S, et al. (2012). Ophthalmologic stem cell transplantation therapies. Regen Med.
58 Siqueira RC, Messias A, Messias K, et al. (2015). Quality of life in patients with retinitis pigmentosa submitted to intravitreal use of bone marrow-derived stem cells (Reticell -clinical trial). Stem Cell Res Ther.
59 Markowitz SN. (2009). Current options in low vision rehabilitation. Geriatr Aging.
60 Geruschat Duane R, Dagnelie Gislin. Restoration of vision following long-term blindness: considerations for providing rehabilitation. J Vis Impair Blind.
61 Mokkink LB, Terwee CB, Patrick DL, et al. (2010). The COSMIN checklist for assessing the methodological quality of studies on measurement properties of health status measurement instruments: an international Delphi study. Quality of life research: an international journal of quality of life aspects of treatment, care and rehabilitation.
62 (2014). Methods guide for effectiveness and comparative effectiveness reviews.
63 Stingl K, BartzSchmidt KU, Besch D, et al. (2015). Subretinal visual implant alpha IMS - clinical trial interim report. Vision Res.
64 Stingl K, Bach M, Bartz-Schmidt KU, et al. (2013). Safety and efficacy of subretinal visual implants in humans: methodological aspects. Clin Exp Optom.
65 Arevalo JF, Al Rashaed S, Kahtani ES, et al. (2015). The Argus II retinal prosthesis in RP patients: surgical and functional outcomes from the KKESH Collaborative Retina Study Group [slide presentation].
66 Arevalo JF, Mura M, Al Rashaed S. (2015). The Argus II retinal prosthesis: surgical and functional outcomes in younger retinitis pigmentosa (RP) patients [poster PO267; slide set].
67 Luo YH, Zhong JJ, da Cruz L. (2015). The use of Argus® II retinal prosthesis by blind subjects to achieve localisation and prehension of objects in 3-dimensional space. Graefes Arch Clin Exp Ophthalmol.
68 De Juan E, Spencer R, Barale PO, et al. (2013). Extraction of retinal tacks from subjects implanted with an epiretinal visual prosthesis. Graefes Arch Clin Exp Ophthalmol.
69 Greenberg RJ, Humayun MS, da Cruz L, et al. (2015). Five-year data from the Argus II retinal prosthesis system clinical trial. Invest Ophthalmol Vis Sci.
70 Luo YH, Davagnanam I, Dacruz L. (2013). MRI brain scans in two patients with the Argus II retinal prosthesis. Ophthalmology.
71 Lauritzen TZ, Harris J, Mohand-Said S, et al. (2012). Reading visual braille with a retinal prosthesis. Front Neurosci.
72 Da Cruz L, Coley BF, Dorn J, et al. (2013). The Argus II epiretinal prosthesis system allows letter and word reading and long-term function in patients with profound vision loss. Br J Ophthalmol.
73 Barry MP, Dagnelie G. (2012). Use of the Argus II retinal prosthesis to improve visual guidance of fine hand movements. Invest Ophthalmol Vis Sci.
74 Geruschat DR, Richards TP, Arditi A, et al. (2016). An analysis of observer-rated functional vision in patients implanted with the Argus II Retinal Prosthesis System at three years. Clin Exp Optom.
75 Garcia S, Petrini K, Rubin GS, et al. (2015). Visual and non-visual navigation in blind patients with a retinal prosthesis. PLoS ONE.
76 da Cruz L, Dorn JD, Humayun MS, et al. (2016). Five-year safety and performance results from the Argus II Retinal Prosthesis System clinical trial. Ophthalmology.
77 Seider MI, Hahn P. (2015). Argus II retinal prosthesis malrotation and repositioning with intraoperative optical coherence tomography in a posterior staphyloma. Clin Ophthalmol.
78 Rizzo S, Belting C, Cinelli L, et al. (2014). The Argus II retinal prosthesis: 12-month outcomes from a single-study center. Am J Ophthalmol.
79 Khan MA, Ho AC, Haller JA. (2015). Ten-year follow-up of a subretinal silicon prosthesis for retinitis pigmentosa. Ophthalmology.
80 Chow AY, Bittner AK, Pardue MT. (2010). The artificial silicon retina in retinitis pigmentosa patients (an american ophthalmological association thesis). Trans Am Ophthalmol Soc.
81 Geruschat DR, Bittner AK, Dagnelie G. (2012). Orientation and mobility assessment in retinal prosthetic clinical trials. Optom Vis Sci.
82 Klauke S, Goertz M, Rein S, et al. (2011). Stimulation with a wireless intraocular epiretinal implant elicits visual percepts in blind humans. Invest Ophthalmol Vis Sci.
83 MenzelSevering J, Laube T, Brockmann C, et al. (2012). Implantation and explantation of an active epiretinal visual prosthesis: 2-year follow-up data from the EPIRET3 prospective clinical trial. Eye (Lond).
84 Roessler G, Laube T, Brockmann C, et al. (2009). Implantation and explantation of a wireless epiretinal retina implant device: observations during the EPIRET3 prospective clinical trial. Invest Ophthalmol Vis Sci.
85 Roessler G, Laube T, Brockmann C, et al. (2011). Angiographic findings following tack fixation of a wireless epiretinal retina implant device in blind RP patients. Graefes Arch Clin Exp Ophthalmol.
86 Mokwa W, Goertz M, Koch C, et al. (2008). Intraocular epiretinal prosthesis to restore vision in blind humans. Conf Proc IEEE Eng Med Biol Soc.
87 Brandi A, Luu CD, Guymer RH, et al. (2016). Progress in the clinical development and utilization of vision prostheses: an update. Eye Brain.
88 Rizzo JF, Ayton LN. (2014). Psychophysical testing of visual prosthetic devices: a call to establish a multi-national joint task force. J Neural Eng.
89 Bittner AK, Jeter P, Dagnelie G. (2011). Grating acuity and contrast tests for clinical trials of severe vision loss. Optom Vis Sci.
90 Kiser AK, Mladenovich D, Eshraghi F, et al. (2005). Reliability and consistency of visual acuity and contrast sensitivity measures in advanced eye disease. Optom Vis Sci.
91 Kiser AK, Mladenovich D, Eshraghi F, et al. (2006). Reliability and consistency of dark-adapted psychophysical measures in advanced eye disease. Invest Ophthalmol Vis Sci.
92 McKnight PE, BabcockParziale J. (2007). Respondent impact on functional ability outcome measures in vision rehabilitation. Optom Vis Sci.
93 Babcock-Parziale J, McKnight PE, Head DN. (2005). Evaluating psychometric properties of a clinical and a self-report blind rehabilitation outcome measure. J Rehabil Res Dev.
94 Finger RP, McSweeney SC, Deverell L, et al. (2014). Developing an instrumental activities of daily living tool as part of the low vision assessment of daily activities protocol. Invest Ophthalmol Vis Sci.
95 Stelmack JA, Stelmack TR, Massof RW. (2002). Measuring low-vision rehabilitation outcomes with the NEI VFQ-25. Invest Ophthalmol Vis Sci.
96 Finger RP, Tellis B, Crewe J, et al. (2014). Developing the impact of vision impairment-very low vision (IVI-VLV) questionnaire as part of the LoVADA protocol. Invest Ophthalmol Vis Sci.
97 Roman AJ, Cideciyan AV, Aleman TS, et al. (2007). Full-field stimulus testing (FST) to quantify visual perception in severely blind candidates for treatment trials. Physiol Meas.
98 (2016). Personal Communication.
99 Jumper JM. (2013). FDA approves world's first artificial retina.
100 Brosky J. (2015). Pixium Vision to challenge Second Sight with retinal implant. Med Dev Daily.
101 (2015). Second Sight announces first successful implant of model of Orion I Visual Cortical Prosthesis.
102 (2016). Personal Communication: patient comment.
103 National Institute for Health and Care Excellence (NICE). (2015). Insertion of an epiretinal prosthesis for retinitis pigmentosa.
104 Vaidya A, Borgonovi E, Taylor RS, et al. (2014). The cost-effectiveness of the Argus II retinal prosthesis in retinitis pigmentosa patients. BMC Ophthalmol.
105 Robinson KA, Saldanha IJ, Mckoy NA. (2011). Frameworks for determining research gaps during systematic reviews.