# Discussion

## Key Findings and Strength of Evidence

The retinal prosthesis system (RPS) studies assessed in this review reported 74 different outcomes, mostly dealing with visual function (31 percent), visual acuity (26 percent), or laboratory-based visual performance measures (30 percent). Day-to-day visual function and quality of life were rarely measured. Little consensus exists among authors of RPS studies about which specific measures are important.

There is some evidence for the validity and/or reliability of the Early Treatment of Diabetic Retinopathy Study (ETDRS), Grating Acuity Test (GAT), Chow Color Test (CCT), and Functional Low-Vision Observer Rated Assessment (FLORA). No included evidence on patients with very low vision addressed the validity or reliability of other outcomes reported in the RPS studies.

Future RPS studies should consider measuring the following outcomes because some evidence shows that they are valid and/or reliable measures in patients with visual acuity 20/200 or worse: full-field flash test (also known as the full field stimulus test), Grating Contrast Sensitivity (GCS), the patient and clinician version of the Functional Assessment of Self-Reliance on Tasks (FAST) instrument, the Very Low Vision Instrumental Activities of Daily Living (IADL-VLV), the Modified National Eye Institute Visual Function Questionnaire 25-item (NEI-VFQ-25) plus supplement, and the Modified Impact of Vision Impairment (IVI).

The table below provides a detailed comparison of the visual acuities of patients assessed in the validation studies compared with the patients enrolled in RPS studies. Three measures in particular have been tested in patients with ultra-low vision. FLORA was tested in a majority of patients enrolled in the Argus II multicenter trial so its applicability to patients implanted with an RPS has been established. The Modified Impact of Vision Impairment Questionnaire and Very Low Vision Instrumental Activities of Daily Living were both tested in patients with Count Finger vision so they are also applicable to this population. The other measures were tested in patients with low but better vision than the typical RPS recipient. However, they represent the best instruments available at this time for measuring other outcomes important to patients receiving an RPS.

Table 7 Baseline vision in the validation studies by baseline vision in the RPS studies

Validation Study Baseline Visual Acuity Instrument(s) Tested | RPS Study and Baseline Visual Acuity
Geruschat et al. 2015^31^ Enrolled a majority (26/30) of Argus II subjects from the multicenter trial so vision was similar to that reported by Ho and colleagues 29 Bare LP in both eyes, 1 No LP FLORA | Arevalo et al. 2015^65,66^ Argus II 7 LP, 1 L projection
Bittner et al. 2011^89^ 32 of 40 eyes met the criteria for legal blindness, best corrected visual acuity 20/200 or worse in the better eye, and/or visual field diameter 20 degrees or less. Grating Acuity Test, ETDRS Visual Acuity, Grating Contrast Sensitivity | Ho et al. 2015 and other authors^15,30,67-76^ Argus II 29 Bare LP in both eyes, 1 No LP
Chow et al. 2010^80^ 17 Mean 1.29 logMAR (range 0.32 to 2.0) Grating Acuity Test and Chow Color Test | Seider and Hahn 2015^77^ Argus II 1 Bare LP
Kiser et al. 2005^90^ 78 subjects in total. Patients with RP were divided into 3 groups of visual acuity (RP-I had VA better than 20/40 [4 patients]; RP-II had VA between 20/40 and 20/199 [12 patients]; RP-III had VA between 20/200 and 20/1000 [10 patients]). Patients with MD were divided into 2 groups of visual acuity (MD-I had VA between 20/200 and 20/500 [8 patients], and MD-II had VA worse than 20/500 [8 patients]). The other 3 patient groups (ON, OR, DR) all had VA worse than 20/200. 18 had normal vision 20/25 or better (control group) ETDRS Visual Acuity | Stingl et al. 2015, 2013^63,64^ Alpha IMS 20 LP without projection, 9 No LP
Finger et al. 2014^96^ 201 patients total. 22% had between 20/200 and counting fingers; 63% had between counting fingers and light perception; 14% had worse than light perception. Modified Impact of Vision Impairment (IVI) questionnaire | Ayton et al. 2014^18^ Bionic Vision 3 LP
Finger et al. 2014^94^ 40 patients total. Mean 2.3 logMAR (SD 1.0) Very Low Vision Instrumental Activities of Daily Living (IADL-VLV) | Rizzo et al. 2014^78^ Argus II 6 Monocular logMAR acuity that was immeasurable and worse than 2.9
McKnight and Babcock-Parziale 2007^92^ 81 patients total. Better eye mean logMAR 1.09 FAST (Functional Assessment of Self-Reliance on Tasks), patient-completed and clinician-completed | Fujikado et al. 2011^23^ STS 2 Bare LP
Roman et al. 2007^97^ 61 patients total. “severely blind”; acuity NR Light Perception test: Full Field Flash Test | Klauke et al. 2011 and other authors^82-86^ EPIRET3 4 LP, 1 No LP, 1 HM
Kiser et al. 2006^91^ 77 patients total. RP patients were divided into 4 groups of visual acuity (RP-I had VA better than 20/40 (8 patients); RP-II had VA between 20/40 and 20/199 (8 patients); RP-III had VA between 20/200 and 20/1000 (12 patients); RP-IV had VA worse than 20/1000 (5 patients)). MD patients were divided into 2 groups of visual acuity (MD-I had VA between 20/200 and 20/500 [12 patients], and MD-II had VA worse than 20/500 [2 patients]). The other 3 patient groups (ON, OR, DR) all had VA worse than 20/200. Light Perception: Full-field flash test | Zrenner et al. 2011^14^ Alpha IMS 3 Blind (bright light stimulation mediated some limited LP without any recognition of shapes)
Babcock-Parziale et al. 2005^93^ 190 patients total. Better eye mean logMAR 1.3 FAST (Functional Assessment of Self-Reliance on Tasks), clinician-completed | Chow et al. 2010, Geruschat at al.^80,81^ Extension study ASR 1 CF at 1– 2 feet, 1 HM at 4–5 feet, 1 HM at 2–3 feet, 1 HM at 1–2 feet, 1 HM at 5–6 feet, 1 HM at 5 feet
Stelmack et al. 2002^95^ 77 patients. Mean 1.00 logMAR Modified NEI-VFQ-25 plus supplement | Chow et al. 2004^22^ ASR At 0.5 m 1 patient (0 letters OD, 0–3 letters OS), 2 patients no letters, 1 patient Bare to No LP, 1 patient HM at 1 foot, 1 patient CF at 1–2 feet

CF=counting fingers; DR=diabetic retinopathy; ETDRS=Early Treatment of Diabetic Retinopathy Study test; FLORA=Functional Low-Vision Observer Rated Assessment; HM=hand motion; logMAR=logarithm of the minimum angle of resolution; L=light; LP=light perception; MD=macular degeneration; NR=not reported; OD=oculus dexter, right eye; ON=optic neuropathy; OR=other retinal disease; OS=oculus sinister, left eye; RP=retinitis pigmentosa; VA= visual acuity

During our interviews with key informants (KIs), particularly patient/advocate KIs, we learned that patients vary in what they expect from a treatment like RPS implantation. Some patients hope to have their sight restored to “normal” vision. Other patients would be satisfied with more modest gains, such as the ability to color coordinate their clothing, use a color-contrast cutting board, or, for those patients with comorbid insulin-dependent diabetes, give themselves insulin injections. With the current state of the technology, both of these expectations may be too high.

One patient who was not a KI but who had a good experience with the Argus II device and commented on our draft report, described his/her experience (the person's sex was not identified), which may reflect a more realistic expectation of RPS implantation. The patient reported that his/her eye had healed sufficiently after just a few weeks and vision improved instantaneously. This patient reported the following improvements:

- Identified the window where the light was coming from
- Located various items hanging on office walls
- Spotted the left and right sides of a doorway
- In conversation, looked a person squarely in the face (rather than trying to aim his/her eyes toward the voice)
- Saw a fireworks display for the first time in 25 years
- Walked with confidence with a white cane on city streets, avoiding the tables and chairs at sidewalk cafes
- Saw his/her two grandchildren standing before him/her and identified them without needing to hear their voices.^102^

Retinal surgeons performing RPS implantation need to accurately present the full range of likely visual acuity gains—which at this point do not include “normal” vision, color vision, or a level of vision sufficient to allow a diabetic to safely self-administer insulin. Surgeons also need to advise patients of the possibility that they may not benefit from an implant and could possibly lose residual light perception following implantation.

When choosing outcomes to include in future RPS studies, investigators should routinely measure quality of life (QoL) and ability to perform activities of daily living (ADLs) in addition to traditional visual acuity measures because these measures are interrelated. Small gains in any vision measure (acuity, visual field, contrast sensitivity, color vision) has the potential to bring about clinically meaningful changes in patients' QoL and ability to perform ADLs.

Although some patients clearly experienced improved visual acuity, visual field, and visual function, the percentages varied greatly among studies of Moderate to High risk of bias. Thus, evidence is insufficient to estimate the proportion of patients who will benefit from an RPS.

There is some suggestion, based on both animal and human studies, that RPSs may have a neuroprotective effect that causes at least a temporary increase in vision in areas far away from the implantation site.

Intraoperative adverse events were reported in more than half of all included studies, the most serious of which included injury to the optic nerve and central retinal defect. Postimplantation adverse events were common and typically mild, including inflammation, temporary intraocular pressure increase, eye scratchiness, and eye-movement restrictions. Serious adverse events were reported by just under half of the studies reporting this outcome and included intraocular pressure increase, hypotony, and presumed endophthalmitis.

## Findings in Relationship to What is Already Known

To assess what is already known about the effectiveness and safety of retinal prostheses for retinitis pigmentosa (RP), we searched for pertinent systematic reviews and cost-effectiveness analyses. We identified one systematic review^103^ and one cost-effectiveness analysis.^104^ The cost-effectiveness analysis^104^ did not offer an independent analysis of effectiveness or safety, since authors simply used the data from the Argus II study by Ho et al. and by other authors.^15,30,67-75^ The systematic review was conducted by the National Institute for Health and Care Excellence (NICE) in the United Kingdom;^103^ its last search date was December 31, 2014. The review included seven publications, and authors acknowledged that some of the publications may have had overlapping patient populations (they did not attempt to identify a set of unique studies). Regarding efficacy, the authors made no overarching statements about efficacy, but rather made five efficacy statements:

- In a case series of 30 patients implanted with an epiretinal prosthesis, improvements in visual acuity were reported in 23 percent (7 of 30 of patients at follow-up of up to 2.7 years). Visual acuity improved from worse than 2.9 logarithm of the minimum angle of resolution (logMAR) to between 2.9 and 1.6 logMAR (p value not reported).^103^
- In the case series of 30 patients, patients were asked to locate a white square that randomly appeared on a black liquid crystal display (LCD) touchscreen. Significantly better square localization test results were reported in 96 percent (27 of 28) of patients when their prosthesis systems were switched on. No further details were provided.^103^
- In the case series of 30 patients, patients were asked to indicate the path of a white bar that swept across a black LCD touchscreen. Significantly better direction of motion test results were observed in 57 percent (16 of 28) of patients when their prosthesis systems were switched on. No further details were provided.^103^
- In the case series of 30 patients, patients were asked to stand in the center of a room, or offset left of center by 3 feet, or offset right of center by 3 feet. They were asked to find a rectangular “door” 20 feet away and to place their hand on it. The mean success rate was 60 percent when the prostheses were switched on compared against 5 percent when the prostheses were switched off, at 24- month followup.^103^
- In a case series of 6 patients, the mean percentage of successful grasps of a white cube placed on a black surface was 69 percent when prostheses were switched on compared against 0 percent when prostheses were switched off, at 3- year follow- up. There was no significant difference between the proportion of successful grasps when patients' eyes were “patched” (both eyes taped closed) or “unpatched.”^103^

All five statements were about the 30-patient Argus II study by Ho et al., also reported by other authors^15,30,67-75^ (the 6-patient case series was a subset). The above statements merely reiterate the data, with no general synthesis of multiple studies. Similarly, regarding safety, the NICE review^103^ simply reiterated data from the studies. Our review includes all the studies included by the NICE review, and several more. In the absence of other evidence syntheses, and given the recent introduction of this technology, we do not comment further on how our findings compare to what is already known.

## Applicability

The patients enrolled in the 11 included RPS publications had RP, choroideremia, rod-cone dystrophy, or Bardet-Biedl syndrome and very low vision (counting fingers to no light perception) and are therefore representative of patients who will receive RPS devices in the future. Because there are no other treatments for patients with late-stage disease, the comparators used in these studies (pre- vs. post-implantation, system ON vs. OFF) were appropriate. One study specified that patients continued to use guide dogs throughout the study and typically underwent cataract removal in conjunction with the implantation procedure.

The maximum duration of study followup was 10 years for one patient with the Artificial Silicon Retina (ASR) device. In the Argus II study, 24 of 30 patients still had functioning devices at a mean of 6.2 years followup. Because patients as young as 25 years of age may receive this device, longer term followup is needed. One single-patient cadaver study suggested that the ASR device had a functional life expectancy of about 20 years.

Outcomes reported in these studies were varied, making cross-study comparisons difficult. Additionally, outcomes were often not measured with valid and/or reliable instruments.

Only a limited number of sites are currently permitted to perform Argus II surgery, but that number will increase over time. As the procedure diffuses more widely outcomes may vary from those at the clinical trial sites, which have received significant training and other resources for surgeons and other personnel involved in caring for the participating patients.

## Implications for Clinical and Policy Decisionmaking

Due to inconsistencies in the evidence, this report makes no conclusions about the likelihood of patient benefit from RPS. Clearly, however, some patients do benefit. The magnitude of that benefit is unknown because of a paucity of evidence on QoL and day-to-day function. However, for these patients, no other intervention exists to address their vision problems, so even small gains may be considered important for clinical and policy decisionmaking.

## Limitations of the Systematic Review Process

The first set of challenges we faced involved literature searching. Even the best search strategies may fail to identify certain records; however, the chance of missing relevant studies is greatly reduced when searches are conducted, as they were for this report, across multiple resources using a combination of controlled vocabulary and keywords. Also, our information specialists searched the Web sites of selected medical association meetings for abstracts and presentation on retinal prosthetic devices.

Key Question 1C presented a particular search challenge, in that the scope of this question was extremely broad. To focus the search, the search strategies for this question (see Appendix A) included some additional limiting options, such as searching for controlled terms that had been indexed as a major focus of the article, and using additional terminology to identify studies that reported reliability, reproducibility, validity, and responsiveness. An additional bibliographic database, PsycINFO, was also introduced to ensure that relevant studies published in the psychological literature were captured.

## Limitations of the Evidence Base

Two key limitations of the evidence base concern heterogeneity of interventions and comparators. First, the 11 studies used six different types of RPSs, and they are in different phases of development and testing. This means that the tested systems may differ in important ways from future versions. We excluded any systems that are known to be obsolete, in an effort to focus on our efforts on current systems. The only RPS that is cleared for marketing in the United States is the Argus II; therefore, this device's outcomes are likely more relevant to U.S. decisionmakers. Second, different studies used different comparators. Some compared patients' pre-implant performance to their post-implant performance. Others compared post-implant ON performance to post-implant OFF performance. Still others compared an implanted eye to an unimplanted eye (presuming that the patients' two eyes had similar acuity and function before implant, which is often not the case). And still others compared post-implant ON performance to a predefined level of chance performance. The variety of comparators clouded whatever true RPS benefits exist.

Another set of problems concerned the outcomes. We noted large variability in the types of outcomes used by authors in an effort to measure the impact of RPS. For visual acuity alone, 19 different outcomes were found in just 9 studies. Part of the reason for this is that visual acuity is a multifaceted concept. Even for a given acuity test, however, authors often reported data in different ways. The most common method was to report the proportion of patients who improved as compared to pre-implantation. Another method of reporting was to compare the proportion of patients who passed a test before versus after implantation (which differs subtly from the proportion improved, since some patients could pass a test both before and after, and yet still have improved). Other studies reported mean results of tests such as logMAR, the number of seconds to identify letters on a screen, or the total number of letters identified correctly. Furthermore, only four of the reported tests have been tested for psychometric properties (see Key Question 1B). Other tests are available (see Key Question 1C) that have been specifically developed for people with very low vision, and future authors of RPS studies should consider them.

A fourth limitation was the small size of the typical study of RPS. The median study enrollment was six patients. Furthermore, some enrolled patients did not receive all of the post-implantation tests, so the actual number of patients per study with data on certain outcomes was sometimes only one or two. These low counts are reflected in the wide confidence intervals around proportion estimates in figures for Key Question 2, as well as our ratings of imprecision during strength-of-evidence assessment. Granted, RPS is rare, and large studies are impractical. However, large imprecision results in little confidence in any estimate of the proportion of patients who would improve after RPS implantation.

## Evidence Gaps

We used Evidence-based Practice Center guidance by Robinson et al.^105^ to delineate reasons for the evidence gaps: A. Insufficient or imprecise information; B. Biased information; C. Inconsistency or unknown consistency; D. Not the right information.

The first identified gap is the paucity of direct information about how RPS affects quality of life. Only one of the 11 included RPS studies reported data on a quality-of-life instrument (NEI-VFQ-25-German Version). Authors reported no statistically significant change in QoL at 3 weeks after implantation or during the 2-year study period after planned explantation of the device. This does not mean there was no change, because the study was too small (only 6 patients enrolled, and only 5 at final follow up) to rule out the possibility of a difference, and the instrument, albeit tested in a low-vision population, may not have been sensitive enough to measure change in this ultra-low vision population. We recognize that the other reported outcomes (visual acuity, laboratory-based measures of function, day-to-day function) may be surrogates for QoL (on the premise that improved acuity will translate into improved quality of life). However, these outcomes are less patient-oriented than QoL itself. The reason for this gap is A: Insufficient or imprecise information.

The second identified gap is the inability to estimate the proportion of patients who improve after RPS implantation. Because studies used different devices, different comparators, and different outcomes (see previous section), there can be no single estimate of the proportion, because all of these aspects will likely affect improvement rates. Even controlling for type of RPS, there was too much outcome heterogeneity to permit an estimate. The reason for this gap is C: Inconsistency.

A fourth gap involved psychometric testing of outcome measures in patients with very low vision (Key Questions 1A and 1B). The studies we found used relatively advanced methods for testing psychometric properties (i.e., Rasch-based analysis, and separation of item difficulty from person ability). Several of these studies had devised new instruments specifically for people with very low vision. The 11 included RPS studies, however, generally did not use these tests (an exception was the Chow et al. studies of the Artificial Silicon Retina,^22,80,81^ which also provided psychometric properties of certain tests). The reason for this gap is D: Not the right information. We encourage greater use of tested instruments in future studies of RPS. With greater consistency of outcome measures, future evidence reviews might be able to estimate the likelihood of improvement after RPS implantation.

A fifth “gap” involves Key Question 5 (off-label uses and other uses of RPS), for which we found one ongoing trial of the Argus II device in patients diagnosed with dry age-related macular degeneration (AMD; NCT02227498). We summarized narrative reviews, and mention a few possible alternate uses. The reason for this gap is A: Insufficient or imprecise information.

## Conclusion

Future studies of RPS devices should make an effort to report valid and reliable measures of important outcomes, especially day-to-day function and quality of life using the FLORA, IADL-VLV, and IVI.