# Abbreviations and Acronyms

ADL: activities of daily living
ADLMS: activities of daily living mobility and safety
AE: adverse event
AFC: alternative forced choice
AHRQ: Agency for Healthcare Research and Quality
AMD: age-related macular degeneration
ANOVA: analysis of variance
AREDS: Age-Related Eye Disease Study
ARVO: Association for Research in Vision and Ophthalmology
ASR: Artificial Silicon Retina
BaLM: Basic Assessment of Light and Motion (BaLM) test
CCT: Chow Color Test
CF: counting fingers
CINAHL: Cumulative Index to Nursing and Allied Health
cm: centimeter
CMS: U.S. Centers for Medicare and Medicaid
CNV: choroidal neovascularization
COI: conflict of interest
COSMIN: COnsensus-based Standards for the selection of health Measurement Instruments
CoV: coefficient of variation
CR._95_: coefficient of repeatability
dB: decibel
EPC: Evidence-based Practice Center
ERG: electroretinographic
ETDRS: Early Treatment of Diabetic Retinopathy Study test
EWB: emotional well-being
FAST: Functional Assessment of Self-Reliance on Tasks
FDA: U.S. Food and Drug Administration
FLORA: Functional Low-Vision Observer Rated Assessment
FrACT: Freiburg Acuity and Contrast Test
GA: geographic atrophy
GAT: Grating Acuity Test
GCS: Grading Contrast Sensitivity test
HM: hand motion
HRQoL: health-related quality of life
IADL-VLV: very low vision instrumental activities of daily living
IOP: intraocular pressure
IVI: Modified Impact of Vision Impairment
KI: Key Informant
KQ: Key Question
LCD: liquid crystal display
LED: light-emitting diode
logMAR: logarithm of the minimum angle of resolution
LP: light perception
mm Hg: millimeters of mercury
MRI: magnetic resonance imaging
NA: not applicable
NEI-VFQ-25: National Eye Institute Visual Function Questionnaire 25-item
NICE: National Institute for Health and Care Excellence
NR: not reported
OD: oculus dextrus; right eye
OS: oculus sinister; left eye
OUReP: Okayama University-Type Retinal Prosthesis
PICOTS: population, intervention, comparators, outcomes, timing, and setting
QoL: quality of life
RCS: Royal College of Surgeons
Rng: range
RP: retinitis pigmentosa
RPE: retinal pigment epithelium
RPS: retinal prosthesis system
SAE: serious adverse event
SD: standard deviation
STS: Suprachoroidal Transretinal Stimulation
UK: United Kingdom
VA: Veterans Health Administration
VEGF: vascular endothelial growth factor
VF: visual field