# References

1 Metzger BE, Coustan DR. Summary and recommendations of the Fourth International Workshop-Conference on Gestational Diabetes Mellitus. The Organizing Committee. Diabetes Care. 1998;21(Suppl 2):B161-B167. [pmid: 9704245].
2 Beckles GL, Thompson-Reid PE, editors. Diabetes and women’s health across the life stages: A public health perspective. Atlanta. U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Division of Diabetes Translation. 2001.
3 Hunt KJ, Schuller KL. The increasing prevalence of diabetes in pregnancy. Obstet Gynecol Clin North Am. 2007;34(2):173-199. vii. [pmid: 17572266].
4 Ferrara A, Hedderson MM, Quesenberry CP, et al. Prevalence of gestational diabetes mellitus detected by the national diabetes data group or the carpenter and coustan plasma glucose thresholds. Diabetes Care. 2002;25(9):1625-1630. [pmid: 12196438].
5 Rosenberg TJ, Garbers S, Lipkind H, et al. Maternal obesity and diabetes as risk factors for adverse pregnancy outcomes: differences among 4 racial/ethnic groups. Am J Public Health. 2005;95(9):1545-1551. [pmid: 16118366].
6 Feig DS, Zinman B, Wang X, et al. Risk of development of diabetes mellitus after diagnosis of gestational diabetes. CMAJ. 2008;179(3):229-234. [pmid: 18663202].
7 Nicholson WK, Wilson LM, Witkop CT, et al. Therapeutic management, delivery, and postpartum risk assessment and screening in gestational diabetes. Evid Rep Technol Assess (Full Rep). 2008;(162):1-96. [pmid: 18457474].
8 Bennett WL, Bolen S, Wilson LM, et al. Performance characteristics of postpartum screening tests for type 2 diabetes mellitus in women with a history of gestational diabetes mellitus: a systematic review. J Womens Health (Larchmt). 2009;18(7):979-987. [pmid: 19575688].
9 Golden SH, Bennett WL, Baptist-Roberts K, et al. Antepartum glucose tolerance test results as predictors of type 2 diabetes mellitus in women with a history of gestational diabetes mellitus: a systematic review. Gend Med. 2009;6(Suppl 1):109-122. [pmid: 19318222].
10 Baptiste-Roberts K, Barone BB, Gary TL, et al. Risk factors for type 2 diabetes among women with gestational diabetes: a systematic review. Am J Med. 2009;122(3):207-214. e4. [pmid: 19272478].
11 Witkop CT, Neale D, Wilson LM, et al. Active compared with expectant delivery management in women with gestational diabetes: a systematic review. Obstet Gynecol. 2009;113(1):206-217. [pmid: 19104376].
12 Nicholson W, Bolen S, Witkop CT, et al. Benefits and risks of oral diabetes agents compared with insulin in women with gestational diabetes: a systematic review. Obstet Gynecol. 2009;113(1):193-205. [pmid: 19104375].
13 Jones J, Hunter D. Consensus methods for medical and health services research. BMJ. 1995;311(7001):376-380. [pmid: 7640549].