# Abbreviations

ACOG: American College of Obstetricians and Gynecologists
ADA: American Diabetes Association
AHRQ: Agency for Healthcare Research and Quality
BMI: Body Mass Index
DPP-4: Dipeptidyl Peptidase-4
EFW: Estimated Fetal Weight
FBG: Fasting Blood Glucose
FDA: Food and Drug Administration
GDM: Gestational Diabetes Mellitus
GLP-1: Glucagon-Like Peptide-1
HbA1c: Hemoglobin A1c
HDL: High Density Lipoproteins
HPA: Hypothalamic-Pituitary-Adrenal
IRB: Institutional Review Board
JHU EPC: Johns Hopkins University Evidence-based Practice Center
NICU: Neonatal Intensive Care Unit
NIH: National Institutes of Health
OGTT: Oral Glucose Tolerance Test
PICO: Population, Intervention, Comparison, and Outcomes
PPG: Postpartum Glucose
RCT: Randomized Controlled Trial
TZD: Thiazolidinedione
WHO: World Health Organization