# Conclusions

Using the 2008 evidence report as a starting point, we developed an eight-step process and identified fifteen research questions on GDM considered of high clinical importance by a multidisciplinary group of stakeholders. We also prioritized outcomes of highest clinical benefit related to six of these questions. In addition, we evaluated the process through a feedback mechanism from the evidence report authors and local and external stakeholders. We anticipate that our process could be used as is, or modified based on the evaluations, as a model for using other evidence reports to take the next step of developing research questions in areas of highest clinical importance. This next step would enable researchers and funding agencies to focus their resources in areas of highest need to make the most clinical impact.