# Appendix D Excluded Studies

Exclusion Codes
E1. Not relevant
E2. Not English
E3. Not original research
E4. Publication date (2009-present for KQ1-3; 2005-present for KQ4-5)
E5. Ineligible COUNTRY
E6. Ineligible SETTING; - E6a. Recreational/tourism; - E6b. Not primary care referable; - E6c. Occupational; - E6d. Childcare/school; - E6e. Other ineligible setting (community, etc.)
E7. Ineligible POPULATION; - E7a. Melanoma patients; - E7b. NMSC patients; - E7c. Other patients under skin cancer surveillance because of known increased risks
E8. Ineligible OUTCOMES; - E8a. Skin cancer metastasis or progression; - E8b. For KQs 1, 2, 4: Outcomes assessed <3 months after baseline assessment; - E8c. Protocol only/results-not-yet-reported; - E8d. Other ineligible outcomes
E9. Ineligible INTERVENTION; - E9a. Mass media campaign; - E9b. Community interventions not affiliated with primary care; - E9c. Can't assess impact of primary care-referable component
E10. Ineligible STUDY DESIGN; - E10a. No comparison group; - E10b. Comparison group is another skin cancer counseling intervention; - E10c. Other ineligible design
E11. Irretrievable
E12. Poor QUALITY

1 SunSmart UV Alert. 2009;:. PMID: . KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.
2 Behavioral counseling to prevent skin cancer: recommendation statement. Am Fam Physician. 2012;868:3-Jan. PMID: 23062167. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.23062167
3 IARC monographs on the evaluation of carcinogenic risks to humans. Solar and ultraviolet radiation. IARC Monogr Eval Carcinog Risks Hum. 1992;55:1-316. PMID: 1345607. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.1345607
4 Aarestrup C, Bonnesen CT, Thygesen LC . The effect of a school-based intervention on sunbed use in Danish pupils at continuation schools: a cluster-randomized controlled trial. Journal of Adolescent Health. 2014;542:214-20. PMID: 24119418. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E8, KQ5E8.24119418
5 Agbai ON, Buster K, Sanchez M . Skin cancer and photoprotection in people of color: a review and recommendations for physicians and the public. J Am Acad Dermatol. 2014;704:748-62. PMID: 24485530. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.24485530
6 Aitken JF, Elwood JM, Lowe JB . A randomised trial of population screening for melanoma. J Med Screen. 2002;91:33-7. PMID: 11943795. KQ1E8, KQ2E8, KQ3E8, KQ4E6e, KQ5E8c.11943795
7 Aitken JF, Youl PH, Janda M . Increase in skin cancer screening during a community-based randomized intervention trial. International Journal of Cancer. 2006;1184:1010-6. PMID: 16152577. KQ1E9c, KQ2E9c, KQ3E9c, KQ4E9c, KQ5E9c.16152577
8 Alberta Provincial Cutaneous Tumour Team Prevention of Skin Cancer: Clinical Practice Guideline CU-014. . 2013;:. PMID: . KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.
9 Alexander M, Mellor JD, McArthur G . “Ipilimumab in pretreated patients with unresectable or metastatic cutaneous, uveal and mucosal melanoma”. Med J Aust. 2014;2011:49-53. PMID: 24999899. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E8.24999899
10 American Academy of Dermatology Ad Hoc Task Force for the ABCDEs of Melanoma, Tsao H, Olazagasti JM, Cordoro KM . Early detection of melanoma: reviewing the ABCDEs. Journal of the American Academy of Dermatology. 2015;724:717-23. PMID: 25698455. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.25698455
11 American Academy of Family Physicians Summary of Recommendations for Clinical Preventive Services. . 2015;:. PMID: . KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.
12 American Cancer Society Cancer Prevention & Early Detection Facts & Figures 2015-2016. . 2015;:. PMID: . KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.
13 Andreeva VA, Cockburn MG, Yaroch AL . Preliminary evidence for mediation of the association between acculturation and sun-safe behaviors. Arch Dermatol. 2011;1477:814-9. PMID: 21768480. KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E9.21768480
14 Aneja S, Brimhall AK, Aneja S . Computerized interactive educational tools used to improve use of sun-protective clothing and sunscreen: a randomized controlled study. Arch Dermatol. 2012;14811:1325-7. PMID: 23165847. KQ1E8d, KQ2E12, KQ3E8, KQ4E8, KQ5E8.23165847
15 Aneja S, Brimhall AK, Kast DR . Improvement in Patient Performance of Skin Self-examinations After Intervention With Interactive Education and Telecommunication Reminders: A Randomized Controlled Study. Archives of Dermatology. 2012;14811:1266-72. PMID: 22911048. KQ1E8, KQ2E12, KQ3E8, KQ4E8, KQ5E8.22911048
16 Anonymous “Summaries for patients. Screening for skin cancer: U.S. Preventive Services Task Force recommendation.[Original report in Ann Intern Med. 2009 Feb 3;150(3):194-8; PMID: 19189909], [Original report in Ann Intern Med. 2009 Feb 3;150(3):188-93; PMID: 191899. Annals of Internal Medicine. 2009;1503:I40. PMID: 19189902. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.19189902
17 Armstrong AW, Idriss NZ, Kim RH. “Effects of video-based, online education on behavioral and knowledge outcomes in sunscreen use: a randomized controlled trial”. Patient Education & Counseling. 2011;832:273-7. PMID: 20570081. KQ1E8, KQ2E10a, KQ3E8, KQ4E8, KQ5E8.20570081
18 Armstrong AW, Watson AJ, Makredes M . “Text-message reminders to improve sunscreen use: a randomized, controlled trial using electronic monitoring”. Archives of Dermatology. 2009;14511:1230-6. PMID: 19917951. KQ1E8b, KQ2E8b, KQ3E8d, KQ4E8b, KQ5E8d.19917951
19 Arnold MR, DeJong W. Skin self-examination practices in a convenience sample of U.S. university students. Preventive Medicine. 2005;403:268-73. PMID: 15533538. KQ1E1, KQ2E1, KQ3E1, KQ4E8, KQ5E8.15533538
20 Arundel P, Ahmed SF, Allgrove J . British Paediatric and Adolescent Bone Group's position statement on vitamin D deficiency. BMJ. 2012;345:e8182. PMID: 23208261. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.23208261
21 Ashrafioun L, Bonar EE. Development of a brief scale to assess frequency of symptoms and problems associated with tanning. Journal of the American Academy of Dermatology. 2014;703:588-9. PMID: 24528910. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.24528910
22 Auster J, Hurst C, Neale RE . Determinants of uptake of whole-body skin self-examination in older men. Behavioral Medicine. 2013;392:36-43. PMID: 23668910. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.23668910
23 Austoker J, Bankhead C, Forbes LJ . Interventions to promote cancer awareness and early presentation: systematic review. British Journal of Cancer. 2009;0:S31-9. PMID: 19956160. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.19956160
24 Autier P, Boniol M, Dore JF. Sunscreen use and increased duration of intentional sun exposure: still a burning issue. Int J Cancer. 2007;1211:5-Jan. PMID: 17415716. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.17415716
25 Autier P, Dore JF, Negrier S . “Sunscreen use and duration of sun exposure: a double-blind, randomized trial”. J Natl Cancer Inst. 1999;9115:1304-9. PMID: 10433619. KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E9.10433619
26 Autier P, Dore JF, Reis AC . Sunscreen use and intentional exposure to ultraviolet A and B radiation: a double blind randomized trial using personal dosimeters. Br J Cancer. 2000;839:1243-8. PMID: 11027441. KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E9.11027441
27 Autier P. Sunscreen abuse for intentional sun exposure. Br J Dermatol. 2009;0:40-5. PMID: 19775356. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.19775356
28 Badertscher N, Meier M, Rosemann T . The role of skin self-examination at the Swiss skin cancer day. BMC Health Services Research. 2014;14:581. PMID: 25408258. KQ1E6e, KQ2E6e, KQ3E6e, KQ4E6e, KQ5E6e.25408258
29 Baker MK, Hillhouse JJ, Liu X. The effect of initial indoor tanning with mother on current tanning patterns. Archives of Dermatology. 2010;14612:1427-8. PMID: 21173329. KQ1E10, KQ2E10, KQ3E8, KQ4E8, KQ5E8.21173329
30 Balk SJ, O'Connor KG, Saraiya M. Counseling parents and children on sun protection: a national survey of pediatricians. Pediatrics. 2004;1144:1056-64. PMID: 15466105. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.15466105
31 Balyaci OE, Kostu N, Temel AB. Training program to raise consciousness among adolescents for protection against skin cancer through performance of skin self examination. Asian Pacific Journal of Cancer Prevention: Apjcp. 2012;1310:5011-7. PMID: 23244101. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.23244101
32 Bandi P, Cokkinides VE, Weinstock MA . “Physician sun protection counseling: prevalence, correlates, and association with sun protection practices among US adolescents and their parents, 2004”. Prev Med. 2010;512:172-7. PMID: 20478331. KQ1E10, KQ2E10, KQ3E8, KQ4E8, KQ5E8.20478331
33 Bandi P, Cokkinides VE, Weinstock MA . “Sunburns, sun protection and indoor tanning behaviors, and attitudes regarding sun protection benefits and tan appeal among parents of U.S. adolescents-1998 compared to 2004”. Pediatric Dermatology. 2010;271:18-Sep. PMID: 20199403. KQ1E10, KQ2E10, KQ3E8, KQ4E8, KQ5E8.20199403
34 Barton MK. Skin self-examination for concerning pigmented lesions appears to be consistent with dermatologist examination. CA: a Cancer Journal for Clinicians. 2015;656:423-4. PMID: 26352483. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.26352483
35 Barton MK. Sunscreen use in adults is beneficial in preventing melanoma. CA: a Cancer Journal for Clinicians. 2011;613:137-8. PMID: 21532097. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.21532097
36 Bataille V, Boniol M, De Vries E . A multicentre epidemiological study on sunbed use and cutaneous melanoma in Europe. Eur J Cancer. 2005;4114:2141-9. PMID: 16125927. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.16125927
37 Battie C, Gohara M, Verschoore M . “Skin cancer in skin of color: an update on current facts, trends, and misconceptions”. J Drugs Dermatol. 2013;122:194-8. PMID: 23377393. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.23377393
38 Bauer A, Diepgen TL, Schmitt J. Is occupational solar ultraviolet irradiation a relevant risk factor for basal cell carcinoma? A systematic review and meta-analysis of the epidemiological literature. Br J Dermatol. 2011;1653:612-25. PMID: 21605109. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.21605109
39 Bauer J, Buttner P, Wiecker TS . “Interventional study in 1,232 young German children to prevent the development of melanocytic nevi failed to change sun exposure and sun protective behavior”. Int J Cancer. 2005;1165:755-61. PMID: 15849749. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E6d, KQ5E6d.15849749
40 Bentzen J, Krarup AF, Castberg IM . Determinants of sunbed use in a population of Danish adolescents. European Journal of Cancer Prevention. 2013;222:126-30. PMID: 22895295. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.22895295
41 Bergstrom KG. “News, views, and reviews. Carrots before sticks: appealing to vanity promotes sun protection”. Journal of Drugs in Dermatology: JDD. 2013;128:952-3. PMID: 23986171. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.23986171
42 Bertolin M, Cercatto MC, Requena C . “Awareness, Attitude, and Adherence to Preventive Measures in Patients at High Risk of Melanoma. A Cross-Sectional Study on 185 Patients”. Journal of Cancer Education. 2015;303:552-66. PMID: 25510366. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.25510366
43 Berwick M, Armstrong BK, Ben-Porat L . Sun exposure and mortality from melanoma. J Natl Cancer Inst. 2005;973:195-9. PMID: 15687362. KQ1E8, KQ2E8, KQ3E8, KQ4E9, KQ5E9.15687362
44 Berwick M, Begg CB, Fine JA . Screening for cutaneous melanoma by skin self-examination. J Natl Cancer Inst. 1996;881:17-23. PMID: 8847720. KQ1E8, KQ2E8, KQ3E8, KQ4E9, KQ5E9.8847720
45 Berwick M. “The good, the bad, and the ugly of sunscreens”. Clin Pharmacol Ther. 2011;891:31-3. PMID: 21170070. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.21170070
46 Bhave N, Reidy K, Randall Kinsella T, Brodsky AL, Robinson JK Caregivers' Response to Pediatric Clinicians Sun Protection Anticipatory Guidance: Sun Protective Swim Shirts for 2-6 year old Children. J Community Med Health Educ. 2014;4316:2161-0711.. PMID: . KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.
47 Biba E. Protection: the sunscreen pill. Nature. 2014;5157527:S124-5. PMID: 25407711. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.25407711
48 Blashill AJ, Safren SA. Skin cancer risk behaviors among US men: the role of sexual orientation. Am J Public Health. 2014;1049:1640-1. PMID: 25033138. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.25033138
49 Blashill AJ, Williams A, Grogan S . Negative appearance evaluation is associated with skin cancer risk behaviors among American men and women. Health Psychol. 2015;341:93-6. PMID: 25133823. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.25133823
50 Bodekaer Larsen M, Petersen B, Philipsen PA . Sun exposure and protection behavior of Danish farm children: parental influence on their children. Photochemistry & Photobiology. 2014;905:1193-8. PMID: 24749661. KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E9.24749661
51 Boniol M, Autier P, Boyle P . Cutaneous melanoma attributable to sunbed use: systematic review and meta-analysis. BMJ. 2012;345:e4757. PMID: 22833605. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.22833605
52 Bowen D, Jabson J, Haddock N . Skin care behaviors among melanoma survivors. Psycho-Oncology. 2012;2112:1285-91. PMID: 21780240. KQ1E7a, KQ2E7a, KQ3E7a, KQ4E7a, KQ5E7a.21780240
53 Bowen DJ, Burke W, Hay JL . Effects of web-based intervention on risk reduction behaviors in melanoma survivors. Journal of Cancer Survivorship. 2015;92:279-86. PMID: 25425205. KQ1E7a, KQ2E7a, KQ3E7a, KQ4E7a, KQ5E7a.25425205
54 Boyle R, O'Hagan AH, Donnelly D . “Trends in reported sun bed use, sunburn, and sun care knowledge and attitudes in a U.K. region: results of a survey of the Northern Ireland population”. British Journal of Dermatology. 2010;1636:1269-75. PMID: 20716213. KQ1E10, KQ2E10, KQ3E9, KQ4E9, KQ5E9.20716213
55 Branstrom R, Hedblad MA, Krakau I . Laypersons' perceptual discrimination of pigmented skin lesions. J Am Acad Dermatol. 2002;465:667-73. PMID: 12004305. KQ1E8, KQ2E8, KQ3E8, KQ4E9, KQ5E9.12004305
56 Breitbart EW, Choudhury K, Anders MP . Benefits and risks of skin cancer screening. Oncol Res Treat. 2014;0:38-47. PMID: 25195831. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.25195831
57 British Association of Dermatologists, Cancer Research UK, Diabetes UK, Multiple Sclerosis Society, National Heart Forum, National Osteoporosis Society, Primary Care Dermatology Society Consensus Vitamin D position statement. . 2010;:. PMID: . KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.
58 Buendia Eisman A, Arias Santiago S, Moreno-Gimenez JC . An Internet-based programme to promote adequate UV exposure behaviour in adolescents in Spain. Journal of the European Academy of Dermatology & Venereology. 2013;274:442-53. PMID: 22329864. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E6d, KQ5E6d.22329864
59 Buendia-Eisman A, Conejo-Mir J, Prieto L . “Buen Rayito Study: awareness, attitudes and behavior of teenagers to sunlight through a web based system in Spain”. European Journal of Dermatology. 2013;234:505-9. PMID: 24001588. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.24001588
60 Buller DB, Andersen PA, Walkosz BJ . Enhancing industry-based dissemination of an occupational sun protection program with theory-based strategies employing personal contact. American Journal of Health Promotion. 2012;266:356-65. PMID: 22747318. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c, KQ5E6c.22747318
61 Buller DB, Berwick M, Lantz K . “Smartphone mobile application delivering personalized, real-time sun protection advice: a randomized clinical trial”. JAMA Dermatology. 2015;1515:497-504. PMID: 25629710. KQ1E7c, KQ2E7c, KQ3E7c, KQ4E7c, KQ5E7c.25629710
62 Buller DB, Berwick M, Lantz K . Evaluation of immediate and 12-week effects of a smartphone sun-safety mobile application: a randomized clinical trial. JAMA Dermatol. 2015;1515:505-12. PMID: 25629819. KQ1E8b, KQ2E8b, KQ3E7b, KQ4E8b, KQ5E7b.25629819
63 Buller DB, Cokkinides V, Hall HI . “Prevalence of sunburn, sun protection, and indoor tanning behaviors among Americans: review from national surveys and case studies of 3 states”. J Am Acad Dermatol. 2011;650:S114-23. PMID: 22018060. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.22018060
64 Buller Db, Berwick M, Lantz K, Buller Mk, Shane J, Kane I, Liu X Evaluation of immediate and 12-week effects of a smartphone sun-safety mobile application: a randomized clinical trial. JAMA dermatology. 2015;1515:505-12. PMID: 0. KQ1E8b, KQ2E8b, KQ3E8b, KQ4E8b, KQ5E8b.
65 Butler DP, Lloyd-Lavery A, Archer CM . Awareness of and attitudes towards skin-cancer prevention: a survey of patients in the UK presenting to their general practice. Clin Exp Dermatol. 2013;384:338-43. PMID: 23530554. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.23530554
66 Caini S, Boniol M, Botteri E . The risk of developing a second primary cancer in melanoma patients: a comprehensive review of the literature and meta-analysis. J Dermatol Sci. 2014;751:9-Mar. PMID: 24680127. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.24680127
67 Canadian Cancer Society Being Safe in the Sun. . 2015;201543098:. PMID: . KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.
68 Cariou C, Gonzales M, Krebill H. “Adapting and implementing an evidence-based sun-safety education program in rural Idaho, 2012”. Prev Chronic Dis. 2014;11:E77. PMID: 24809363. KQ1E6a, KQ2E6a, KQ3E6a, KQ4E6a, KQ5E6a.24809363
69 Carli P, De Giorgi V, Palli D . Dermatologist detection and skin self-examination are associated with thinner melanomas: results from a survey of the Italian Multidisciplinary Group on Melanoma. Arch Dermatol. 2003;1395:607-12. PMID: 12756097. KQ1E8, KQ2E8, KQ3E8, KQ4E9, KQ5E9.12756097
70 Carrera C, Puig-Butille JA, Aguilera P . Impact of sunscreens on preventing UVR-induced effects in nevi: in vivo study comparing protection using a physical barrier vs sunscreen. JAMA Dermatology. 2013;1497:803-13. PMID: 23699984. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.23699984
71 CDC “Sunburn and sun protective behaviors among adults aged 18-29 years--United States, 2000-2010”. MMWR Morb Mortal Wkly Rep. 2012;6118:317-22. PMID: 22572977. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.22572977
72 Chao LX. and Patterson SS. and Rademaker AW. and Liu D. and Kundu RV. Melanoma Perception in People of Color: A Targeted Educational Intervention. American Journal of Clinical Dermatology. 2016;29:29. PMID: . KQ1E8b, KQ2E8b, KQ3E8b, KQ4E8b, KQ5E8b.
73 Chesnut C, Kim J. Is there truly no benefit with sunscreen use and Basal cell carcinoma? A critical review of the literature and the application of new sunscreen labeling rules to real-world sunscreen practices. J Skin Cancer. 2012;2012:480985. PMID: 22649734. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.22649734
74 Chia A, Trevena L. A Systematic Review of Training to Improve Melanoma Diagnostic Skills in General Practitioners. J Cancer Educ. 2015;:. PMID: 26070535. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.26070535
75 Choi K, Lazovich D, Southwell B . Prevalence and characteristics of indoor tanning use among men and women in the United States. Archives of Dermatology. 2010;14612:1356-61. PMID: 21173319. KQ1E10, KQ2E10, KQ3E10, KQ4E8, KQ5E8.21173319
76 Christensen K, Champion J, Wagner C “The effects of appearance-based and health-based interventions on sun protection attitudes, intentions, and behaviors of college students”. Psycho-oncology. 2014;23:317. PMID: 0. KQ1E11, KQ2E11, KQ3E11, KQ4E11, KQ5E11.
77 Cleary Cm, White Km, Young Rm, Hawkes Al, Leske S, Starfelt Lc, Wihardjo K Study protocol: A randomised controlled trial of a theory-based online intervention to improve sun safety among Australian adults. BMC cancer. 2014;141:. PMID: 0. KQ1E8c, KQ2E8c, KQ3E8c, KQ4E8c, KQ5E8c.
78 Clipp SL, Burke A, Hoffman-Bolton J . Sun-seeking behavior to increase cutaneous vitamin D synthesis: when prevention messages conflict. Public Health Reports. 2011;1264:533-9. PMID: 21800747. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.21800747
79 Cohen Liza, Brown Judith, Haukness Heather, Walsh Lori, Robinson June K Sun protection counseling by pediatricians has little effect on parent and child sun protection behavior. The Journal of pediatrics. 2013;1622:381-386. PMID: . KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.
80 Cokkinides VE, Bandi P, Weinstock MA . Use of sunless tanning products among US adolescents aged 11 to 18 years. Archives of Dermatology. 2010;1469:987-92. PMID: 20855697. KQ1E10, KQ2E10, KQ3E10, KQ4E8, KQ5E8.20855697
81 Cooper Dp, Goldenberg Jl, Arndt J “Perceived efficacy, conscious fear of death and intentions to tan: not all fear appeals are created equal”. British journal of health psychology. 2014;191:15-Jan. PMID: 0. KQ1E6a, KQ2E6a, KQ3E6a, KQ4E6a, KQ5E6a.
82 Coups EJ, Manne SL, Heckman CJ Multiple skin cancer risk behaviors in the U.S. population. Am J Prev Med. 2008;342:87-93. PMID: 18201637. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E8.18201637
83 Coups EJ, Stapleton JL, Hudson SV . Skin cancer surveillance behaviors among US Hispanic adults. Journal of the American Academy of Dermatology. 2013;684:576-84. PMID: 23182066. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.23182066
84 Coups EJ, Stapleton JL, Hudson SV . Sun protection and exposure behaviors among Hispanic adults in the United States: differences according to acculturation and among Hispanic subgroups. BMC Public Health. 2012;12:985. PMID: 23153104. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.23153104
85 Craciun C, Schuz N, Lippke S . Facilitating sunscreen use in women by a theory-based online intervention: a randomized controlled trial. Journal of Health Psychology. 2012;172:207-16. PMID: 21752862. KQ1E8, KQ2E8b, KQ3E8, KQ4E8, KQ5E8.21752862
86 Crump C, Sundquist K, Sieh W . Season of birth and other perinatal risk factors for melanoma. International Journal of Epidemiology. 2014;433:793-801. PMID: 24453238. KQ1E9, KQ2E8, KQ3E8, KQ4E8, KQ5E8.24453238
87 Cust AE, Armstrong BK, Goumas C . Sunbed use during adolescence and early adulthood is associated with increased risk of early-onset melanoma. Int J Cancer. 2011;12810:2425-35. PMID: 20669232. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.20669232
88 Cust AE, Jenkins MA, Goumas C . Early-life sun exposure and risk of melanoma before age 40 years. Cancer Causes Control. 2011;226:885-97. PMID: 21472378. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.21472378
89 Day AK, Wilson CJ, Hutchinson AD . The role of skin cancer knowledge in sun-related behaviours: a systematic review. J Health Psychol. 2014;199:1143-62. PMID: 23682066. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6.23682066
90 de Maleissye MF, Beauchet A, Saiag P . Sunscreen use and melanocytic nevi in children: a systematic review. Pediatr Dermatol. 2013;301:51-9. PMID: 22994908. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.22994908
91 de Waure C, Quaranta G, Gualano MR . Systematic review of studies investigating the association between dietary habits and cutaneous malignant melanoma. Public Health. 2015;1298:1099-113. PMID: 26212104. KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E9.26212104
92 Del Rosso JQ, Thiboutot D, Gallo R . “Consensus recommendations from the American Acne & Rosacea Society on the management of rosacea, part 1: a status report on the disease state, general measures, and adjunctive skin care”. Cutis. 2013;925:234-40. PMID: 24343208. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.24343208
93 Dennis LK, Beane Freeman LE, VanBeek MJ. Sunscreen use and the risk for melanoma: a quantitative review. Ann Intern Med. 2003;13912:966-78. PMID: 14678916. KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E9.14678916
94 Dennis LK, Lowe JB, Snetselaar LG. Tanning behavior among young frequent tanners is related to attitudes and not lack of knowledge about the dangers. Health Educ J. 2009;683:232-243. PMID: 22707763. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.22707763
95 Dennis LK, Lowe JB. Does artificial UV use prior to spring break protect students from sunburns during spring break?. “Photodermatology, Photoimmunology & Photomedicine”. 2013;293:140-8. PMID: 23651274. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.23651274
96 Denzer N, Vogt T, Reichrath J. Vitamin D receptor (VDR) polymorphisms and skin cancer: A systematic review. Dermatoendocrinol. 2011;33:205-10. PMID: 22110781. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.22110781
97 Detert H, Hedlund S, Anderson CD . Validation of sun exposure and protection index (SEPI) for estimation of sun habits. Cancer Epidemiol. 2015;396:986-93. PMID: 26547793. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.26547793
98 Diao DY, Lee TK. Sun-protective behaviors in populations at high risk for skin cancer. Psychol Res Behav Manag. 2013;7:18-Sep. PMID: 24379732. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.24379732
99 Diehl K, Bock C, Breitbart EW . Building awareness of the health risks of sunbed use: identification of target groups for prevention. “Photodermatology, Photoimmunology & Photomedicine”. 2013;296:291-9. PMID: 24580548. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.24580548
100 Dillard AJ, Hisler G. Enhancing the effects of a narrative message through experiential information processing: An experimental study. Psychology & Health. 2015;307:803-20. PMID: 25515848. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E8.25515848
101 Djaja N, Youl P, Aitken J . Evaluation of a skin self examination attitude scale using an item response theory model approach. Health & Quality of Life Outcomes. 2014;12:189. PMID: 25539671. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E8.25539671
102 Dobbinson SJ, Jamsen K, Dixon HG . Assessing population-wide behaviour change: concordance of 10-year trends in self-reported and observed sun protection. Int J Public Health. 2014;591:157-66. PMID: 23519893. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.23519893
103 Dudley DA, Winslade MJ, Wright BJ . Rationale and study protocol to evaluate the SunSmart policy intervention: a cluster randomised controlled trial of a primary school-based health promotion program. BMC Public Health. 2015;15:42. PMID: 25636822. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E6d, KQ5E6d, KQ6.25636822
104 Dupuy A, Dunant A, Grob JJ . Randomized controlled trial testing the impact of high-protection sunscreens on sun-exposure behavior. Arch Dermatol. 2005;1418:950-6. PMID: 16103322. KQ1E6a, KQ2E6a, KQ3E6a, KQ4E6a, KQ5E6a.16103322
105 Dyson J, Cowdell F Development and psychometric testing of the ‘Motivation and Self-Efficacy in Early Detection of Skin Lesions’ index. Journal of Advanced Nursing. 2014;7012:2952-63. PMID: 24805303. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E8.24805303
106 Elliott F, Suppa M, Chan M . Relationship between sunbed use and melanoma risk in a large case-control study in the United Kingdom. Int J Cancer. 2012;13012:3011-3. PMID: 21823115. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.21823115
107 Emmons KM, Geller AC, Puleo E . Skin cancer education and early detection at the beach: a randomized trial of dermatologist examination and biometric feedback. Journal of the American Academy of Dermatology. 2011;642:282-9. PMID: 21163550. KQ1E6a, KQ2E6a, KQ3E8, KQ4E8, KQ5E8.21163550
108 Epstein DS, Lange JR, Gruber SB . Is physician detection associated with thinner melanomas?. JAMA. 1999;2817:640-3. PMID: 10029126. KQ1E8, KQ2E8, KQ3E8, KQ4E9, KQ5E9.10029126
109 Everett Jones S, O'Malley Olsen E, Michael SL . Association of UV index and sunscreen use among White high school students in the United States. J Sch Health. 2013;8310:750-6. PMID: 24020690. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.24020690
110 Excellence National Institute for Health and Clinical “Skin cancer prevention: information, resources and environmental changes”. . 2011;:. PMID: . KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.
111 Falk M, Anderson C. Prevention of skin cancer in primary healthcare: an evaluation of three different prevention efforts and the applicability of a phototest. European J Gen Pract. 2008;14:. PMID: . KQ1E12, KQ2E12, KQ3E8, KQ4E8, KQ5E8.
112 Falk M. Differences in sun exposure habits between self-reported skin type and ultraviolet sensitivity measured by phototest. “Photodermatology, Photoimmunology & Photomedicine”. 2011;274:190-5. PMID: 21729167. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.21729167
113 Famenini S, Young LC. Aspirin use and melanoma risk: a review of the literature. J Am Acad Dermatol. 2014;701:187-91. PMID: 24355265. KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E9.24355265
114 Faurschou A, Beyer Dm, Schmedes A, Bogh Mk, Philipsen Pa, Wulf Hc The relation between sunscreen layer thickness and vitamin D production after ultraviolet B exposure: A randomized clinical trial. British Journal of Dermatology. 2012;1672:391-395. PMID: 0. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.
115 Federman DG, Kirsner RS, Concato J. Sunscreen counseling by US physicians. JAMA. 2014;3121:87-8. PMID: 25058222. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.25058222
116 Feldman SR, Fleischer AB. Skin examinations and skin cancer prevention counseling by US physicians: a long way to go. J Am Acad Dermatol. 2000;43:. PMID: . KQ1E4, KQ2E4, KQ3E4, KQ4E4, KQ5E4.
117 Feldman SR, Fleischer AB Jr. Skin examinations and skin cancer prevention counseling by US physicians: a long way to go. J Am Acad Dermatol. 2000;430:234-7. PMID: 10906644. KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E9.10906644
118 Finch L, Youl P, Marshall AL . User preferences for text message-delivered skin cancer prevention and early detection. Journal of Telemedicine & Telecare. 2015;214:227-34. PMID: 25697490. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E8.25697490
119 Forrest KY, Stuhldreher WL. Prevalence and correlates of vitamin D deficiency in US adults. Nutr Res. 2011;311:48-54. PMID: 21310306. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.21310306
120 Fortes C, Mastroeni S, Bonamigo R . Can ultraviolet radiation act as a survival enhancer for cutaneous melanoma?. European Journal of Cancer Prevention. 2016;251:34-40. PMID: 25646933. KQ1E7a, KQ2E7a, KQ3E7a, KQ4E7a, KQ5E7a.25646933
121 Freijy T, Kothe EJ. Dissonance-based interventions for health behaviour change: a systematic review. Br J Health Psychol. 2013;182:310-37. PMID: 23480429. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.23480429
122 Gaber R, Mallett KA, Hultgren B . Enhanced fidelity of an educational intervention on skin self-examination through surveillance and standardization. J Nurs Educ Pract. 2014;42:253-258. PMID: 25414761. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E8.25414761
123 Gandini S, Gnagnarella P, Serrano D . Vitamin D receptor polymorphisms and cancer. Adv Exp Med Biol. 2014;810:69-105. PMID: 25207361. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.25207361
124 Gavin A, Boyle R, Donnelly D . “Trends in skin cancer knowledge, sun protection practices and behaviours in the Northern Ireland population”. European Journal of Public Health. 2012;223:408-12. PMID: 22094579. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.22094579
125 Geller AC. Educational and screening campaigns to reduce deaths from melanoma. Hematology - Oncology Clinics of North America. 2009;233:”515-27, i. PMID: 19464600. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.19464600
126 Glanz K, Gies P, O'Riordan D . Validity of self-reported solar UVR exposure compared with objectively measured UVR exposure. Cancer Epidemiol Biomarkers Prev. 2010;19:. PMID: . KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.
127 Glanz K, Volpicelli K, Kanetsky PA . “Melanoma genetic testing, counseling, and adherence to skin cancer prevention and detection behaviors”. “Cancer Epidemiology, Biomarkers & Prevention”. 2013;224:607-14. PMID: 23392000. KQ1E7a, KQ2E7a, KQ3E8, KQ4E8, KQ5E8.23392000
128 Glanz K, Yaroch AL, Dancel M . Measures of sun exposure and sun protection practices for behavioral and epidemiologic research. Arch Dermatol. 2008;1442:217-22. PMID: 18283179. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.18283179
129 Glanz K,Escoffery C,Elliott T,Nehl Ej Randomized Trial of Two Dissemination Strategies for a Skin Cancer Prevention Program in Aquatic Settings. American journal of public health. 2015;1057:1415-23. PMID: 0. KQ1E6a, KQ2E6a, KQ3E6a, KQ4E6a, KQ5E6a.
130 Gold J, Aitken CK, Dixon HG . A randomised controlled trial using mobile advertising to promote safer sex and sun safety to young people. Health Education Research. 2011;265:782-94. PMID: 21447750. KQ1E12, KQ2E12, KQ3E8, KQ4E10, KQ5E10.21447750
131 Gordon LG, Rowell D Health system costs of skin cancer and cost-effectiveness of skin cancer prevention and screening: a systematic review. Eur J Cancer Prev. 2015;242:141-9. PMID: 25089375. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E8.25089375
132 Goulart JM, Quigley EA, Dusza S . Skin cancer education for primary care physicians: a systematic review of published evaluated interventions. J Gen Intern Med. 2011;269:1027-35. PMID: 21472502. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7.21472502
133 Goulart JM, Quigley EA, Dusza S . Skin cancer education for primary care physicians: a systematic review of published evaluated interventions. Journal of General Internal Medicine. 2011;269:1027-35. PMID: 21472502. KQ1E4, KQ2E4, KQ3E4, KQ4E4, KQ5E4.21472502
134 Grant WB Increased risk of noncutaneous malignancy after diagnosis of nonmelanoma skin cancer may be due to sun avoidance. Br J Dermatol. 2016;:. PMID: . KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7.
135 Green AC, Williams GM, Logan V . Reduced melanoma after regular sunscreen use: randomized trial follow-up. J Clin Oncol. 2011;293:257-63. PMID: 21135266. KQ1E9, KQ2E9, KQ3E8, KQ4E8, KQ5E8.21135266
136 Gritz ER, Tripp MK, de Moor CA . Skin cancer prevention counseling and clinical practices of pediatricians. Pediatr Dermatol. 2003;201:16-24. PMID: 12558840. KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E9.12558840
137 Grodstein F, Speizer FE, Hunter DJ. A prospective study of incident squamous cell carcinoma of the skin in the nurses' health study. J Natl Cancer Inst. 1995;8714:1061-6. PMID: 7616597. KQ1E10, KQ2E10, KQ3E10, KQ4E8, KQ5E8.7616597
138 Guide to Community Preventive Services Cancer Prevention and Control: Skin Cancer Prevention. . 2014;:. PMID: . KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.
139 Guide to Community Preventive Services Preventing skin cancer: child care center-based interventions. . 2013;:. PMID: . KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.
140 Guide to Community Preventive Services Preventing skin cancer: interventions in outdoor recreational and tourism settings. . 2014;:. PMID: . KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.
141 Guide to Community Preventive Services Preventing skin cancer: primary and middle school interventions. . 2012;:. PMID: . KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.
142 Guy GP Jr, Thomas CC . “Vital signs: melanoma incidence and mortality trends and projections - United States, 1982-2030”. MMWR Morb Mortal Wkly Rep. 2015;6421:591-6. PMID: 26042651. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.26042651
143 Hamidi R, Cockburn MG, Peng DH. Prevalence and predictors of skin self-examination: prospects for melanoma prevention and early detection. International Journal of Dermatology. 2008;4710:993-1003. PMID: 18986343. KQ1E8, KQ2E9, KQ3E8, KQ4E8, KQ5E8.18986343
144 Hamidi R, Peng D, Cockburn M. Efficacy of skin self-examination for the early detection of melanoma. International Journal of Dermatology. 2010;492:126-34. PMID: 20465635. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.20465635
145 Han J, Colditz GA, Hunter DJ. Risk factors for skin cancers: a nested case-control study within the Nurses' Health Study. Int J Epidemiol. 2006;356:1514-21. PMID: 16943234. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.16943234
146 Hawkes AL, Hamilton K, White KM . A randomised controlled trial of a theory-based intervention to improve sun protective behaviour in adolescents (‘you can still be HOT in the shade’): study protocol. BMC Cancer. 2012;12:1. PMID: 22212211. KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E9.22212211
147 Haylett AK, Chiang YZ, Nie Z . Sunscreen photopatch testing: a series of 157 children. British Journal of Dermatology. 2014;1712:370-5. PMID: 24673302. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E8.24673302
148 Heckman C, Darlow S, Munshi T . Development of an Internet Intervention to Address Behaviors Associated with Skin Cancer Risk among Young Adults. Internet Interv. 2015;23:340-350. PMID: 26640776. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E8.26640776
149 Heckman CJ, Darlow S, Manne SL . Correspondence and correlates of couples' skin cancer screening. JAMA Dermatology. 2013;1497:825-30. PMID: 23864084. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.23864084
150 Heckman CJ, Zhu F, Manne SL . Process and outcomes of a skin protection intervention for young adults. Journal of Health Psychology. 2013;184:561-73. PMID: 22843632. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E8.22843632
151 Heckman CJ. Enhancing skin cancer screening through behavioral intervention. JAMA Dermatology. 2014;1504:363-5. PMID: 24553600. KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E9.24553600
152 Heckman CJ. and Handorf EA. and Darlow SD. and Ritterband LM. and Manne SL. An Online Skin Cancer Risk-Reduction Intervention for Young Adults: Mechanisms of Effects. Health Psychol. 2016;:. PMID: . KQ1E12, KQ2E12, KQ3E12, KQ4E12, KQ5E12.
153 Hernandez C, Kim H, Mauleon G . A pilot program in collaboration with community centers to increase awareness and participation in skin cancer screening among Latinos in Chicago. Journal of Cancer Education. 2013;282:342-5. PMID: 23378167. KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E9.23378167
154 Hernandez C, Wang S, Abraham I . Evaluation of educational videos to increase skin cancer risk awareness and sun-safe behaviors among adult Hispanics. Journal of Cancer Education. 2014;293:563-9. PMID: 24595966. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E8.24595966
155 Hevey D, Pertl M, Thomas K . Body consciousness moderates the effect of message framing on intentions to use sunscreen. Journal of Health Psychology. 2010;154:553-9. PMID: 20460412. KQ1E8d, KQ2E8d, KQ3E8d, KQ4E8d, KQ5E8d.20460412
156 Hill MJ. Skin cancer awareness: not just in May. Dermatology Nursing. 2009;213:114. PMID: 19554841. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.19554841
157 Hillhouse J. and Turrisi R. and Scaglione NM. and Cleveland MJ. and Baker K. and Florence LC. A Web-Based Intervention to Reduce Indoor Tanning Motivations in Adolescents: a Randomized Controlled Trial. Prevention Science. 2017;182:131-140. PMID: . KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E8.
158 Hingle Melanie D, Snyder Aimee L, McKenzie Naja E . Effects of a Short Messaging Service–Based Skin Cancer Prevention Campaign in Adolescents. Am J Prev Med. 2014;475:617-623. PMID: . KQ1E10, KQ2E10, KQ3E8, KQ4E8, KQ5E8.
159 Hirst N, Gordon L, Gies P . Estimation of avoidable skin cancers and cost-savings to government associated with regulation of the solarium industry in Australia. Health Policy. 2009;893:303-11. PMID: 18760857. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.18760857
160 Hirst NG, Gordon LG, Scuffham PA . Lifetime cost-effectiveness of skin cancer prevention through promotion of daily sunscreen use. Value in Health. 2012;152:261-8. PMID: 22433757. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.22433757
161 Ho BK, Reidy K, Huerta I, . Effectiveness of a Multicomponent Sun Protection Program for Young Children: A Randomized Clinical Trial. JAMA Pediatr. 2016;:. PMID: 26857829. KQ1E8b, KQ2E8b, KQ3E8, KQ4E8b, KQ5E8.26857829
162 Hollands GJ, French DP, Griffin SJ . The impact of communicating genetic risks of disease on risk-reducing health behaviour: systematic review with meta-analysis. BMJ. 2016;352:i1102. PMID: 26979548. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E8.26979548
163 Holman DM, Berkowitz Z, Guy GP . “The association between demographic and behavioral characteristics and sunburn among U.S. adults - National Health Interview Survey, 2010”. Prev Med. 2014;63:12-Jun. PMID: 24589442. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.24589442
164 Holman DM, Watson M Correlates of intentional tanning among adolescents in the United States: a systematic review of the literature. J Adolesc Health. 2013;520:S52-9. PMID: 23601612. KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E9.23601612
165 Horsham C, Auster J, Sendall MC . Interventions to decrease skin cancer risk in outdoor workers: update to a 2007 systematic review. BMC Res Notes. 2014;7:9-Jan. PMID: 24397996. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c, KQ5E6c.24398140
166 Houdmont J. and Madgwick P. and Randall R. Sun safety in construction: a U.K. intervention study. Occupational Medicine (Oxford). 2016;661:20-6. PMID: . KQ1E6c, KQ2E6c, KQ3E6c, KQ4E8, KQ5E8.
167 Housman TS, Feldman SR, Williford PM . Skin cancer is among the most costly of all cancers to treat for the Medicare population. J Am Acad Dermatol. 2003;483:425-9. PMID: 12637924. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.12637924
168 Howlader N, Noone A M, Krapcho M, Garshell J, Miller D, Altekruse S F, Kosary C L, Yu M, Ruhl J, Tatalovich Z, Mariotto A, Lewis D R, Chen H S, Feuer E J, Cronin K A “SEER Cancer Statistics Review, 1975-2012”. . 2015;:. PMID: . KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E9.
169 Hu H, Xie Y, Yang G . Nonsteroidal anti-inflammatory drug use and the risk of melanoma: a meta-analysis. European Journal of Cancer Prevention. 2014;231:62-68. PMID: 12013019409. KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E9.
170 Huang P, Yang XD, Chen SD . The association between Parkinson's disease and melanoma: a systematic review and meta-analysis. Transl Neurodegener. 2015;4:21. PMID: 26535116. KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E9.26535116
171 Hull PR, Piemontesi NG, Lichtenwald J. Compliance with self-examination surveillance in patients with melanoma and atypical moles: an anonymous questionnaire study. Journal of Cutaneous Medicine & Surgery. 2011;152:97-102. PMID: 21477557. KQ1E7a, KQ2E7a, KQ3E7a, KQ4E7a, KQ5E7a.21477557
172 Huncharek M, Kupelnick B. Use of topical sunscreens and the risk of malignant melanoma: a meta-analysis of 9067 patients from 11 case-control studies. Am J Public Health. 2002;927:1173-7. PMID: 12084704. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.12084704
173 Hunter S, Love-Jackson K, Abdulla R . Sun protection at elementary schools: a cluster randomized trial. Journal of the National Cancer Institute. 2010;1027:484-92. PMID: 20332388. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E6d, KQ5E6d.20332388
174 Hunter Seft, Wells Kristen J, Jacobsen Paul B, Lee Ji?Hyun, Boulware David, Love?Jackson Kymia, Abdulla Rania, Roetzheim Richard G Assessment of elementary school students' sun protection behaviors. Pediatr Dermatol. 2010;272:182-188. PMID: . KQ1E6d, KQ2E6d, KQ3E6d, KQ4E6d, KQ5E6d.
175 Hussain SK, Sundquist J, Hemminki K. The effect of having an affected parent or sibling on invasive and in situ skin cancer risk in Sweden. J Invest Dermatol. 2009;1299:2142-7. PMID: 19242514. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.19242514
176 International Agency for Research on Cancer Working Group on artificial ultraviolet light, skin cancer The association of use of sunbeds with cutaneous malignant melanoma and other skin cancers: A systematic review. Int J Cancer. 2007;1205:1116-22. PMID: 17131335. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.17131335
177 Isaacowitz DM, Harris JA. “Middle-aged adults facing skin cancer information: fixation, mood, and behavior”. Psychology & Aging. 2014;292:342-50. PMID: 24956002. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E8.24956002
178 Italia N, Rehfuess EA. Is the Global Solar UV Index an effective instrument for promoting sun protection? A systematic review. Health Educ Res. 2012;272:200-13. PMID: 21730253. KQ1E8, KQ2E10, KQ3E10, KQ4E1, KQ5E1.21730253
179 Jain N, Anderson MJ, Patel P . Melanoma simulation model: promoting opportunistic screening and patient counseling. JAMA Dermatology. 2013;1496:710-6. PMID: 23552462. KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E9.23552462
180 Janda M, Baade PD, Youl PH . The skin awareness study: promoting thorough skin self-examination for skin cancer among men 50 years or older. Contemporary Clinical Trials. 2010;311:119-30. PMID: 19900577. KQ1E8d, KQ2E8d, KQ3E8d, KQ4E8d, KQ5E8d.19900577
181 Janda M, Loescher LJ, Banan P . Lesion selection by melanoma high-risk consumers during skin self-examination using mobile teledermoscopy. JAMA Dermatology. 2014;1506:656-8. PMID: 24522284. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E8.24522284
182 Janda M, Loescher LJ, Soyer HP. Enhanced skin self-examination: a novel approach to skin cancer monitoring and follow-up. JAMA Dermatology. 2013;1492:231-6. PMID: 23426490. KQ1E9, KQ2E9, KQ3E9, KQ4E7, KQ5E8.23426490
183 Janda M, Youl P, Marshall AL . The HealthyTexts study: a randomized controlled trial to improve skin cancer prevention behaviors among young people. Contemporary Clinical Trials. 2013;351:159-67. PMID: 23557730. KQ1E8c, KQ2E8c, KQ3E8c, KQ4E8c, KQ5E8c.23557730
184 Javed S, Javed SA, Mays RM . Clinical characteristics and awareness of skin cancer in Hispanic patients. Dermatology Online Journal. 2013;199:19623. PMID: 24050296. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.24050296
185 Karagas MR, Stannard VA, Mott LA . Use of tanning devices and risk of basal cell and squamous cell skin cancers. J Natl Cancer Inst. 2002;943:224-6. PMID: 11830612. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.11830612
186 Kasparian NA, McLoone JK, Meiser B. Skin cancer-related prevention and screening behaviors: a review of the literature. Journal of Behavioral Medicine. 2009;325:406-28. PMID: 19521760. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.19521760
187 Kauvar AN, Cronin T Jr . “Consensus for nonmelanoma skin cancer treatment: basal cell carcinoma, including a cost analysis of treatment methods”. Dermatol Surg. 2015;415:550-71. PMID: 25868035. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.25868035
188 Kearney GD, Xu X, Balanay JA . Sun safety among farmers and farmworkers: a review. J Agromedicine. 2014;191:53-65. PMID: 24417532. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c, KQ5E6c.24417532
189 Khalesi M, Whiteman DC, Tran B . “A meta-analysis of pigmentary characteristics, sun sensitivity, freckling and melanocytic nevi and risk of basal cell carcinoma of the skin”. Cancer Epidemiol. 2013;375:534-43. PMID: 23849507. KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E9.23849507
190 King AJ, Gehl RW, Grossman D . Skin self-examinations and visual identification of atypical nevi: comparing individual and crowdsourcing approaches. Cancer Epidemiology. 2013;376:979-84. PMID: 24075797. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.24075797
191 King Andy J Visual Exemplification and Skin Cancer: The Utility of Exemplars in Promoting Skin Self-Exams and Atypical Nevi Identification. Journal of Health Communication. 2016;217:826-36. PMID: 27337542. KQ1E8b, KQ2E8b, KQ3E8b, KQ4E8b, KQ5E8b.27337542
192 Klein WM, Bloch M, Hesse BW . Behavioral research in cancer prevention and control: a look to the future. American Journal of Preventive Medicine. 2014;463:303-11. PMID: 24512871. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.24512871
193 Koster B, Thorgaard C, Philip A . Prevalence of sunburn and sun-related behaviour in the Danish population: a cross-sectional study. Scand J Public Health. 2010;385:548-52. PMID: 20484310. KQ1E10c, KQ2E10c, KQ3E10c, KQ4E10c, KQ5E10c.20484310
194 Krist AH, Baumann LJ, Holtrop JS . Evaluating Feasible and Referable Behavioral Counseling Interventions. Am J Prev Med. 2015;490:S138-49. PMID: 26296548. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.26296548
195 Lakhani NA, Saraiya M, Thompson TD . Total body skin examination for skin cancer screening among U.S. adults from 2000 to 2010. Prev Med. 2014;61:75-80. PMID: 24418263. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E8.24418263
196 Lana A, Faya-Ornia G, Lopez ML. Impact of a web-based intervention supplemented with text messages to improve cancer prevention behaviors among adolescents: results from a randomized controlled trial. Preventive Medicine. 2014;59:54-9. PMID: 24287124. KQ1E9c, KQ2E9c, KQ3E9c, KQ4E9c, KQ5E9c.24287124
197 Langbecker Danette, Diaz Abbey, Chan Raymond J, Marquart Louise, Hevey David, Hamilton Janelle Educational programmes for primary prevention of skin cancer. Cochrane Database of Systematic Reviews. 2014;4:. PMID: 0. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.
198 Langford R, Bonell CP, Jones HE . The WHO Health Promoting School framework for improving the health and well-being of students and their academic achievement. Cochrane Database Syst Rev. 2014;4:CD008958. PMID: 24737131. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E6d, KQ5E6d.24737131
199 Lansbury L, Bath-Hextall F, Perkins W . Interventions for non-metastatic squamous cell carcinoma of the skin: systematic review and pooled analysis of observational studies. BMJ. 2013;347:. PMID: 12013063584. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.
200 Lazovich D, Choi K, Rolnick C . An intervention to decrease adolescent indoor tanning: a multi-method pilot study. Journal of Adolescent Health. 2013;520:S76-82. PMID: 23601614. KQ1E8b, KQ2E8b, KQ3E8b, KQ4E1, KQ5E1.23601614
201 Lee KB, Weinstock MA, Risica PM “Components of a successful intervention for monthly skin self-examination for early detection of melanoma: the “”Check It Out”” trial”. Journal of the American Academy of Dermatology. 2008;586:1006-12. PMID: 18406492. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.18406492
202 Lemal M, Van den Bulck J. Testing the effectiveness of a skin cancer narrative in promoting positive health behavior: a pilot study. Preventive Medicine. 2010;512:178-81. PMID: 20450930. KQ1E8b, KQ2E8b, KQ3E8d, KQ4E8b, KQ5E8d.20450930
203 Li S, Liu Y, Zeng Z . Association between non-steroidal anti-inflammatory drug use and melanoma risk: a meta-analysis of 13 studies. Cancer Causes Control. 2013;248:1505-16. PMID: 23677334. KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E9.23677334
204 Li Z, Gu M, Cen Y. Age at first birth and melanoma risk: a meta-analysis. Int J Clin Exp Med. 2014;712:5201-9. PMID: 25664022. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.25664022
205 Lin JS, Eder M, Weinmann S . Behavioral Counseling to Prevent Skin Cancer: Systematic Evidence Review to Update the 2003 U.S. Preventive Services Task Force Recommendation. . 2011;:. PMID: 2154254521542545. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.
206 Lin JS, Eder M, Weinmann S Behavioral counselling to prevent skin cancer: a systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. 2011;1543:190-201. PMID: 12011000788. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.
207 Lin JS, Eder M, Weinmann S. Behavioral counselling to prevent skin cancer:a systematic review for the U.S. preventative services task force. Ann Intern Med. 2011;154:. PMID: . KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.
208 Lin SW, Wheeler DC, Park Y . Prospective study of ultraviolet radiation exposure and mortality risk in the United States. American Journal of Epidemiology. 2013;1784:521-33. PMID: 23863757. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.23863757
209 Lin SW, Wheeler DC, Park Y . Prospective study of ultraviolet radiation exposure and risk of cancer in the United States. Int J Cancer. 2012;1316:E1015-23. PMID: 22539073. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.22539073
210 Lindqvist PG, Epstein E, Landin-Olsson M . Avoidance of sun exposure is a risk factor for all-cause mortality: results from the Melanoma in Southern Sweden cohort. Journal of Internal Medicine. 2014;2761:77-86. PMID: 24697969. KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E9.24697969
211 Lindqvist PG and Landin-Olsson M. The relationship between sun exposure and all-cause mortality. Photochem Photobiol Sci. 2017;:. PMID: . KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.
212 Linos E, Keiser E, Fu T . “Hat, shade, long sleeves, or sunscreen? Rethinking US sun protection messages based on their relative effectiveness”. Cancer Causes Control. 2011;227:1067-71. PMID: 21637987. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.21637987
213 Loescher LJ, Hibler E, Hiscox H . An Internet-delivered video intervention for skin self-examination by patients with melanoma. Archives of Dermatology. 2010;1468:922-3. PMID: 20713834. KQ1E7a, KQ2E7a, KQ3E7a, KQ4E7a, KQ5E7a.20713834
214 Lomas A, Leonardi-Bee J, Bath-Hextall F. A systematic review of worldwide incidence of nonmelanoma skin cancer. Br J Dermatol. 2012;1665:1069-80. PMID: 22251204. KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E9.22251204
215 Lorenc T, Jamal F, Cooper C. Resource provision and environmental change for the prevention of skin cancer: systematic review of qualitative evidence from high-income countries. Health Promot Int. 2013;283:345-56. PMID: 22498818. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.22498818
216 Macbeth AE, Grindlay DJ, Williams HC What's new in skin cancer? An analysis of guidelines and systematic reviews published in 2008-2009. Clin Exp Dermatol. 2011;365:453-8. PMID: 21671988. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.21671988
217 Mahler HI, Kulik JA, Gerrard M . “Effects of upward and downward social comparison information on the efficacy of an appearance-based sun protection intervention: a randomized, controlled experiment”. Journal of Behavioral Medicine. 2010;336:496-507. PMID: 20652391. KQ1E8b, KQ2E8b, KQ3E8d, KQ4E8b, KQ5E8d.20652391
218 Mahler HI The role of emotions in UV protection intentions and behaviors. Psychology Health & Medicine. 2014;193:344-54. PMID: 23731279. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.23731279
219 Mallett KA, Turrisi R, Guttman K . Assessing dermatologists' ability to deliver a novel intervention to improve patients' use of sun protection: the ABC method of physician-patient communication. Archives of Dermatology. 2011;14712:1451-3. PMID: 21844429. KQ1E10a, KQ2E10a, KQ3E8, KQ4E8, KQ5E8.21844429
220 Markova A, Weinstock MA, Risica P . Effect of a web-based curriculum on primary care practice: basic skin cancer triage trial. Family Medicine. 2013;458:558-68. PMID: 24129868. KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E9.24129868
221 Marks R, Foley PA, Jolley D . The effect of regular sunscreen use on vitamin D levels in an Australian population. Results of a randomized controlled trial. Arch Dermatol. 1995;1314:415-21. PMID: 7726582. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E8.7726582
222 Mays D and Tercyak Kp Framing Indoor Tanning Warning Messages to Reduce Skin Cancer Risks Among Young Women: Implications for Research and Policy. American journal of public health. 2015;1058:e70-6. PMID: . KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E8.
223 Mays D and Zhao X The influence of framed messages and self-affirmation on indoor tanning behavioral intentions in 18- to 30-year-old women. Health psychology : official journal of the Division of Health Psychology, American Psychological Association. 2016;352:123-30. PMID: . KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E8.
224 McClendon BT, Prentice-Dunn S. Reducing skin cancer risk: an intervention based on protection motivation theory. J Health Psychol. 2001;6:. PMID: .KQ1E8b, KQ2E8b, KQ3E8, KQ4E1, KQ5E1.
225 McFarland SL, Schram SE. Physician skin examinations for melanoma screening. Cutis. 2015;963:175-82. PMID: 26562268. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.26562268
226 McMichael JR, Ezirike J, Veledar E . The social acceptability of handheld umbrellas for sun protection. “Photodermatology, Photoimmunology & Photomedicine. 2014;304:220-7. PMID: 24735389. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E8.24735389
227 McWhirter JE, Hoffman-Goetz L. Systematic review of population-based studies on the impact of images on UV attitudes and behaviours. Health Promot Int. 2015;302:397-410. PMID: 23669159. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6.23669159
228 McWhirter JE, Hoffman-Goetz L. Visual images for patient skin self-examination and melanoma detection: a systematic review of published studies. J Am Acad Dermatol. 2013;691:47-55. PMID: 12013038426. KQ1E9c, KQ2E9c, KQ3E9c, KQ4E9c, KQ5E9c.
229 McWhirter JE, Hoffman-Goetz L. Visual images for skin cancer prevention: a systematic review of qualitative studies. J Cancer Educ. 2012;272:202-16. PMID: 22481615. KQ1E9c, KQ2E9c, KQ3E9c, KQ4E9c, KQ5E9c.22481615
230 Metterle L, Russell JS, Patel NS. An overview of the medical management of nonmelanoma skin cancer. Curr Probl Cancer. 2015;394:226-36. PMID: 26277493. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.26277493
231 Miljkovic S, Baljozovic D, Krajnovic D . The impact of education on adolescents' sun behavior: experiences from Serbia. Srpski Arhiv Za Celokupno Lekarstvo. 2014;14242861:330-6. PMID: 25033590. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.25033590
232 Montague M, Borland R, Sinclair C. “Slip! slop! slap! and SunSmart, 1980-2000: skin cancer control and 20 years of population-based campaigning”. Health Educ Behav. 2001;28:. PMID: . KQ1E4, KQ2E4, KQ3E4, KQ4E4, KQ5E4.
233 Morris KL, Cooper DP, Goldenberg JL . Improving the efficacy of appearance-based sun exposure interventions with the terror management health model. Psychol Health. 2014;2911:1245-64. PMID: 24811049. KQ1E8b, KQ2E8b, KQ3E8b, KQ4E8b, KQ5E8b.24811049
234 Moyer VA Behavioral counseling to prevent skin cancer: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2012;1571:59-65. PMID: 22751761. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.22751761
235 Muhn CY, From L, Glied M Detection of artificial changes in mole size by skin self-examination. J Am Acad Dermatol. 2000;420:754-9. PMID: 10775850. KQ1E8, KQ2E8, KQ3E8, KQ4E9, KQ5E9.10775850
236 Mujumdar UJ, Hay JL, Monroe-Hinds YC . Sun protection and skin self-examination in melanoma survivors. Psycho-Oncology. 2009;1810:1106-15. PMID: 19142859. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7.19142859
237 Mulliken JS, Russak JE, Rigel DS. The effect of sunscreen on melanoma risk. Dermatol Clin. 2012;303:369-76. PMID: 22800545. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.22800545
238 Muranushi C, Olsen CM, Pandeya N . Aspirin and nonsteroidal anti-inflammatory drugs can prevent cutaneous squamous cell carcinoma: a systematic review and meta-analysis. J Invest Dermatol. 2015;1354:975-83. PMID: 25521453. KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E9.25521453
239 Nahar VK, Allison Ford M, Brodell RT . Skin cancer prevention practices among malignant melanoma survivors: a systematic review. J Cancer Res Clin Oncol. 2015;:. PMID: 26642962. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7.26642962
240 Nahar VK Skin cancer prevention among school children: a brief review. Cent Eur J Public Health. 2013;214:227-32. PMID: 24592730. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.24592730
241 National Institute for Health and Care Excellence Skin cancer prevention: public health guideline. . 2011;:. PMID: . KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.
242 Nowson CA, McGrath JJ, Ebeling PR . Vitamin D and health in adults in Australia and New Zealand: a position statement. Medical Journal of Australia. 2012;19611:686-7. PMID: 22708765. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.22708765
243 O'Riordan D, Nehl E, Gies P . Validity of covering-up sun-protection habits: association of observations and self-report. J Am Acad Dermatol. 2009;60:. PMID: . KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.
244 O'Keefe DJ, Wu D Gain-framed messages do not motivate sun protection: a meta-analytic review of randomized trials comparing gain-framed and loss-framed appeals for promoting skin cancer prevention. Int J Environ Res Public Health. 2012;96:2121-33. PMID: 22829794. KQ1E9c, KQ2E9c, KQ3E9c, KQ4E9c, KQ5E9c.22829794
245 Oliveria SA, Chau D, Christos PJ . Diagnostic accuracy of patients in performing skin self-examination and the impact of photography. Arch Dermatol. 2004;1401:57-62. PMID: 14732661. KQ1E8, KQ2E8, KQ3E8, KQ4E9, KQ5E9.14732661
246 Oliveria SA, Christos PJ, Marghoob AA . Skin cancer screening and prevention in the primary care setting: national ambulatory medical care survey 1997. J Gen Intern Med. 2001;165:297-301. PMID: 11359547. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.11359547
247 Oliveria SA, Saraiya M, Geller AC . Sun exposure and risk of melanoma. Arch Dis Child. 2006;912:131-8. PMID: 16326797. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.16326797
248 Olsen CM, Carroll HJ, Whiteman DC. Estimating the attributable fraction for cancer: A meta-analysis of nevi and melanoma. Cancer Prevention Research. 2010;32:233-45. PMID: 20086181. KQ1E10, KQ2E10, KQ3E10, KQ4E8d, KQ5E8d.20086181
249 Olsen CM, Green AC, Neale RE . Cohort profile: the QSkin Sun and Health Study. International Journal of Epidemiology. 2012;414:929-929i. PMID: 22933644. KQ1E10, KQ2E10, KQ3E8, KQ4E8, KQ5E8.22933644
250 Olsen CM, Zens MS, Green AC . Biologic markers of sun exposure and melanoma risk in women: pooled case-control analysis. Int J Cancer. 2011;1293:713-23. PMID: 0. KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E9.
251 Orlow I, Roy P, Reiner AS . Vitamin D receptor polymorphisms in patients with cutaneous melanoma. Int J Cancer. 2012;1302:405-18. PMID: 21365644. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.21365644
252 Ou-Yang H. and Jiang LI. and Meyer K. and Wang SQ. and Farberg AS. and Rigel DS. Sun Protection by Beach Umbrella vs Sunscreen With a High Sun Protection Factor: A Randomized Clinical Trial. JAMA Dermatology. 2017;18:18. PMID: . KQ1E6a, KQ2E6a, KQ3E6a, KQ4E6a, KQ5E6a.
253 Paddock LE, Lu SE, Bandera EV . Skin self-examination and long-term melanoma survival. Melanoma Res. 2016;:. PMID: 26990272. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7.26990272
254 Pagoto SL, Schneider KL, Oleski J . Design and methods for a cluster randomized trial of the Sunless Study: a skin cancer prevention intervention promoting sunless tanning among beach visitors. BMC Public Health. 2009;9:50. PMID: 19196482. KQ1E6a, KQ2E6a, KQ3E6a, KQ4E6a, KQ5E6a.19196482
255 Pagoto SL, Schneider KL, Oleski J . The sunless study: a beach randomized trial of a skin cancer prevention intervention promoting sunless tanning. Archives of Dermatology. 2010;1469:979-84. PMID: 20855696. KQ1E6a, KQ2E6a, KQ3E6a, KQ4E6a, KQ5E6a.20855696
256 Perkins SH, Stensland KD, Galsky MD . An analysis of the clinical trial landscape for cutaneous melanoma. Cutis. 2015;963:186-90. PMID: 26562269. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.26562269
257 Petrarca S, Follmann M, Breitbart EW . “Critical appraisal of clinical practice guidelines for adaptation in the evidence-based guideline “”prevention of skin cancer”””. JAMA Dermatol. 2013;1494:466-71. PMID: 23715595. KQ1E6e, KQ2E6e, KQ3E6e, KQ4E6e, KQ5E6e.23715595
258 Pichon LC, Corral I, Landrine H . Sun-protection behaviors among African Americans. American Journal of Preventive Medicine. 2010;383:288-95. PMID: 20171530. KQ1E10, KQ2E10, KQ3E10, KQ4E8, KQ5E8.20171530
259 Pollitt RA, Geller AC, Brooks DR . Efficacy of skin self-examination practices for early melanoma detection. “Cancer Epidemiology, Biomarkers & Prevention. 2009;1811:3018-23. PMID: 19861521. KQ1E7a, KQ2E7a, KQ3E7a, KQ4E7a, KQ5E7a.19861521
260 Quereux G, Nguyen JM, Volteau C . Prospective trial on a school-based skin cancer prevention project. European Journal of Cancer Prevention. 2009;182:133-44. PMID: 19337061. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E6d, KQ5E6d.19337061
261 Raimondi S, Pasquali E, Gnagnarella P . BsmI polymorphism of vitamin D receptor gene and cancer risk: a comprehensive meta-analysis. Mutat Res. 2014;769:17-34. PMID: 25771722. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.25771722
262 Rat C, Quereux G, Riviere C, Clouet S, Senand R, Dreno B, Nguyen J Impact of a targeted screening on melanoma prevention behaviour. A randomised controlled trial. Journal of investigative dermatology. 2012;132:S71. PMID: 0. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E8.
263 Reeder AI, Gray A, McCool JP “Occupational sun protection: workplace culture, equipment provision and outdoor workers' characteristics”. Journal of Occupational Health. 2013;552:84-97. PMID: 23385117. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.23385117
264 Reeder AI, Jopson JA, Gray A Baseline survey of sun protection policies and practices in primary school settings in New Zealand. Health Education Research. 2009;245:778-87. PMID: 19329531. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E6d, KQ5E6d.19329531
265 Reggiani C, Manfredini M, Mandel VD . Update on non-invasive imaging techniques in early diagnosis of non-melanoma skin cancer. G Ital Dermatol Venereol. 2015;1504:393-405. PMID: 26184797. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.26184797
266 Reid AE, Aiken LS. Correcting injunctive norm misperceptions motivates behavior change: a randomized controlled sun protection intervention. Health Psychology. 2013;325:551-60. PMID: 23646838. KQ1E8b, KQ2E8b, KQ3E8b, KQ4E8, KQ5E8.23646838
267 Reinau D, Weiss M, Meier CR . “Outdoor workers' sun-related knowledge, attitudes and protective behaviours: a systematic review of cross-sectional and interventional studies”. Br J Dermatol. 2013;1685:928-40. PMID: 23252833. KQ1E6a, KQ2E6a, KQ3E6a, KQ4E6a, KQ5E6a.23252833
268 Reynolds KD, Buller DB, French SA . School sun-protection policies: measure development and assessments in 2 regions of the United States. Journal of School Health. 2012;8211:499-507. PMID: 23061553. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.23061553
269 Risica PM, Weinstock MA, Rakowski W . Body satisfaction effect on thorough skin self-examination. American Journal of Preventive Medicine. 2008;351:68-72. PMID: 18541179. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E8.18541179
270 Roberts DC, Black D. Comparison of interventions to reduce sun exposure. Behavioral Medicine. 2009;352:67-76. PMID: 19433378. KQ1E8b, KQ2E8b, KQ3E8, KQ4E8b, KQ5E8.19433378
271 Robertson K, McIntosh RD, Bradley-Scott C . “Image training, using random images of melanoma, performs as well as the ABC(D) criteria in enabling novices to distinguish between melanoma and mimics of melanoma”. Acta Dermato-Venereologica. 2014;943:265-70. PMID: 24212235. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E8.24212235
272 Robertson LM, Douglas F, Ludbrook A . What works with men? A systematic review of health promoting interventions targeting men. BMC Health Services Research. 2008;8:141. PMID: 18598339. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.18598339
273 Robinson Jk and Hultgren Ba and Turrisi R Helping children be safe outdoors with sun protection. Journal of investigative dermatology. 2016;1360:S43. PMID: . KQ1E8b, KQ2E8b, KQ3E8, KQ4E8b, KQ5E8.
274 Robinson JK, Bigby M. Prevention of melanoma with regular sunscreen use. JAMA. 2011;3063:302-3. PMID: 21712528. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.21712528
275 Robinson JK, Gaber R, Hultgren B . “Skin self-examination education for early detection of melanoma: a randomized controlled trial of Internet, workbook, and in-person interventions”. Journal of Medical Internet Research. 2014;161:e7. PMID: 24418949. KQ1E7a, KQ2E7a, KQ3E7a, KQ4E7a, KQ5E7a.24418949
276 Robinson JK, Turrisi R, Stapleton J. Efficacy of a partner assistance intervention designed to increase skin self-examination performance. Archives of Dermatology. 2007;1431:37-41. PMID: 17224540. KQ1E7a, KQ2E7a, KQ3E7a, KQ4E7a, KQ5E7a.17224540
277 Robinson JK, Turrisi R, Stapleton J. Examination of mediating variables in a partner assistance intervention designed to increase performance of skin self-examination. Journal of the American Academy of Dermatology. 2007;563:391-7. PMID: 17147966. KQ1E7a, KQ2E7a, KQ3E7a, KQ4E7a, KQ5E7a.17147966
278 Robinson JK. “Sun exposure, sun protection, and vitamin D”. JAMA. 2005;29412:1541-3. PMID: 16193624. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.16193624
279 Robinson JK and Hultgren B. and Mallett K. and Turrisi R. Self-confidence and Embarrassment About Partner-Assisted Skin Self-examination for Melanoma. JAMA Dermatology. 2016;14:14. PMID: . KQ1E7a, KQ2E7a, KQ3E7a, KQ4E7a, KQ5E7a.
280 Rodrigues A, Sniehotta FF, Araujo-Soares V. Are interventions to promote sun-protective behaviors in recreational and tourist settings effective? A systematic review with meta-analysis and moderator analysis. Ann Behav Med. 2013;452:224-38. PMID: 23229160. KQ1E6a, KQ2E6a, KQ3E6a, KQ4E6a, KQ5E6a.23229160
281 Rodrigues, Sniehotta, Falko F, Araujo Soares Are interventions to promote sun-protective behaviors in recreational and tourist settings effective? A systematic review with meta-analysis and moderator analysis. Annals of Behavioral Medicine. 2013;452:224-238. PMID: 12013054304. KQ1E6a, KQ2E6a, KQ3E6a, KQ4E1, KQ5E1.
282 Rodriguez VM. and Robers E. and Zielaskowski K. and Javier Gonzalez C. and Hunley K. and Kaphingst KA. and Guest DD. and Sussman A. and Meyer White KA. and Schwartz MR. and Greb J. and Talamantes Y. and Bigney J. and Berwick M. and Hay JL. Translation and adaptation of skin cancer genomic risk education materials for implementation in primary care. Journal of Community Genetics. 2017;81:53-63. PMID: . KQ1E8d, KQ2E8d, KQ3E8d, KQ4E8d, KQ5E8d.
283 Roetzheim Rg, Love-Jackson Km, Hunter Sg, Lee Jh, Chen R, Abdulla R, Wells Kj A cluster randomized trial of sun protection at elementary schools. Results from year 2. American journal of preventive medicine. 2011;416:615-8. PMID: 0. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E6d, KQ5E6d.
284 Rogers HW, Weinstock MA, Feldman SR . “Incidence Estimate of Nonmelanoma Skin Cancer (Keratinocyte Carcinomas) in the US Population, 2012”. JAMA Dermatol. 2015;15110:1081-6. PMID: 25928283. KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E9.25928283
285 Roman C, Lugo-Somolinos A, Thomas N. Skin cancer knowledge and skin self-examinations in the Hispanic population of North Carolina: the patient's perspective. JAMA Dermatology. 2013;1491:103-4. PMID: 23324772. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.23324772
286 Roman CJ. and Guan X. and Barnholtz-Sloan JS. and Xu J. and Bordeaux JS. A Trial Online Educational Melanoma Program Aimed at the Hispanic Population Improves Knowledge and Behaviors. Dermatologic Surgery. 2016;425:672-6. PMID: . KQ1E10a, KQ2E10a, KQ3E10a, KQ4E10a, KQ5E10a.
287 Rouhani P, Hu S, Kirsner RS Melanoma in Hispanic and black Americans. Cancer Control. 2008;153:248-53. PMID: 18596677. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.18596677
288 Sanchez Guillermo, Nova John, Rodriguez-Hernandez Andrea Esperanza, Solorzano-Restrepo Carolina, Gonzalez Jenny, Olmos Miguel, Godfrey Kathie, Arevalo-Rodriguez Ingrid Sun protection for preventing basal cell and squamous cell skin cancers. Cochrane Database of Systematic Reviews. 2014;6:. PMID: 0. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.
289 Sancho-Garnier H, Pereira B, Cesarini P “A cluster randomized trial to evaluate a health education programme “”Living with Sun at School”””. International Journal of Environmental Research & Public Health [Electronic Resource]. 2012;97:2345-61. PMID: 22851947. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E6d, KQ5E6d.22851947
290 Santiago-Rivas M, Velicer WF, Redding CA . Cluster subtypes within the precontemplation stage of change for sun protection behavior. Psychology Health & Medicine. 2012;173:311-22. PMID: 22175661. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.22175661
291 Santiago-Rivas M, Wang C, Jandorf L Sun Protection Beliefs among Hispanics in the US. J Skin Cancer. 2014;2014:161960. PMID: 25431673. KQ1E8, KQ2E8, KQ3E8, KQ4E1, KQ5E1.25431673
292 Saraiya M, Glanz K, Briss P . Preventing skin cancer: findings of the Task Force on Community Preventive Services On reducing Exposure to Ultraviolet Light. MMWR Recomm Rep. 2003;520:12-Jan. PMID: 14561953. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.14561953
293 Saraiya M, Glanz K, Briss PA . Interventions to prevent skin cancer by reducing exposure to ultraviolet radiation: a systematic review. Am J Prev Med. 2004;275:422-66. PMID: 15556744. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6.15556744
294 Schneider JS, Moore DH 2nd,Mendelsohn ML “Screening program reduced melanoma mortality at the Lawrence Livermore National Laboratory, 1984 to 1996”. Journal of the American Academy of Dermatology. 2008;585:741-9. PMID: 18068264. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c, KQ5E6c.18068264
295 Seidel N, Stoelzel F, Garzarolli M . Sun protection training based on a theater play for preschoolers: an effective method for imparting knowledge on sun protection?. Journal of Cancer Education. 2013;283:435-8. PMID: 23728992. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E6d, KQ5E6d.23728992
296 Shenoy R, Molenda MA, Mostow EN. The introduction of skin self-photography as a supplement to skin self-examination for the detection of skin cancer. Journal of the American Academy of Dermatology. 2014;701:e15. PMID: 24355279. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.24355279
297 Shih ST, Carter R, Sinclair C . Economic evaluation of skin cancer prevention in Australia. Preventive Medicine. 2009;495:449-53. PMID: 19747936. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.19747936
298 Siegel RL, Miller KD, Jemal A “Cancer statistics, 2015”. CA Cancer J Clin. 2015;651:29-May. PMID: 25559415. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.25559415
299 Sinclair C, Foley P. Skin cancer prevention in Australia. Br J Dermatol. 2009;161:. PMID: . KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.
300 Singh SD, Ajani UA, Johnson CJ . “Association of cutaneous melanoma incidence with area-based socioeconomic indicators-United States, 2004-2006”. Journal of the American Academy of Dermatology. 2011;650:S58-68. PMID: 22018068. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.22018068
301 Sivamani RK, Crane LA, Dellavalle RP The benefits and risks of ultraviolet tanning and its alternatives: the role of prudent sun exposure. Dermatol Clin. 2009;272:”149-54, v. PMID: 19254658. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.19254658
302 Smit AK. and Espinoza D. and Newson AJ. and Morton RL. and Fenton G. and Freeman L. and Dunlop K. and Butow PN. and Law MH. and Kimlin MG. and Keogh LA. and Dobbinson SJ. and Kirk J. and Kanetsky PA. and Mann GJ. and Cust AE. A Pilot Randomized Controlled Trial of the Feasibility, Acceptability, and Impact of Giving Information on Personalized Genomic Risk of Melanoma to the Public. Cancer Epidemiology, Biomarkers & Prevention. 2016;4:4. PMID: . KQ1E9, KQ2E9, KQ3E9, KQ4E8, KQ5E8.
303 Smit P, Plomp E, Neumann HA . The influence of the location of the lesion on the absolute risk of the development of skin cancer in a patient with actinic keratosis. J Eur Acad Dermatol Venereol. 2013;276:667-71. PMID: 23057666. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.23057666
304 Smith A, Harrison S, Nowak M . Changes in the pattern of sun exposure and sun protection in young children from tropical Australia. Journal of the American Academy of Dermatology. 2013;685:774-83. PMID: 23267720. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.23267720
305 Song F, Qureshi AA, Gao X . Smoking and risk of skin cancer: a prospective analysis and a meta-analysis. Int J Epidemiol. 2012;416:1694-705. PMID: 23064412. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.23064412
306 Stock ML, Gerrard M, Gibbons FX . “Sun protection intervention for highway workers: long-term efficacy of UV photography and skin cancer information on men's protective cognitions and behavior.[Erratum appears in Ann Behav Med. 2010 Feb;39(1):100 Note: Weng, Chih-Yuan [added]]”. Annals of Behavioral Medicine. 2009;383:225-36. PMID: 20049658. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c, KQ5E6c.20049658
307 Stock Ml, Gerrard M, Gibbons Fx, Dykstra Jl, Weng Cy, Mahler Hi, Walsh La, Kulik Ja Sun protection intervention for highway workers: long-term efficacy of UV photography and skin cancer information on men's protective cognitions and behavior. Annals of behavioral medicine : a publication of the Society of Behavioral Medicine. 2009;383:225-36. PMID: 0. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c, KQ5E6c.
308 Swetter SM. and Pollitt RA. and Brooks DR. and Johnson TM. and Park ER. and Geller AC. Efficacy of physician and self skin-examination practices for early melanoma detection. Journal of Clinical Oncology. 2008;260:9037. PMID: . KQ1E7a, KQ2E7a, KQ3E7a, KQ4E7a, KQ5E7a.
309 Szabo C, Ocsai H, Csabai M . A randomised trial to demonstrate the effectiveness of electronic messages on sun protection behaviours. Journal of Photochemistry & Photobiology. B - Biology. 2015;149:257-64. PMID: 26114220. KQ1E8, KQ2E7, KQ3E8, KQ4E8, KQ5E8.26114220
310 Tagliabue E, Raimondi S, Gandini S. Meta-analysis of Vitamin D-Binding Protein and Cancer Risk. Cancer Epidemiol Biomarkers Prev. 2015;2411:1758-65. PMID: 26364161. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.26364161
311 Tang JY, Wu A, Linos E . High prevalence of vitamin D deficiency in patients with basal cell nevus syndrome. Archives of Dermatology. 2010;14610:1105-10. PMID: 20956641. KQ1E7c, KQ2E7c, KQ3E7c, KQ4E7c, KQ5E7c.20956641
312 Torrens R, Swan BA. Promoting prevention and early recognition of malignant melanoma. Dermatology Nursing. 2009;213:115-22; qu. PMID: 19554842. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.19554842
313 Tripp MK, Vernon SW, Gritz ER . Children's skin cancer prevention: a systematic review of parents' psychosocial measures. Am J Prev Med. 2013;443:265-73. PMID: 23415124. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E8.23415124
314 Trolle L, Henrik-Nielsen R, Gniadecki R. Ability to self-detect malignant melanoma decreases with age. Clinical & Experimental Dermatology. 2011;365:499-501. PMID: 21418284. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.21418284
315 Tsai S and Frank Sh and Bordeaux Js Improving sun-protective behaviors and self skin-examinations among African-Americans: A randomized controlled trial. Journal of investigative dermatology. 2016;1360:S113. PMID: . KQ1E8b, KQ2E8b, KQ3E8, KQ4E8b, KQ5E8.
316 Tuong W, Larsen ER, Armstrong AW. Videos to influence: a systematic review of effectiveness of video-based education in modifying health behaviors. J Behav Med. 2014;372:218-33. PMID: 23188480. KQ1E9c, KQ2E9c, KQ3E9c, KQ4E9c, KQ5E9c.23188480
317 Tuong W, Armstrong Aw Appearance-based video education is more effective than health-based video education in promoting sunscreen use among adolescents: A randomized controlled trial. Journal of investigative dermatology. 2014;134:S49. PMID: 0. KQ1E8b, KQ2E8b, KQ3E10b, KQ4E8b, KQ5E10b.
318 Tuong WArmstrong AW. Effect of appearance-based education compared with health-based education on sunscreen use and knowledge: a randomized controlled trial. J Am Acad Dermatol. 2014;704:665-9. PMID: 24508292. KQ1E8b, KQ2E8b, KQ3E8, KQ4E8b, KQ5E8.24508292
319 Tyagi A, Miller K, Cockburn M. e-Health Tools for Targeting and Improving Melanoma Screening: A Review. Journal of Skin Cancer. 2012;2012:437502. PMID: 23304515. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.23304515
320 U.SPreventive Services Task Force “Final Recommendation Statement: Vitamin D Deficiency: Screening, 2014”. . 2014;201642750:. PMID: . KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.
321 U.SPreventive Services Task Force Final Recommendation Statement: Vitamin Supplementation to Prevent Cancer and CVD: Counseling. . 2014;201642750:. PMID: . KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.
322 Usher-Smith JA, Emery J, Kassianos AP . Risk prediction models for melanoma: a systematic review. Cancer Epidemiol Biomarkers Prev. 2014;238:1450-63. PMID: 24895414. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E8.24895414
323 Van 't Riet J, Cox AD, Cox D . Does perceived risk influence the effects of message framing? A new investigation of a widely held notion. Psychology & Health. 2014;298:933-49. PMID: 24579986. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E8.24579986
324 Velasques K. and Michels LR. and Colome LM. and Haas SE. Educational Activities for Rural and Urban Students to Prevent Skin Cancer in Rio Grande do Sul, Brazil. Asian Pacific Journal of Cancer Prevention: Apjcp. 2016;173:1201-7. PMID: . KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.
325 Volkov A, Dobbinson S, Wakefield M . Seven-year trends in sun protection and sunburn among Australian adolescents and adults. Aust N Z J Public Health. 2013;37:. PMID: . KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.
326 Walker DK. Skin Protection for (SPF) Kids Program. Journal of Pediatric Nursing. 2012;273:233-42. PMID: 22525811. KQ1E6d, KQ2E6d, KQ3E6d, KQ4E6d, KQ5E6d.22525811
327 Wang SQ, Lim HW. Current status of the sunscreen regulation in the United States: 2011 Food and Drug Administration's final rule on labeling and effectiveness testing. J Am Acad Dermatol. 2011;654:863-9. PMID: 21821312. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.21821312
328 Watson M, Garnett E, Guy GP . The Surgeon General's Call to Action to Prevent Skin Cancer. . 2014;:. PMID: 2532083525320835. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.
329 Watts CG, Dieng M, Morton RL . “Clinical practice guidelines for identification, screening and follow-up of individuals at high risk of primary cutaneous melanoma: a systematic review”. Br J Dermatol. 2015;1721:33-47. PMID: 25204572. KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E9.25204572
330 Wehner MR, Shive ML, Chren MM . Indoor tanning and non-melanoma skin cancer: systematic review and meta-analysis. BMJ. 2012;345:e5909. PMID: 23033409. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.23033409
331 Weiss J, Kirsner RS, Hu S. Trends in primary skin cancer prevention among US Hispanics: a systematic review. J Drugs Dermatol. 2012;115:580-6. PMID: 22527425. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E8.22527425
332 Werner RN, Sammain A, Erdmann R . The natural history of actinic keratosis: a systematic review. Br J Dermatol. 2013;1693:502-18. PMID: 23647091. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E8.23647091
333 Wheless L, Ruczinski I, Alani RM . The association between skin characteristics and skin cancer prevention behaviors. “Cancer Epidemiology, Biomarkers & Prevention. 2009;1810:2613-9. PMID: 19755654. KQ1E10, KQ2E10, KQ3E10, KQ4E8, KQ5E8.19755654
334 White K, Young R, Hawkes A, Hamilton K, Leske S, Starfelt L A randomised controlled trial of a theory-based school intervention to improve sun-protective behaviour among adolescents. Asia-Pacific journal of clinical oncology. 2012;8:261. PMID: 0. KQ1E8c, KQ2E8c, KQ3E8c, KQ4E8c, KQ5E8c.
335 White KM, Hyde MK, O'Connor EL . Testing a belief-based intervention encouraging sun-safety among adolescents in a high risk area. Preventive Medicine. 2010;5142798:325-8. PMID: 20637795. KQ1E6d, KQ2E7c, KQ3E7c, KQ4E7c, KQ5E7c.20637795
336 White KM, Starfelt LC, Young RM . Predicting Australian adults' sun-safe behaviour: examining the role of personal and social norms. British Journal of Health Psychology. 2015;202:396-412. PMID: 24917299. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.24917299
337 White Km, Starfelt Lc, Young Rm, Hawkes Al, Cleary C, Leske S, Wihardjo K A randomised controlled trial of an online theory-based intervention to improve adult Australians' sun-protective behaviours. Preventive medicine. 2015;72:19-22. PMID: 0. KQ1E8b, KQ2E8b, KQ3E8d, KQ4E8b, KQ5E8d.25572618
338 Williams AL, Grogan S, Clark-Carter D . Appearance-based interventions to reduce ultraviolet exposure and/or increase sun protection intentions and behaviours: a systematic review and meta-analyses. Br J Health Psychol. 2013;181:182-217. PMID: 22989352. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6.22989352
339 Williams AL, Grogan S, Clark-Carter D . Impact of a facial-ageing intervention versus a health literature intervention on women's sun protection attitudes and behavioural intentions. Psychology & Health. 2013;289:993-1008. PMID: 23527527. KQ1E8b, KQ2E8b, KQ3E8b, KQ4E8, KQ5E8.23527527
340 Wolff T, Tai E, Miller T. Screening for skin cancer: an update of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2009;1503:194-8. PMID: 19189909. KQ1E10, KQ2E10, KQ3E10, KQ4E10, KQ5E10.19189909
341 Yagerman S, Marghoob A. Melanoma patient self-detection: a review of efficacy of the skin self-examination and patient-directed educational efforts. Expert Review of Anticancer Therapy. 2013;1312:1423-31. PMID: 24236821. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.24236821
342 Yew YW, Lai YC, Schwartz RA. Coffee Consumption and Melanoma: A Systematic Review and Meta-Analysis of Observational Studies. Am J Clin Dermatol. 2015;:. PMID: 26547919. KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E9.26547919
343 Zhang YP, Chu RX, Liu H. Vitamin A intake and risk of melanoma: a meta-analysis. PLoS One. 2014;97:e102527. PMID: 12014046943. KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E9.
344 Zhao XZ, Yang BH, Yu GH . Polymorphisms in the vitamin D receptor (VDR) genes and skin cancer risk in European population: a meta-analysis. Arch Dermatol Res. 2014;3066:545-53. PMID: 24771013. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.24771013
345 Zhu Y, Cheng Y, Luo RC . Aspirin for the primary prevention of skin cancer: A meta-analysis. Oncol Lett. 2015;93:1073-1080. PMID: 25663859. KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E9.25663859