# Appendix C Ongoing Studies

On December 14, 2016 we searched clinicaltrials.gov and WHO International Clinical Trials Registry platform for trials of behavioral counseling for sun protection and skin self-exam. We identified several relevant ongoing studies.

Study | Country | Population | Interventions | Relevant Outcomes | Anticipated Completion
A Randomized Controlled Trial of an Online Theory-based Intervention to Improve Adult Australians' Sun-protective Behaviours^21^ | Australia | Queensland residents aged 18 years and older | Online counseling lesson | Sun-protective behaviors | Currently recruiting
An Appearance-Based Intervention to Reduce Teen Skin Cancer Risk^2^ | USA | 13 to 18 year-old females who have indoor tanned or have intention to indoor tan | Appearance-focused website intervention vs. control website | Indoor tanning behavior | Last updated on ClinicalTrials.gov in 2012; estimated final date of data collection May 2014
Melanoma prevention in Australian primary care patients^3^ | Australia | Adults with no history of melanoma (n = 273) | Risk assessment with tailored feedback vs. risk assessment and no tailored feedback | Sun protection behaviors 12 weeks after intervention | NR
Sun Protection, Tanning Behaviors and Attitudes in Adolescents^4^ | USA | Children and adolescents 12 to 14 years old (n = 293) | UV photography | Sun protection behaviors, indoor tanning 12 weeks after intervention | 2018
Comparison of Two Strategies for Counseling Skin Examination and Sun Protection in First-degree Relatives of Patients With Melanoma (FADEMELA) ^5^ | France | First degree relatives to patient with personal history of Stage 0 through IIB melanoma (estimated enrollment n = 1125) | Written advice from patient's PCP to FDRs of melanoma patients about sun protection | Sun protection behaviors one year after intervention | 2018
The effect of personal ultraviolet radiation (UVR) devices and the SunSmart phone application on sun protection habits in the adult population in Queensland^6^ | Australia | Adults 18 to 35 with no history of skin cancer (n = 201) | UVR with and without Smart Phone Application (SunSmart) | Sun protection behaviors 12 weeks after intervention initaition | Data collection completed May 2016
Engaging Moms on Teen Indoor Tanning Through Social Media: Protocol of a Randomized Controlled Trial^7^ | USA | Mother-teen daughter dyads | Facebook-delivered health communication intervention | Indoor tanning 6 months after intervention | 2019
Educational programmes for primary prevention of skin cancer ^8^ (Cochrane review) | Multiple countries | Children and adults excluding high-risk groups for the development of skin cancer (e.g. transplant patients) or those with a history of skin cancer. | Studies that compare an educational program with the aim of preventing skin cancer with a placebo or no intervention. | The incidence of skin cancer following an educational program. | NR

## References

1 Cleary CM, White KM, Young RM, . Study protocol: a randomised controlled trial of a theory-based online intervention to improve sun safety among Australian adults. BMC Cancer. 2014;14:162-. PMID: PMC3973973.24602210
2 East Tennessee State University. An Appearance-Based Intervention to Reduce Teen Skin Cancer Risk (iSTART). Bethesda (MD): National Library of Medicine (US) [2016 Jan 06]. https://clinicaltrials.gov/ct2/show/NCT01508013 NLM identifier: NCT01508013.
3 Vuong K. Melanoma prevention in Australian primary care patients International Clinical Trials Registry Platform]. http://apps.who.int/trialsearch/Trial2.aspx?TrialID=ACTRN12615001019594.
4 Tripp M. Ultraviolet (UV) Photography in Adolescents. ClinicalTrials.gov]. https://clinicaltrials.gov/ct2/show/record/NCT02426853?term=sun+protection&rank=10.
5 Machet L. Comparison of Two Strategies for Counseling Skin Examination and Sun Protection in First-degree Relatives of Patients With Melanoma (FADEMELA) ClinicalTrials.gov]. https://clinicaltrials.gov/ct2/show/NCT02917473?term=counseling+for+skin+cancer&rank=58.
6 Lowe J. The effect of personal ultraviolet radiation (UVR) devices and the SunSmart phone application on sun protection habits. Australian New Zealand Clinical Trials Registry 2016]. https://www.anzctr.org.au/Trial/Registration/TrialReview.aspx?id=368458.
7 Pagoto SL, Baker K, Griffith J, . Engaging Moms on Teen Indoor Tanning Through Social Media: Protocol of a Randomized Controlled Trial. JMIR Res Protoc. 2016;5(4):e228. PMID: 27899339.27899339
8 Langbecker D, Diaz A, Chan RJ, . Educational programmes for primary prevention of skin cancer. Cochrane Database of Systematic Reviews [serial on the Internet]. 2014; (4): Available from: http://onlinelibrary.wiley.com/doi/10.1002/14651858.CD011061/abstract.