# Chapter 3 Results

## Description of Included Studies

### Literature Search Results

We reviewed 2,100 abstracts and 353 full-text articles for all KQs (Appendix B Figure 1). We included 21 unique trials, reported in 27 articles: 6 reported results in pediatric populations (n=4252)^168-173^ and 16 reported on adult populations (n=16,309) (Error! Reference source not found.).^173-188^ Of the 6 pediatric studies, five reported results in child populations (ages 0-12) and one reported results in adolescents (ages 11-15). Of the 16 adult studies, 3 reported results in young adults (ages 17-25 or university students), and 13 studies results in adults of a broad age range (ages 18 and older). One trial (the Project SCAPE [Skin Cancer Awareness, Prevention and Education] family study by Glanz and colleagues) reported results for both adults and children.^173^

Nine trials (10 articles) reported the effect of behavioral counseling on skin cancer outcomes (KQ1), 21 trials (27 articles) reported skin cancer prevention behaviors (KQ2), and two trials (two articles) reported harms of behavioral counseling for skin cancer prevention (KQ3). We found no studies that met our eligibility criteria for the association between skin self-exam and skin cancer outcomes (KQ4), and no studies on the harms of skin self-exam (KQ5).

Articles were most commonly excluded due to ineligible study design (did not include a comparison group, compared two active skin cancer counseling interventions, or not a randomized or controlled trial) or ineligible outcomes (Appendix B Table 1). Appendix C provides a list of all excluded studies, with the main reason for their exclusion.

### Quality

We rated 19 trials as fair quality and two as good quality. For trials rated as fair quality, limitations included a lack of reporting on how missing data were handled and incomplete reporting of blinding methods, randomization, allocation concealment, or followup rates. Followup rates ranged from 70.8 percent to 80.5 percent in pediatric studies, and 63.6 percent to 95.8 percent in adult trials. Less common were issues with the selection of control group, lack of reporting measures of intervention fidelity or adherence, and either baseline values or raw data not being reported.

All six pediatric trials^168-173^ and 9 adult trials^173, 175, 177-180, 182, 185, 186^ reported either process evaluation or measures of intervention adherence. Measures were heterogeneous across trials, such as participant report of receiving or using materials, mean number of phone contacts per participant, or participants' website usage. Most adherence estimates were above 70 percent and we found no measures that suggested poor fidelity or adherence.

### Outcome Assessment

All trials used self-report or parent-report to assess behavioral outcomes and sunburn, but there was heterogeneity in the time frames assessed (past month to past year), individual items or scales used, reporting of individual behaviors that make up composite scores, and reporting of unadjusted or absolute values. Sun protection behaviors most commonly were assessed using heterogeneously adapted versions^172, 173, 175, 176, 178, 182, 186, 188^ of the Sun Habits Index^189^ (Appendix A). Measures of skin self-exam also were heterogeneous, ranging from any or partial exam, to mole-checking, to total body exam with numbers of body parts examined

Trials typically did not supplement self-reported outcomes with direct observations or other objective measurement, though a few studies asked participants to complete sun protection diaries that were consistent with the composite measures.^172, 173, 175^ One study included a measure of tanning using a device designed to read skin darkening, which was consistent with self-reported results.^172^

In the single pediatric study reporting nevi counts, counts were conducted by trained health care providers.^172^ In the single adult study reporting skin cancer outcomes, participant medical records were the data source.^187^

Most trials timed assessments and interventions to address seasonality by choosing sunny climates as intervention sites, planning interventions to peak in spring, timing followup assessments in late summer or fall, or querying a specific time frame during assessment (e.g., most recent sun exposure). Exceptions included two older trials focused on multiple risk behaviors besides sun protection^183, 184^ and a trial whose primary outcome was skin self-exam. The skin self-exam trial did not assess sun protection behaviors so seasonal considerations in outcome assessment are likely minimal.^180^

## Results: Children and Adolescents

### Study Characteristics

Six trials, four published since the previous review, provided data for 4,252 children or adolescents (Error! Reference source not found.).^168-173^ All six trials took place in the United States and encompassed a generally wide age range. One trial included infants with followup to age 3;^168^ four trials included children between ages 3 and 10;^169, 170, 172, 173^ and one included adolescents aged 11–15 (Error! Reference source not found.).^171^ The four trials including children aged 3–10 all were published since the previous review. Two trials had risk-based inclusion criteria, limiting enrollment to children aged 4–10 at moderate or high skin cancer risk (n=1301; Project SCAPE family study by Glanz et al., 2013)^173^ and to children aged 12 and younger of melanoma survivors (n=340; Gritz et al., 2013).^170^ In the other four trials, children had varying constellations of skin cancer risk factors. The one trial that enrolled parents of infants (Kaiser Kids Sun Care by Crane et al., 2006) (n=728) reported no inclusion or exclusion criteria except the child's age (soon after birth), but parents with dark skin, eyes, and hair were informed that the program might have minimal benefit to them.^168^ Another included trial randomized children aged six of all phenotypes (n=867) but reported results only for non-Hispanic white participants (n=677).^172^ The Sun Smart trial (Norman et al., 2007) recruited adolescents aged 11–15 (58% White) from six primary care practices in California's San Diego County,^171^ whereas the Sun Sense trial (Glasser et al., 2010) among children aged 3–10 years (45% White) recruited parent-child pairs from a University of California-Los Angeles pediatric clinic.^169^ Across all six trials, white race ranged from 43.7 percent of the study population^169^ to 100 percent;^172^ two trials further provided a gradation of “fair white” skin^168, 172^ or skin that does not tan after burning.^172^

Most of the interventions focused on parents; some also provided child-appropriate materials (Error! Reference source not found.). In the one trial among adolescents, the adolescent was counseled directly. All intervention messages focused on increasing sun protective behaviors (e.g., using sunscreen, avoiding mid-day sun, wearing sun protective clothing) (Error! Reference source not found.). None of the interventions among children or adolescents focused on the use of indoor tanning or performing skin self-exam. Three of the six trials included direct, face-to-face counseling plus print and/or phone support.^168, 169, 171^ The most intensive trial was the Kaiser Kids Sun Care cluster RCT (Crane et al., 2006) targeting children aged 0–3.^168^ In this trial, intervention clinics placed prompts in each child's medical record to remind physicians to discuss sun protection with parents during well-child visits at 2, 6, 18, and 36 months; control sites performed usual care. Educational materials, sunscreen, a hat, and sunglasses also were provided. In the Sun Sense trial (Glasser et al., 2010) among children aged 3–10, parents and children randomized to the intervention took part in one 10–15 minute counseling session with a health educator and were given child-focused educational materials (print and video) and sun protection aids (t-shirt, sunscreen, hat).^169^ In the Sun Smart trial among adolescents (Norman et al., 2007), adolescents received brief (2–3 minute) tailored sun cancer risk information (based on computer-based assessment) from a primary care provider during one in-person counseling session and four followup phone calls from a health counselor.^171^ Adolescents also received mailed materials promoting sun protection and sunscreen samples. The remaining three trials^170, 172, 173^ were print-based with mailed materials directed to parents and/or children ranging from 3 mailings over 6 weeks^173^ to 14 mailings over 3 years.^172^ Two of these print-based interventions included materials tailored to the participant's level of risk, barriers to change, self-efficacy, or other factors.^172, 173^ For example, the Project SCAPE family study (Glanz et al., 2013) of children aged 4–10 and their parents involved three mailings of personalized risk feedback and recommendations, interactive skin cancer education materials, and a family fun guide about safe sun practices.^173^ All of the trials reported basing their interventions on accepted theoretical frameworks of health behavior change (e.g., Health Belief Model, Social Cognitive Theory).

### Summary of Results

None of the trials among children and adolescents reported skin cancer outcomes (KQ1). Three trials, however, reported the effects of the intervention on sunburn among children aged 3–10 (n=2,508). All three trials were published since the previous review and generally found no effect of the interventions on sunburn at 4-month to 3-year followup.^170, 172, 173^ One trial among 6-year-olds (Crane et al., 2012) found a small intervention effect on parent-reported nonsevere sunburn; but no effect on severe, blistering sunburn at 3 years.^172^ This same trial found no difference between the mean number of small or large nevi between intervention and control group children at 3-year followup.

All six of the trials among children and adolescents reported the effect of the intervention on composite sun protection behaviors (KQ2) (n=4252). No outcomes related to indoor tanning and skin self-exam were reported in the child and adolescent trials given the focus of the interventions. Five of the six trials found a statistically significant benefit of the intervention on parent-reported composite sun protection scores compared with controls at 3-month to 3-year followup. The individual items and scales measuring sun protective behaviors were highly variable across the trials and make interpretation of the absolute differences difficult (e.g., 0.7 between-group difference in change at 3 years on a 25-point scale).^172^ To assist with interpretation, we plotted standardized mean differences (Cohen's d) in change for the five trials that provided sufficient data. Effect sizes ranged from 0 to 0.96, with the three larger trials suggesting an effect ranging from 0.16 to 0.50 (average around 0.32)—a small to moderate effect (Error! Reference source not found.). Effects on sunscreen use and other individual sun protection behaviors were generally consistent within each trial. There were no apparent trends in the effectiveness of the interventions according to intervention or population characteristics. The population represented by these trials includes infants (1 trial; Crane et al., 2006) through adolescents aged 15 years (1 trial; Norman et al., 2007) with generally moderate-to-high risk based on race and/or skin type. The one trial that found no effect for both sunburn and sun protective behavior outcomes was the only trial focused on children of melanoma survivors (Gritz et al., 2013). The lack of effect in this trial may reflect the higher rates of protective behaviors in general at baseline, the relatively older age of the children included (mean age: 7.3 years), the motivation of the control group, or the lower uptake of the intervention (only 71% of intervention participants reported watching the educational DVD). None of the six trials among children or adolescents reported on harms of interventions.

### Detailed Results by KQ (Children and Adolescents)

#### KQ1 Does Counseling Patients in Skin Cancer Prevention Improve a) Intermediate Outcomes or b) Skin Cancer Outcomes?

Neither the included study of children aged 0–3 (Crane et al., 2006)^168^ nor the included study in adolescents (Norman et al., 2007)^171^ reported any intermediate or health outcomes (Table 5).

Table 5 Association Between Counseling Interventions and Intermediate Outcomes or Skin Cancer Outcomes (KQ1): Children and Adolescents

Study | Population | Intervention (number of sessions/mailings) | Followup (months) | Outcome | Question/instrument | Group | Followup N | Baseline | Followup | Between group difference
Crane 2012^172a^ Fair | Children age 6 | Tailored mailings (14): Newsletters for parents/children promoting child sun protection | 36 | Nevi (small) | Number of nevi <2mm; geometric mean (95% CI) | IG | 324 | 18.25 (17.32-19.22) | 35.64 (33.52-37.90) | p=0.52
Crane 2012^172a^ Fair | Children age 6 | Tailored mailings (14): Newsletters for parents/children promoting child sun protection | 36 | Nevi (small) | Number of nevi <2mm; geometric mean (95% CI) | CG | 310 | 18.25 (17.32-19.22) | 35.23 (33.10-37.49) | p=0.52
Crane 2012^172a^ Fair | Children age 6 | Tailored mailings (14): Newsletters for parents/children promoting child sun protection | 36 | Nevi (large) | Presence of nevi ≥2 mm; odds (95% CI) | IG | 324 | 1.29 (1.09-1.52) | 3.26 (2.48-4.27) | p=0.09
Crane 2012^172a^ Fair | Children age 6 | Tailored mailings (14): Newsletters for parents/children promoting child sun protection | 36 | Nevi (large) | Presence of nevi ≥2 mm; odds (95% CI) | CG | 310 | 1.29 (1.09-1.52) | 3.95 (2.95-5.29) | p=0.09
Crane 2012^172a^ Fair | Children age 6 | Tailored mailings (14): Newsletters for parents/children promoting child sun protection | 36 | Sunburn | Severe (blistering) sunburn, past year; any vs none, Odds (95% CI) | IG | 324 | 0.01 (0.01-0.03) | 0.02 (0.01-0.04) | p=0.15
Crane 2012^172a^ Fair | Children age 6 | Tailored mailings (14): Newsletters for parents/children promoting child sun protection | 36 | Sunburn | Severe (blistering) sunburn, past year; any vs none, Odds (95% CI) | CG | 310 | 0.01 (0.01-0.03) | 0.05 (0.03-0.09) | p=0.15
Crane 2012^172a^ Fair | Children age 6 | Tailored mailings (14): Newsletters for parents/children promoting child sun protection | 36 | Sunburn | Nonsevere sunburn past year; any vs none, Odds (95% CI) | IG | 324 | 0.82 (0.70-0.96) | 1.26 (1.01-1.57) | p=0.02
Crane 2012^172a^ Fair | Children age 6 | Tailored mailings (14): Newsletters for parents/children promoting child sun protection | 36 | Sunburn | Nonsevere sunburn past year; any vs none, Odds (95% CI) | CG | 310 | 0.82 (0.70-0.96) | 1.43 (1.14-1.79) | p=0.02
Glanz 2013^173^ Good | Children ages 4-10 at increased skin cancer risk | Tailored mailings (3) for parents promoting children's sun protection | 4 | Sunburn | Red/painful sunburns past 12 mo (Scale 1=one to 5=5 or more) mean (SE)^b^ | IG | 517 | 1.61 (0.04) | 1.27 (0.04) | Effect size NR; p=0.67^b^
Glanz 2013^173^ Good | Children ages 4-10 at increased skin cancer risk | Tailored mailings (3) for parents promoting children's sun protection | 4 | Sunburn | Red/painful sunburns past 12 mo (Scale 1=one to 5=5 or more) mean (SE)^b^ | CG | 530 | 1.68 (0.04) | 1.37 (0.04) | Effect size NR; p=0.67^b^
Gritz 2013^170^ Fair | Children (age ≤12) of melanoma survivors | Standard mailings (3) promoting sun protection; print materials, DVD; children's activities | 4 | Sunburn | Rate of sunburns past 6 mo (baseline) or past 3 mo (followup) | IG | 138 | NR | NR | p=0.98^c^
Gritz 2013^170^ Fair | Children (age ≤12) of melanoma survivors | Standard mailings (3) promoting sun protection; print materials, DVD; children's activities | 4 | Sunburn | Rate of sunburns past 6 mo (baseline) or past 3 mo (followup) | CG | 143 | NR | NR | p=0.98^c^

a Crane 2012 randomized 867 participants but only reported results for white non-Hispanic participants (n=677). The authors report that results for white non-Hispanic participants were similar to results for all participants.

b Adjusted for location and risk group.

c Adjusted for demographics, sun sensitivity, and clinical characteristics. For the binary outcome of sunburn decreasing between baseline and followup, the authors report an odds ratio of 1.01 (95% CI NR).

Abbreviations: KQ=key question, CI=confidence interval, IG=intervention group, CG=control group, NR=not reported, SE=standard error, mo=months.

##### Children Aged 3–10

Sunburn. Only one of the three trials reporting sunburn outcomes in children found a statistically significant effect of the intervention. The trial by Crane and colleagues (2012) among 6-year-olds found a small intervention effect at 3 years for the odds of nonsevere sunburn in the previous year (effect size, -0.25 [95%, CI -0.47 to -0.04], p=0.02, frequencies not reported) but no effect for severe, blistering sunburn in the same time period (effect size, -0.52 [95% CI, -1.23 to 0.19], p=0.15).^172^ These results, however, were only among the 677 non-Hispanic white participants; results for all participants (n=867) were not reported. The remaining two trials found no effect. In the Project SCAPE family study by Glanz and colleagues (2013), parent-reported frequency of red/painful sunburn in the previous 12 months decreased in both groups between baseline and 4-month followup (1–5 scale of 1 sunburn per month to 5 sunburns per month over the past year): from 1.61 to 1.27 in the intervention group and from 1.68 to 1.37 in the control group) but the between-group difference was not statistically significant, suggesting the tailored materials in the intervention group may not have improved sunburn outcomes beyond the minimal intervention given to the control group.^173^ Likewise, in the study of children of melanoma survivors (Gritz et al., 2013), there was no difference in number of sunburns between groups at 4 months (frequencies not reported, adjusted treatment effect p=0.98).^170^

Nevi. Crane (2012) also assessed the presence of nevi in study children. The mean number of small nevi (<2 mm) increased similarly in the intervention (18.3 to 35.6) and control groups (18.3 to 35.2) (between-group difference, p=0.52) between baseline and 3-year followup. The odds of having large nevi (≥2 mm) also were similar in both groups at followup (p=0.09).^172^

#### KQ2 Do Primary Care–Relevant Counseling Interventions Improve Skin Cancer Prevention Behaviors?

##### Children Aged 0–3

The Kaiser Kids Sun Care trial by Crane and colleagues (2006) involved a comprehensive primary care-based intervention among parents of infants through 3 years of age (n=728). It found a statistically significant difference between the intervention and usual care control group in parent-reported sun protection behaviors over 3-year followup (p=0.04 group by time effect).^168^ At 3 years, mean scores on the use of 7 sun protection strategies (scale range 7–28) were 18.2 among intervention versus 17.7 among control group participants (p=0.049). Behaviors in both groups peaked at 1 year, remained steady at year 2, and declined by year 3, although the intervention group scores declined more slowly. Individual sun protective behaviors showing a difference between groups at 3-year followup were sunglasses (39.4% vs. 29.9% at 3 years, p=0.02) and hat use (57.3% vs. 47.4%, p=0.02; hats were provided as part of the intervention). Over the entire study period, only shade-seeking was significantly higher in the intervention group (72.6% vs. 65.2% at 3 years; p=0.06 at 3 years, p=0.03 overall test) (Table 6).^168^

Table 6 Association Between Counseling Interventions and Skin Cancer Prevention Behaviors (KQ2): Children and Adolescents^a^

Study | Population | Intervention (number of sessions/mailings) | Followup (months) | Outcome | Question/instrument | Group | Followup N | Baseline | Followup | Between group difference
Crane 2006^168^ Fair | Children age <1 | PCP counseling (4); print materials for parents promoting child sun protection (4); sunscreen samples; hat | 36 | Sun protection | Scale: Use of 7 sun protection strategies for child between 11 am and 3 pm (mean) (possible score 7-28)^b^ | IG | 276 | NR | 18.2 | p=0.04 (overall effect)^c^
Crane 2006^168^ Fair | Children age <1 | PCP counseling (4); print materials for parents promoting child sun protection (4); sunscreen samples; hat | 36 | Sun protection | Scale: Use of 7 sun protection strategies for child between 11 am and 3 pm (mean) (possible score 7-28)^b^ | CG | 269 | NR | 17.7 | p=0.04 (overall effect)^c^
Crane 2006^168^ Fair | Children age <1 | PCP counseling (4); print materials for parents promoting child sun protection (4); sunscreen samples; hat | 36 | Sunscreen | Always/frequently use 11am-3pm, N (%) | IG | 276 | NR | 260.0 (94.2) | p=0.46 (overall effect)
Crane 2006^168^ Fair | Children age <1 | PCP counseling (4); print materials for parents promoting child sun protection (4); sunscreen samples; hat | 36 | Sunscreen | Always/frequently use 11am-3pm, N (%) | CG | 269 | NR | 250.0 (93.1) | p=0.46 (overall effect)
Crane 2012^172d^ Fair | Children age 6 | Tailored mailings (14): Newsletters for parents/children promoting child sun protection | 36 | Sun protection | 5 sun protection strategies (1 never to 5 very often for each), mean (95% CI)^e^ | IG | 344 | 15.6 (15.4-15.8) | 16.3 (16.1-16.6)^f^ | p<0.001^g^
Crane 2012^172d^ Fair | Children age 6 | Tailored mailings (14): Newsletters for parents/children promoting child sun protection | 36 | Sun protection | 5 sun protection strategies (1 never to 5 very often for each), mean (95% CI)^e^ | CG | 333 | 15.6 (15.4-15.8) | 15.6 (15.3-15.8) | p<0.001^g^
Crane 2012^172d^ Fair | Children age 6 | Tailored mailings (14): Newsletters for parents/children promoting child sun protection | 36 | Sunscreen | Use on days child is outside ≥15 min, current summer (1 never to 5 very often); mean (95% CI) | IG | 344 | 4.2 (4.1-4.3) | 4.3 (4.1-4.3) | p<0.001
Crane 2012^172d^ Fair | Children age 6 | Tailored mailings (14): Newsletters for parents/children promoting child sun protection | 36 | Sunscreen | Use on days child is outside ≥15 min, current summer (1 never to 5 very often); mean (95% CI) | CG | 333 | 4.2 (4.1-4.3) | 4.2 (4.2-4.4) | p<0.001
Glasser 2010^169^ Fair | Children age 3-10 | In-person parent education (1); materials (children's video, print materials); sun protection aids (shirt, hat, sunscreen) | 3 | Sun protection | Scale: 3 sun protection behaviors: 3 (low) to 12 (high), mean (SD)^h^ | IG | 71 | 7.4 (2.1) | 9.4 (2.2) | p=0.0001^i^
Glasser 2010^169^ Fair | Children age 3-10 | In-person parent education (1); materials (children's video, print materials); sun protection aids (shirt, hat, sunscreen) | 3 | Sun protection | Scale: 3 sun protection behaviors: 3 (low) to 12 (high), mean (SD)^h^ | CG | 70 | 7.5 (2.0) | 7.5 (2.0) | p=0.0001^i^
Glasser 2010^169^ Fair | Children age 3-10 | In-person parent education (1); materials (children's video, print materials); sun protection aids (shirt, hat, sunscreen) | 3 | Sun protection | Scale: 3 sun avoidance behaviors: 3 (low) to 12 (high), mean (SD)^j^ | IG | 71 | 8.3 (2.1) | 9.3 (2.1) | p=0.07^i^
Glasser 2010^169^ Fair | Children age 3-10 | In-person parent education (1); materials (children's video, print materials); sun protection aids (shirt, hat, sunscreen) | 3 | Sun protection | Scale: 3 sun avoidance behaviors: 3 (low) to 12 (high), mean (SD)^j^ | CG | 70 | 9.0 (2.2) | 9.0 (2.2) | p=0.07^i^
Glasser 2010^169^ Fair | Children age 3-10 | In-person parent education (1); materials (children's video, print materials); sun protection aids (shirt, hat, sunscreen) | 3 | Sunscreen | Use most of the time, N (%)^k^ | IG | 71 | 29.0 (41.0) | 50.0 (70.0) | p=0.0132^l^
Glasser 2010^169^ Fair | Children age 3-10 | In-person parent education (1); materials (children's video, print materials); sun protection aids (shirt, hat, sunscreen) | 3 | Sunscreen | Use most of the time, N (%)^k^ | CG | 70 | 32.0 (46.0) | 35.0 (50.0) | p=0.0132^l^
Glanz 2013^173^ Good | Children age 4-10 at increased skin cancer risk | Tailored mailings (3) for parents promoting family sun protection | 4 | Sun protection | Scale: 5 behaviors past 3 mo, 1 rarely/never to 4 always, mean (SE)^m n^ | IG | 517 | 2.2 (0.0) | 2.5 (0.0) | Effect size 0.16; p<0.0001^m o^
Glanz 2013^173^ Good | Children age 4-10 at increased skin cancer risk | Tailored mailings (3) for parents promoting family sun protection | 4 | Sun protection | Scale: 5 behaviors past 3 mo, 1 rarely/never to 4 always, mean (SE)^m n^ | CG | 530 | 2.2 (0.0) | 2.3 (0.0) | Effect size 0.16; p<0.0001^m o^
Glanz 2013^173^ Good | Children age 4-10 at increased skin cancer risk | Tailored mailings (3) for parents promoting family sun protection | 4 | Time in sun | Hours spent in sun per day, <1 to 6 per day, 10am-4pm, weekends or weekday, mean (SE)^m^ ^p^ | IG | 517 | 3.41 (0.1) | 2.98 (0.1) | Effect size NR; p=0.24^m^
Glanz 2013^173^ Good | Children age 4-10 at increased skin cancer risk | Tailored mailings (3) for parents promoting family sun protection | 4 | Time in sun | Hours spent in sun per day, <1 to 6 per day, 10am-4pm, weekends or weekday, mean (SE)^m^ ^p^ | CG | 530 | 3.5 (0.1) | 3.1 (0.1) | Effect size NR; p=0.24^m^
Glanz 2013^173^ Good | Children age 4-10 at increased skin cancer risk | Tailored mailings (3) for parents promoting family sun protection | 4 | Sunscreen | Use 10am-4pm, 1 (rarely) to 4 (always), mean (SE)^m^ | IG | 517 | 3.1 (0.0) | 3.3 (0.0) | Effect size 0.13; p<0.0001^m^
Glanz 2013^173^ Good | Children age 4-10 at increased skin cancer risk | Tailored mailings (3) for parents promoting family sun protection | 4 | Sunscreen | Use 10am-4pm, 1 (rarely) to 4 (always), mean (SE)^m^ | CG | 530 | 3.2 (0.0) | 3.2 (0.0) | Effect size 0.13; p<0.0001^m^
Glanz 2013^173^ Good | Children age 4-10 at increased skin cancer risk | Tailored mailings (3) for parents promoting family sun protection | 4 | SSE | SSE by parent, past 3 mo, adjusted % (SE)^m^ | IG | 517 | 60.0 (0.1) | 87.0 (0.1) | p=0.06^m^; Effect size: NY: 0.22, Hawaii:(-0.02)
Glanz 2013^173^ Good | Children age 4-10 at increased skin cancer risk | Tailored mailings (3) for parents promoting family sun protection | 4 | SSE | SSE by parent, past 3 mo, adjusted % (SE)^m^ | CG | 530 | 57.0 (0.2) | 81.0 (0.1) | p=0.06^m^; Effect size: NY: 0.22, Hawaii:(-0.02)
Gritz 2013^170^ Fair | Children (age ≤12) of melanoma survivors | Standard mailings (3) promoting sun protection; print materials, DVD; children's activities | 4 | Sun protection | Scale: 14 behaviors past 3 mo; 1(fewer) to 5 (more), mean (SE)^q^ | IG | 138 | 3.4 (0.1)^r^ | 3.7 (0.1)^r^ | p=0.94
Gritz 2013^170^ Fair | Children (age ≤12) of melanoma survivors | Standard mailings (3) promoting sun protection; print materials, DVD; children's activities | 4 | Sun protection | Scale: 14 behaviors past 3 mo; 1(fewer) to 5 (more), mean (SE)^q^ | CG | 143 | 3.4 (0.1)^r^ | 3.7 (0.1)^r^ | p=0.94
Gritz 2013^170^ Fair | Children (age ≤12) of melanoma survivors | Standard mailings (3) promoting sun protection; print materials, DVD; children's activities | 4 | Sunscreen | Scale: sunscreen behaviors from 7 items, past 3 mo; 1(fewer) to 5(more), mean (SE)^s^ | IG | 138 | 2.64 (0.1) | 2.89 (0.1) | p=0.79
Gritz 2013^170^ Fair | Children (age ≤12) of melanoma survivors | Standard mailings (3) promoting sun protection; print materials, DVD; children's activities | 4 | Sunscreen | Scale: sunscreen behaviors from 7 items, past 3 mo; 1(fewer) to 5(more), mean (SE)^s^ | CG | 143 | 2.64 (0.1) | 2.87 (0.1) | p=0.79
Norman 2007^171, 190, 191^ Fair | Adolescents age 11-15 | PCP counseling using tailored risk information (1);phone counseling (4); mailed materials promoting sun protection; sunscreen samples | 24 | Sun protection | Scale: 7 behaviors past 6 mo; 1 (never) to 5 (always), T score mean (95% CI)^t^ | IG | 315 | 48.0 (47.1, 49.0)^u^ | 52.0 (50.9, 53.1)^u^ | p=0.003^v^
Norman 2007^171, 190, 191^ Fair | Adolescents age 11-15 | PCP counseling using tailored risk information (1);phone counseling (4); mailed materials promoting sun protection; sunscreen samples | 24 | Sun protection | Scale: 7 behaviors past 6 mo; 1 (never) to 5 (always), T score mean (95% CI)^t^ | CG | 341 | 47.9 (47.0, 48.9)^u^ | 48.7 (47.6, 50.0)^u^ | p=0.003^v^
Norman 2007^171, 190, 191^ Fair | Adolescents age 11-15 | PCP counseling using tailored risk information (1);phone counseling (4); mailed materials promoting sun protection; sunscreen samples | 24 | Sunscreen | Always/often use sunscreen, past 6 mo, % (95% CI) | IG | 315 | NR | 52.9 (48.8, 57.0)^u^ | p<0.05
Norman 2007^171, 190, 191^ Fair | Adolescents age 11-15 | PCP counseling using tailored risk information (1);phone counseling (4); mailed materials promoting sun protection; sunscreen samples | 24 | Sunscreen | Always/often use sunscreen, past 6 mo, % (95% CI) | CG | 341 | NR | 45.9 (41.8, 49.8)^u^ | p<0.05

a Results for individual sun protection behaviors (e.g., hat use, wearing sunglasses, avoiding mid-day sun, etc.) are not reported separately in this table. Statistically significant individual behaviors favoring the intervention group are noted in footnotes.

b Behaviors in this scale: Shade-seeking, protective clothing, sunglasses, limiting sun exposure, hat use, and avoiding mid-day sun. No variance reported (SE/SD NR).

c Statistically significant individual behaviors favoring IG at followup: Hat use and wearing sunglasses.

d Crane 2012 randomized 867 participants, but only reported results for white non-Hispanic participants (n=677). The authors report that results for White non-Hispanic participants were similar to results for all participants.

e Behaviors in this scale: Clothing, hats, shade, sunscreen, midday sun avoidance.

f Adjusted in linear mixed model analysis for within-child correlation over time.

g Statistically significant individual behaviors favoring IG at followup: Avoiding mid-day sun, wearing protective clothing, hat use, and shade-seeking.

h Behaviors in this scale: Hat, shirt, sunscreen. Each item options 1 (rarely) to 4 (most of the time). Time frame asked is NR.

i Main effect, IG vs CG at followup, adjusted for race/ethnicity, age, pretest knowledge, attitudes, and behaviors. Analysis of covariance models were used to analyze effect of intervention on followup scores for sun protection and sun avoidance, corrected for baseline scores and for demographic differences between groups.

j Behaviors in this scale: Considered sun when planning activities; adjusted activities for sun avoidance; limited time in the sun. Each item options 1 (rarely) to 4 (most of the time). Time frame asked is NR.

k Parent-reported; time frame NR.

l Calculated p-value (p value for between group differences is NR in paper).

m Adjusted for location and risk group.

n Behaviors in this scale: shirt with sleeves, sunglasses, shade-seeking, sunscreen, hat.

o Statistically significant individual behaviors favoring IG at followup: Hat use, wearing a shirt, and wearing sunglasses.

p Parent report of children's time in sun.

q Behaviors in this scale: Sunscreen (7 items); clothing (5 items); shade-seeking (1 item); avoiding midday sun (1 item).

r This is not an error. Baseline and followup values were identical for IG and CG per the paper (B=0.000).

s Behaviors in this scale include applying sunscreen 30 minutes before going outdoors; reapplying within 1 hour; reapplying after each hour outdoors.

t Behaviors in this scale: Shirt, shade-seeking, avoiding midday sun, limiting sun exposure, 3 sunscreen items (general, SPF 15 on face, SPF 15 on body). Cites Weinstock 2000 Sun Protection Behavior Scale.^202^

u Data extrapolated from figure in paper.

v Statistically significant individual behaviors favoring IG at followup: Avoiding mid-day sun, limiting sun exposure, all sunscreen items.

Abbreviations: KQ=key question, PCP=primary care provider, IG=intervention group, CG=control group, NR=not reported, CI=confidence interval, SD=standard deviation, SE=standard error, SSE=skin self-exam, NY=New York.

No significant differences were apparent at the 3-year followup in sunscreen use even though sunscreen samples were provided as part of the intervention. However, very high proportions of parents in both groups reported always or frequent use of sunscreen on their child (94.2% and 93.1%, not significant [NS]) and 99 percent of the population reported intentions to use sunscreen at baseline, suggesting parents may have been educated about sunscreen before the study.^168^

##### Children Aged 3–10

Three of the four trials among children aged 3–10 reported statistically significant between-group differences for changes in sun protection behaviors and sunscreen use at 3-month to 3-year followup.^169, 172, 173^ For example, in the good-quality Project SCAPE family study (Glanz et al., 2013) among children aged 4–10 at increased skin cancer risk (n=1301), statistically significant group by time intervention effects were found for composite child sun protective behaviors (study-reported effect size, 0.16; p<0.001), sunscreen use (study-reported effect size, 0.13; p<0.0001), wearing a shirt (p<0.001), wearing a hat (p<0.001), and wearing sunglasses (p<0.03) following the tailored mailed intervention. No effect was seen for sun avoidance measures (i.e., staying in the shade or mid-day sun exposure). Absolute mean changes over 4 months on the composite sun protection scale (range 1–4 with higher scores equaling higher frequency) were from 2.19 (standard error [SE] 0.02) to 2.48 (SE 0.02) among the intervention group versus 2.19 (SE 0.02) to 2.34 (SE 0.02) among control group participants. Treatment effect was observed at the New York site (effect size 0.22) and not at the Hawaii site (effect size -0.02).^173^

The tailored mailed intervention among 6-year-olds (n=677) reported by Crane (2012),^172^ found a small, statistically significant benefit of the intervention over the 3 years of followup in the composite sun protection score (overall group by time effect, p<0.001) but there was no consistent effect of the intervention on individual sun protection behaviors over time (i.e., sunscreen use, clothing use, avoiding mid-day sun, limiting time in sun, shade use, hat use, and sunglasses use). The smaller Sun Sense trial (n=197; Glasser et al., 2010) found a statistically significant effect of the counseling intervention on composite sun protection behaviors (hat, shirt, and sunscreen use) and use of sunscreen at 3 months, but not on composite sun avoidance behaviors (considered the sun when planning activities, adjusted activities for sun avoidance, and limited time in the sun).^169^ This intervention, “Slip, Slop, Slap,” specifically emphasized sun protection behaviors rather than sun avoidance.

The one study finding no effect on sun protection behaviors again was the trial among children of melanoma survivors (n=340; Gritz et al., 2013).^170^ Sun protection scores and sunscreen use improved among both intervention and control group participants from baseline to 4-month followup with no between-group difference. For example, mean composite sun protection scores increased from 3.41 to 3.65 (on a 5-point scale) in both groups over 4 months. The study found a statistically significant increase in wide-brimmed hat use in the intervention group compared with the control group; and both groups scored 3.9 on a 5-point scale for limiting time outdoors at baseline, suggesting this population may be already practicing sun avoidance.

##### Adolescents Aged 11–15

In the SunSmart study involving physicians directly counseling adolescents (Norman et al., 2007), followup phone counseling by a health educator, and print materials, sun protection composite scores were higher at 2-year followup in the intervention group compared with the control group (scores not reported; p=0.003) as was sunscreen use (52.9% vs. 45.9% p<0.05).^171, 190, 191^ The intervention group was roughly 5 to 10 percent (exact numbers not reported) more likely to report “always” or “often” avoiding midday sun exposure, limiting midday sun exposure, using sunscreen on the face, and using sunscreen on sun-exposed areas. There were no differences between the two groups for wearing a shirt or staying in the shade.

#### KQ3 What Are the Harms of Counseling Interventions for Skin Cancer Prevention?

No studies.

#### KQ4 What Is the Association Between Skin Self-Examination and Skin Cancer Outcomes?

No studies.

#### KQ5 What Are the Harms of Skin Self-Examination?

No studies.

## Results: Adults and Young Adults

### Study Characteristics

Sixteen trials (reported in 20 articles), including 16,309 adults in total, met our inclusion criteria (Error! Reference source not found.).^173-188^ Ten were published since the previous review.^173, 175, 176, 178, 180, 182, 185-188^ We rated 14 as fair quality (n=14,462) and two as good quality (n=1847). Eleven trials took place in the United States, three in Australia, one in France, and one in the United Kingdom.

Most trials included adults with broad age criteria, but three included specifically young adults aged 18–25^178^ or university students^179, 181^ (n=1528) and one included only men over age 50 (Error! Reference source not found.).^180^ One study^173^ included parents of children aged 4–10 as part of a family-focused intervention. Study populations were predominantly white or fair-skinned (45.0% to 100%, with all but one study above 60% white) and predominantly female, with seven trials having a population that was 70 percent or more female.^173, 175-177, 183-185^ Ten adult trials used risk-based inclusion criteria,^174-180, 182, 185, 186^ but all study populations had substantial skin cancer risk factors. Four trials included adults at moderate or high skin cancer risk as measured by risk assessment tools.^175, 176, 178, 185, 186^ In one nonrandomized trial, patients were eligible for the intervention group if they had one or more melanoma risk factor and control group participants were selected to match the skin and demographic profile of intervention group participants.^177^ Two trials included only adult siblings^174^ or first-degree relatives^182^ of melanoma patients, and one study included female university students who use indoor tanning.^179^ Sample sizes ranged from 108 to 5407 with a median sample size of 568.

Interventions varied in their settings, messages, components, and delivery (Error! Reference source not found., Error! Reference source not found.). Seven of the 16 trials were either conducted in or recruited from primary care.^175-177, 183, 185-187^ Four were conducted directly in primary care settings^177, 185-187^ and three recruited participants from a primary care setting but conducted their interventions by mail.^175, 176, 183^ We judged the remaining interventions to be referable from or feasible for primary care. The majority of the interventions included comprehensive skin cancer prevention messages, such as general skin cancer education and strategies for reducing sun exposure (sun protection/sun avoidance behaviors). Several also included messages promoting or teaching skin self-exams,^174, 176-178, 182^ and three trials included interventions focused exclusively on conducting skin self-exams.^180, 187, 188^

One trial among young adults focused solely on reducing indoor tanning use (among indoor tanning users).^179^ The other two young adult trials focused on improving skin cancer prevention behaviors. One involved a tailored interactive educational web program called UV4.me, and one was an appearance-focused intervention involving personal UV facial photographs and a brief video about photoaging.

The majority of the interventions (7 trials) were strictly mail-based interventions whereby participants received print materials, videos, and/or skin cancer prevention aids (e.g., sunscreen, mirrors for skin self-exams) mailed directly to their homes.^173, 175, 176, 179, 180, 183, 184^ Five trials included direct face-to-face or phone counseling in addition to print materials: in two trials the counseling was provided in-person by primary care physicians,^185, 186^ and in the remaining three trials the counseling was provided by health educators or study staff either in-person^187^ or via phone.^174, 182^ Four interventions were technology-based, using text messages,^188^ an interactive online program,^178^ an interactive computer module provided in a primary care setting,^177^ or simulated participant UV facial images to reinforce intervention messages.^181^ All but two of the 16 trials included tailored feedback or education specific to the participant's level of risk and/or barriers to change. The other two included relatively focused populations (young adult female indoor tanners^179^ and men over age 50^180^) that allowed for specific intervention messaging.

Interventions had varying contact with participants, ranging from a single distribution of standard print materials^179^ to a six-month intervention involving individually tailored brief counseling from a health educator, followup phone calls, a tailored letter, educational print and video materials, and skin self-exam aids.^187^ Five trials were limited to a single session with no reinforcement of study messages.^177, 179, 181, 185, 186^ The longest interventions, one of text messages^188^ and two of mailed materials,^183, 184^ took place over the course of one year.

### Summary of Results

Seven trials among adults (n=5315) (six fair-quality and one good-quality) reported the effects of the intervention on health or intermediate outcomes of relevance to KQ1: six trials reported the effects on sunburn and one reported on nevi and skin cancer outcomes. All seven trials reporting KQ1 outcomes represent new evidence. In general, there was no effect of the interventions on the number or frequency of sunburns at 3-month to 1-year followup. Only one trial in young adults (n=965) found a statistically significant improvement in the frequency of red or painful sunburns among intervention versus control group participants at 3-month followup. Only one adult trial (n=1356) reported skin cancer outcomes and found no difference in the number of melanomas detected between groups at 1 year after an intervention promoting skin self-exam.

In terms of behavioral outcomes (KQ2), half of the trials (6 of 12 trials) found small, statistically significant improvements in self-reported sun protection behaviors after the intervention compared to control conditions over 3-month to 2-year followup; similarly, four of seven trials reporting sunscreen use found improvements. Standardized mean differences in change (Cohen's d) in composite sun protection scores ranged from -0.46 (in favor of the control group) to 0.57 (in favor of the intervention group) although most effects were in the magnitude of a 0.10 to 0.20 effect size (Error! Reference source not found.). There were minimal data on the effects of the interventions on indoor tanning use. Only one trial among female indoor tanners (n=430) found an attenuated increase in tanning sessions at 6-month followup relative to the control group.

The most consistent results were observed for self-reported skin self-exams. Of eleven trials (n=7771) assessing skin self-exam, nine adult trials found that interventions were associated with small, statistically significant increases in rates of total or partial skin self-exam compared to control conditions at 3-month to 1-year followup.

Harms of interventions were reported in only two studies. One study suggested an increase in skin procedures in the first six months after a skin self-exam-focused trial, but found no difference at 12 months.^187^ Skin cancer worry did not differ between groups in one adult study focused on risk assessment and sun protection counseling.^185^

### Detailed Results by KQ (Adults and Young Adults)

#### KQ1 Does Counseling Patients in Skin Cancer Prevention Improve: a) Intermediate Outcomes or b) Skin Cancer Outcomes?

##### Sunburn

Only one trial found an intervention effect (Table 7). In the 3-group UV4.me trial by Heckman and colleagues (2016) of online education for young adults (n=965, 86% fair skin), the proportion of participants reporting red/painful sunburn in the past month decreased more markedly from baseline to 3 months in the intervention group compared to the other groups (54.5% to 26.3% in the intervention group; 51.5% to 38.2% in the public website group; 56.3% to 41.2% in the assessment-only control group, p=0.014 for intervention vs. assessment-only; NS for intervention vs. public website).^178^

Table 7 Association Between Counseling Interventions and Intermediate Outcomes or Skin Cancer Outcomes (KQ1): Adults and Young Adults

Study | Population | Intervention (number of sessions/mailings) | Followup (months) | Outcome | Question/instrument | Group | Followup N | Baseline | Followup | Between group difference
Glanz 2010^175^ Fair | Adults age 20-65 at increased skin cancer risk | Tailored mailings (3) promoting sun protection and SSE; SSE aids | 4 | Sunburn | Red/painful sunburns in past 12 mo; Scale of 0=none to 3=3 or more sunburns; Mean (SE)^a^ | IG | 307 | 1.44 (0.07) | 0.89 (0.07) | p=0.14^a^
Glanz 2010^175^ Fair | Adults age 20-65 at increased skin cancer risk | Tailored mailings (3) promoting sun protection and SSE; SSE aids | 4 | Sunburn | Red/painful sunburns in past 12 mo; Scale of 0=none to 3=3 or more sunburns; Mean (SE)^a^ | CG | 289 | 1.37 (0.07) | 0.96 (0.07) | p=0.14^a^
Glanz 2013^173^ Good | Parents of children age 4-10 | Tailored mailings (3) for parents promoting children's sun protection | 4 | Sunburn | Red/painful sunburns in past 12 mo; Scale of 1=one to 5=5 or more sunburns; mean (SE) | IG | 517 | 1.46 (0.04) | 1.00 (0.04) | Effect size NR; p=0.97^b^
Glanz 2013^173^ Good | Parents of children age 4-10 | Tailored mailings (3) for parents promoting children's sun protection | 4 | Sunburn | Red/painful sunburns in past 12 mo; Scale of 1=one to 5=5 or more sunburns; mean (SE) | CG | 530 | 1.49 (0.04) | 1.03 (0.04) | Effect size NR; p=0.97^b^
Glanz 2015^176^ Fair | Adults (age range 18-91) at increased skin cancer risk | Tailored mailings (3) on risk reduction, SSE, clinical skin exam, and sunscreen | 3 | Sunburn | Any sunburns in last 3 mo; (1=never; to 4=more than twice); Mean (SD) | IG | 83 | 1.54 (0.77) | 1.47 (0.70) | p=0.065^c^
Glanz 2015^176^ Fair | Adults (age range 18-91) at increased skin cancer risk | Tailored mailings (3) on risk reduction, SSE, clinical skin exam, and sunscreen | 3 | Sunburn | Any sunburns in last 3 mo; (1=never; to 4=more than twice); Mean (SD) | CG | 109 | 1.46 (0.87) | 1.56 (0.92) | p=0.065^c^
Heckman 2016^178^ Fair | Young adults age 18-25 at increased skin cancer risk | IG1: Tailored interactive web program (12 modules) IG2: Public website | 3 | Sunburn | Red/painful sunburn in past mo, N (%) | IG1 | 195 | 156 (54.5) | 51 (26.3) | p=0.014
Heckman 2016^178^ Fair | Young adults age 18-25 at increased skin cancer risk | IG1: Tailored interactive web program (12 modules) IG2: Public website | 3 | Sunburn | Red/painful sunburn in past mo, N (%) | IG2 | 205 | 172 (51.5) | 78 (38.2) | p=0.014
Heckman 2016^178^ Fair | Young adults age 18-25 at increased skin cancer risk | IG1: Tailored interactive web program (12 modules) IG2: Public website | 3 | Sunburn | Red/painful sunburn in past mo, N (%) | CG | 229 | 191 (56.3) | 94 (41.2) | p=0.014
Rat 2014^185^ Fair | Adults at increased melanoma risk | PCP counseling using tailored feedback (1) | 5 | Sunburn | Any sunburn in previous summer, N (%) | IG | 97 | NR | 26 (26.8) | p=0.42^d^
Rat 2014^185^ Fair | Adults at increased melanoma risk | PCP counseling using tailored feedback (1) | 5 | Sunburn | Any sunburn in previous summer, N (%) | CG | 76 | NR | 23 (30.3) | p=0.42^d^
Weinstock 2007^187^ Fair | Adults age ≥18 | Study team counseling (2); materials promoting SSE (print, video); SSE aids; tailored letter (1) | 12 | Nevi | Diagnosed severely atypical nevi during 12-mo study period, N (%) | IG | 688 | NR | 1 (0.15) | NR
Weinstock 2007^187^ Fair | Adults age ≥18 | Study team counseling (2); materials promoting SSE (print, video); SSE aids; tailored letter (1) | 12 | Nevi | Diagnosed severely atypical nevi during 12-mo study period, N (%) | CG | 668 | NR | 1 (0.15) | NR
Weinstock 2007^187^ Fair | Adults age ≥18 | Study team counseling (2); materials promoting SSE (print, video); SSE aids; tailored letter (1) | 12 | Melanoma | Diagnosed melanoma during 12-mo study period, N (%) | IG | 688 | NR | 0 (0) | NR
Weinstock 2007^187^ Fair | Adults age ≥18 | Study team counseling (2); materials promoting SSE (print, video); SSE aids; tailored letter (1) | 12 | Melanoma | Diagnosed melanoma during 12-mo study period, N (%) | CG | 668 | NR | 1 (0.15) | NR
Weinstock 2007^187^ Fair | Adults age ≥18 | Study team counseling (2); materials promoting SSE (print, video); SSE aids; tailored letter (1) | 12 | BCC | Diagnosed BCC during 12-mo study period, N (%) | IG | 688 | NR | 7 (1.02) | NR
Weinstock 2007^187^ Fair | Adults age ≥18 | Study team counseling (2); materials promoting SSE (print, video); SSE aids; tailored letter (1) | 12 | BCC | Diagnosed BCC during 12-mo study period, N (%) | CG | 668 | NR | 3 (0.45) | NR
Weinstock 2007^187^ Fair | Adults age ≥18 | Study team counseling (2); materials promoting SSE (print, video); SSE aids; tailored letter (1) | 12 | SCC | Diagnosed SCC during 12-mo study period, N (%) | IG | 688 | NR | 3 (0.44) | NR
Weinstock 2007^187^ Fair | Adults age ≥18 | Study team counseling (2); materials promoting SSE (print, video); SSE aids; tailored letter (1) | 12 | SCC | Diagnosed SCC during 12-mo study period, N (%) | CG | 668 | NR | 4 (0.60) | NR
Youl 2015^188, 192^ Good | Adults age 18-42 | IG1: Tailored text messages promoting sun protection (21) IG2: Tailored text messages promoting SSE (21) | 12 | Sunburn | Any sunburn in past 12 mo, N (%) | IG1 | 173 | 151 (80.7) | 121 (69.9) | IG1: OR 0.87 (95% CI 0.54, 1.40); p=0.962 IG2: OR 0.95 (95% CI 0.59, 1.55); p=0.800
Youl 2015^188, 192^ Good | Adults age 18-42 | IG1: Tailored text messages promoting sun protection (21) IG2: Tailored text messages promoting SSE (21) | 12 | Sunburn | Any sunburn in past 12 mo, N (%) | IG2 | 163 | 147 (83.5) | 117 (71.8) | IG1: OR 0.87 (95% CI 0.54, 1.40); p=0.962 IG2: OR 0.95 (95% CI 0.59, 1.55); p=0.800
Youl 2015^188, 192^ Good | Adults age 18-42 | IG1: Tailored text messages promoting sun protection (21) IG2: Tailored text messages promoting SSE (21) | 12 | Sunburn | Any sunburn in past 12 mo, N (%) | CG | 165 | 152 (83.1) | 120 (72.7) | IG1: OR 0.87 (95% CI 0.54, 1.40); p=0.962 IG2: OR 0.95 (95% CI 0.59, 1.55); p=0.800
Youl 2015^188, 192^ Good | Adults age 18-42 | IG1: Tailored text messages promoting sun protection (21) IG2: Tailored text messages promoting SSE (21) | 12 | Sunburn | 2 or more sunburns in past 12 mo, N (%) | IG1 | 173 | 102 (54.5) | 60 (34.7) | IG1: OR 0.82 (95% CI 0.53, 1.27); p=0.377 IG2: OR 1.20 (95% CI 0.66, 1.59); p=0.478
Youl 2015^188, 192^ Good | Adults age 18-42 | IG1: Tailored text messages promoting sun protection (21) IG2: Tailored text messages promoting SSE (21) | 12 | Sunburn | 2 or more sunburns in past 12 mo, N (%) | IG2 | 163 | 107 (60.8) | 65 (39.9) | IG1: OR 0.82 (95% CI 0.53, 1.27); p=0.377 IG2: OR 1.20 (95% CI 0.66, 1.59); p=0.478
Youl 2015^188, 192^ Good | Adults age 18-42 | IG1: Tailored text messages promoting sun protection (21) IG2: Tailored text messages promoting SSE (21) | 12 | Sunburn | 2 or more sunburns in past 12 mo, N (%) | CG | 165 | 102 (55.7) | 65 (39.4) | IG1: OR 0.82 (95% CI 0.53, 1.27); p=0.377 IG2: OR 1.20 (95% CI 0.66, 1.59); p=0.478

a Adjusted for location, risk level, age, and gender.

b Adjusted for location, risk level.

c After adjusting for social norms, treatment effect was nonsignificant for sunburns (p=0.065). Without adjustment for social norms, treatment effect was significant for sunburn (p=0.03).

d Adjusted for age, sex, education level.

Abbreviations: KQ=key question, SSE=skin self-exam, mo=month, SE=standard error, IG=intervention group, CG=control group, NR=not reported, SD=standard deviation, CG1=control group 1, CG2=control group 2, BCC=basal cell carcinoma, SCC=squamous cell carcinoma, IG1=intervention group 1, IG2=intervention group 2, OR=odds ratio.

None of the trials among adults found statistically significant improvements in rates of sunburn following the intervention compared with control conditions.

##### Nevi/Skin Cancer

In the Check It Out trial promoting skin self-exam in adults recruited from primary care (n=1356; Weinstock et al., 2007),^187^ participants were asked to report if they had a skin procedure during the 12-month study period. For those reporting a procedure, patient medical records were examined to identify cancer outcomes, though no detail was provided on any efforts to identify skin cancer in people not reporting a skin procedure. No between-group differences in nevi or skin cancers were reported with few cases in general. In the intervention group (n=688, 55 reporting procedure at 0–6 months, 27 reporting at 6–12 months), one severely atypical nevi, seven basal cell carcinomas, three squamous cell carcinomas, and no melanomas were identified. In the control group (n=668, 24 reporting skin procedure at 0–6 months, 22 at 6–12 months), one severely atypical nevi, three basal cell carcinomas, four squamous cell carcinomas, and one melanoma were identified.

#### KQ2 Do Primary Care-Relevant Counseling Interventions Improve Skin Cancer Prevention Behaviors?

##### Sun Protection

One trial in young adults^178^ and five adult trials^173, 175, 177, 183, 188^ found an intervention effect for sun protection behaviors, all reported as incremental changes in composite scores (Table 8). For example, in the good-quality Project SCAPE family study (Glanz et al., 2013) of mailed tailored materials, parents (n=1301, 68% white) in both intervention and minimal-intervention control groups saw improvements in sun protection behaviors at 4 months. Between-group differences favored the intervention group, but the effect size was small at 0.07 (1–4 scale: from 2.43 to 2.62 in the intervention group, from 2.39 to 2.53 in the control group, p=0.02).^173^ In the Healthy Text study (2015) by Youl and colleagues (n=546, 65% fair skin, mean age 32), one intervention group received tailored sun protection-focused text messages and one received skin self-exam messages over 12 months; a control group received physical activity messages over the same time period. Both the sun protection message group and the skin self-exam-message group reported significant improvements in sun protection behaviors from baseline to 12-month followup compared to the attention-control group (1–4 scale where 2 is “sometimes” and 3 is “often”: from 2.50 to 2.63 for sun protection group, p=0.032; from 2.50 to 2.63 for the skin self-exam group, p=0.05; from 2.46 to 2.50 in control group).^188, 192^

Table 8 Association Between Counseling Interventions and Skin Cancer Prevention Behaviors (KQ2): Adults and Young Adults^a^

Study | Population | Intervention (number of sessions/mailings) | Followup (months) | Outcome | Question/instrument | Group | Followup N | Baseline | Followup | Between group difference
Geller 2006^174^ Fair | Adult (age ≥18) siblings of melanoma patients | Health educator phone counseling (4); mailed print materials (3) promoting sun protection and SSE | 12 | Sunscreen | Routinely use SPF 15+, N (%) | IG | 149 | 132 (55.9) | 100 (67.4) | OR 0.96 (95% CI 0.67, 1.38); p value NR^b^
Geller 2006^174^ Fair | Adult (age ≥18) siblings of melanoma patients | Health educator phone counseling (4); mailed print materials (3) promoting sun protection and SSE | 12 | Sunscreen | Routinely use SPF 15+, N (%) | CG | 165 | 145 (56.6) | 109 (66.1) | OR 0.96 (95% CI 0.67, 1.38); p value NR^b^
Geller 2006^174^ Fair | Adult (age ≥18) siblings of melanoma patients | Health educator phone counseling (4); mailed print materials (3) promoting sun protection and SSE | 12 | Tanning (outdoor) | Tanned by end of last summer, N (%) | IG | 149 | 99 (41.7) | 38 (25.7) | OR 0.72 (95% CI 0.47, 1.09); p value NR^b^
Geller 2006^174^ Fair | Adult (age ≥18) siblings of melanoma patients | Health educator phone counseling (4); mailed print materials (3) promoting sun protection and SSE | 12 | Tanning (outdoor) | Tanned by end of last summer, N (%) | CG | 165 | 96 (37.2) | 59 (35.6) | OR 0.72 (95% CI 0.47, 1.09); p value NR^b^
Geller 2006^174^ Fair | Adult (age ≥18) siblings of melanoma patients | Health educator phone counseling (4); mailed print materials (3) promoting sun protection and SSE | 12 | SSE | Comprehensive mole examination, past 6 mo, N (%) | IG | 149 | 143 (60.4) | 132 (88.5) | OR 1.76 (95% CI 1.06, 2.91); p value NR^b^
Geller 2006^174^ Fair | Adult (age ≥18) siblings of melanoma patients | Health educator phone counseling (4); mailed print materials (3) promoting sun protection and SSE | 12 | SSE | Comprehensive mole examination, past 6 mo, N (%) | CG | 165 | 166 (64.5) | 138 (83.5) | OR 1.76 (95% CI 1.06, 2.91); p value NR^b^
Geller 2006^174^ Fair | Adult (age ≥18) siblings of melanoma patients | Health educator phone counseling (4); mailed print materials (3) promoting sun protection and SSE | 12 | SSE | Ask a family member to check a mole, past 6 mo, N (%) | IG | 149 | 108 (45.5) | 105 (70.8) | OR 0.97 (95% CI 0.63, 1.50); p value NR^b^
Geller 2006^174^ Fair | Adult (age ≥18) siblings of melanoma patients | Health educator phone counseling (4); mailed print materials (3) promoting sun protection and SSE | 12 | SSE | Ask a family member to check a mole, past 6 mo, N (%) | CG | 165 | 113 (44.0) | 114 (69.1) | OR 0.97 (95% CI 0.63, 1.50); p value NR^b^
Geller 2006^174^ Fair | Adult (age ≥18) siblings of melanoma patients | Health educator phone counseling (4); mailed print materials (3) promoting sun protection and SSE | 12 | SSE | Compare all moles, past 6 mo, N (%) | IG | 149 | 135 (57.1) | 134 (89.7) | OR 2.20 (95% CI 1.22, 3.98); p value NR^b^
Geller 2006^174^ Fair | Adult (age ≥18) siblings of melanoma patients | Health educator phone counseling (4); mailed print materials (3) promoting sun protection and SSE | 12 | SSE | Compare all moles, past 6 mo, N (%) | CG | 165 | 158 (61.5) | 137 (83.0) | OR 2.20 (95% CI 1.22, 3.98); p value NR^b^
Geller 2006^174^ Fair | Adult (age ≥18) siblings of melanoma patients | Health educator phone counseling (4); mailed print materials (3) promoting sun protection and SSE | 12 | SSE | Use picture to assist with mole examination, past 6 mo N (%) | IG | 149 | 35 (14.7) | 65 (43.5) | OR 1.57 (95% CI 0.89, 2.75); p value NR^b^
Geller 2006^174^ Fair | Adult (age ≥18) siblings of melanoma patients | Health educator phone counseling (4); mailed print materials (3) promoting sun protection and SSE | 12 | SSE | Use picture to assist with mole examination, past 6 mo N (%) | CG | 165 | 24 (9.5) | 34 (20.5) | OR 1.57 (95% CI 0.89, 2.75); p value NR^b^
Glanz 2010^175^ Fair | Adults age 20-65 at increased skin cancer risk | Tailored mailings (3) promoting sun protection and SSE; SSE aids | 4 | Sun protection | Scale: 6 behaviors past 3 mo, 1 rarely/never to 4 always, mean (SE)^c^ | IG | 307 | 2.34 (0.03)^d^ | 2.57 (0.03)^d^ | Effect size: 0.13, p=0.001^d e^
Glanz 2010^175^ Fair | Adults age 20-65 at increased skin cancer risk | Tailored mailings (3) promoting sun protection and SSE; SSE aids | 4 | Sun protection | Scale: 6 behaviors past 3 mo, 1 rarely/never to 4 always, mean (SE)^c^ | CG | 289 | 2.34 (0.03)^d^ | 2.46 (0.03)^d^ | Effect size: 0.13, p=0.001^d e^
Glanz 2010^175^ Fair | Adults age 20-65 at increased skin cancer risk | Tailored mailings (3) promoting sun protection and SSE; SSE aids | 4 | Sunscreen | Use 10am-4pm, 1 (rarely) to 4 (always), mean (SE) | IG | 307 | 2.54 (0.06)^f^ | 2.78 (0.06)^f^ | p=0.57^f^
Glanz 2010^175^ Fair | Adults age 20-65 at increased skin cancer risk | Tailored mailings (3) promoting sun protection and SSE; SSE aids | 4 | Sunscreen | Use 10am-4pm, 1 (rarely) to 4 (always), mean (SE) | CG | 289 | 2.63 (0.06)^f^ | 2.84 (0.06)^f^ | p=0.57^f^
Glanz 2010^175^ Fair | Adults age 20-65 at increased skin cancer risk | Tailored mailings (3) promoting sun protection and SSE; SSE aids | 4 | Time in sun | <1 hour to 6 hours per day, 10am-4pm, weekends or weekday, past 3 mo, mean (SE) | IG | 307 | 2.55 (0.07)^f^ | 2.22 (0.07)^f^ | p=0.35^f^
Glanz 2010^175^ Fair | Adults age 20-65 at increased skin cancer risk | Tailored mailings (3) promoting sun protection and SSE; SSE aids | 4 | Time in sun | <1 hour to 6 hours per day, 10am-4pm, weekends or weekday, past 3 mo, mean (SE) | CG | 289 | 2.60 (0.08)^f^ | 2.34 (0.08)^f^ | p=0.35^f^
Glanz 2010^175^ Fair | Adults age 20-65 at increased skin cancer risk | Tailored mailings (3) promoting sun protection and SSE; SSE aids | 4 | SSE | Total body SSE, past 3 mo, adjusted % (SE) | IG | 307 | 39.0 (3.0)^g^ | 71.0 (3.0)^g^ | p=0.004; Total effect size=0.21^g^; High-risk effect size=0.39
Glanz 2010^175^ Fair | Adults age 20-65 at increased skin cancer risk | Tailored mailings (3) promoting sun protection and SSE; SSE aids | 4 | SSE | Total body SSE, past 3 mo, adjusted % (SE) | CG | 289 | 43.0 (3.0)^g^ | 61.0 (3.0)^g^ | p=0.004; Total effect size=0.21^g^; High-risk effect size=0.39
Glanz 2013^173^ Good | Parents of children age 4-10 | Tailored mailings (3) for parents promoting family sun protection | 4 | Sun protection | Scale: 5 behaviors past 3 mo, 1 rarely/never to 4 always, mean (SE)^h^ | IG | 517 | 2.43 (0.02) | 2.62 (0.02) | Effect size 0.07; p=0.02^i^
Glanz 2013^173^ Good | Parents of children age 4-10 | Tailored mailings (3) for parents promoting family sun protection | 4 | Sun protection | Scale: 5 behaviors past 3 mo, 1 rarely/never to 4 always, mean (SE)^h^ | CG | 530 | 2.39 (0.02) | 2.53 (0.02) | Effect size 0.07; p=0.02^i^
Glanz 2013^173^ Good | Parents of children age 4-10 | Tailored mailings (3) for parents promoting family sun protection | 4 | Sunscreen | Use 10am-4pm, 1 (rarely) to 4 (always), mean (SE) | IG | 517 | 2.83 (0.04) | 3.06 (0.04) | Effect size 0.06; p=0.04
Glanz 2013^173^ Good | Parents of children age 4-10 | Tailored mailings (3) for parents promoting family sun protection | 4 | Sunscreen | Use 10am-4pm, 1 (rarely) to 4 (always), mean (SE) | CG | 530 | 2.81 (0.04) | 2.94 (0.04) | Effect size 0.06; p=0.04
Glanz 2013^173^ Good | Parents of children age 4-10 | Tailored mailings (3) for parents promoting family sun protection | 4 | Time in sun | Hours spent in sun per day, <1 to 6 per day, 10am-4pm, weekends or weekday, mean (SE) | IG | 517 | 2.80 (0.05) | 2.46 (0.05) | Effect size NR; p=0.29
Glanz 2013^173^ Good | Parents of children age 4-10 | Tailored mailings (3) for parents promoting family sun protection | 4 | Time in sun | Hours spent in sun per day, <1 to 6 per day, 10am-4pm, weekends or weekday, mean (SE) | CG | 530 | 2.83 (0.05) | 2.43 (0.05) | Effect size NR; p=0.29
Glanz 2013^173^ Good | Parents of children age 4-10 | Tailored mailings (3) for parents promoting family sun protection | 4 | SSE | SSE (total/partial not specified), past 3 mo, adjusted % (SE) | IG | 517 | 54.0 (0.33) | 79.0 (0.07) | Effect size 0.14; p=0.03^j^
Glanz 2013^173^ Good | Parents of children age 4-10 | Tailored mailings (3) for parents promoting family sun protection | 4 | SSE | SSE (total/partial not specified), past 3 mo, adjusted % (SE) | CG | 530 | 52.0 (0.60) | 71.0 (0.08) | Effect size 0.14; p=0.03^j^
Glanz 2015^176^ Fair | Adults (age range 18-91) at increased skin cancer risk | Tailored mailings (3) on risk reduction, skin self-exam, clinical skin exam, and sunscreen | 3 | Sun protection | Scale: 6 behaviors past 3 mo, 1 rarely/never to 4 always, mean (SD)^c^ | IG | 83 | 2.53 (0.59) | 2.78 (0.53) | p value NR, NS^k^
Glanz 2015^176^ Fair | Adults (age range 18-91) at increased skin cancer risk | Tailored mailings (3) on risk reduction, skin self-exam, clinical skin exam, and sunscreen | 3 | Sun protection | Scale: 6 behaviors past 3 mo, 1 rarely/never to 4 always, mean (SD)^c^ | CG | 109 | 2.64 (0.62) | 2.76 (0.58) | p value NR, NS^k^
Glanz 2015^176^ Fair | Adults (age range 18-91) at increased skin cancer risk | Tailored mailings (3) on risk reduction, skin self-exam, clinical skin exam, and sunscreen | 3 | Sunscreen | Use 10am-4pm, 1 (rarely) to 4 (always), mean (SD) | IG | 83 | 2.60 (1.04) | 2.95 (0.92) | p value NR, NS^k^
Glanz 2015^176^ Fair | Adults (age range 18-91) at increased skin cancer risk | Tailored mailings (3) on risk reduction, skin self-exam, clinical skin exam, and sunscreen | 3 | Sunscreen | Use 10am-4pm, 1 (rarely) to 4 (always), mean (SD) | CG | 109 | 2.90 (1.02) | 3.15 (0.86) | p value NR, NS^k^
Glanz 2015^176^ Fair | Adults (age range 18-91) at increased skin cancer risk | Tailored mailings (3) on risk reduction, skin self-exam, clinical skin exam, and sunscreen | 3 | Time in sun | Hours spent in sun per day, 1 to 6 per day, 10am-4pm, previous summer, weekends, mean (SD) | IG | 83 | 2.73 (1.72) | 2.51 (1.64) | p=0.68^l^
Glanz 2015^176^ Fair | Adults (age range 18-91) at increased skin cancer risk | Tailored mailings (3) on risk reduction, skin self-exam, clinical skin exam, and sunscreen | 3 | Time in sun | Hours spent in sun per day, 1 to 6 per day, 10am-4pm, previous summer, weekends, mean (SD) | CG | 109 | 2.67 (1.61) | 2.50 (1.71) | p=0.68^l^
Glanz 2015^176^ Fair | Adults (age range 18-91) at increased skin cancer risk | Tailored mailings (3) on risk reduction, skin self-exam, clinical skin exam, and sunscreen | 3 | Time in sun | Hours spent in sun per day, 1 to 6 per day, 10am-4pm, previous summer, weekdays, mean (SD) | IG | 83 | 1.28 (1.26) | 1.43 (1.43) | p=0.27^l^
Glanz 2015^176^ Fair | Adults (age range 18-91) at increased skin cancer risk | Tailored mailings (3) on risk reduction, skin self-exam, clinical skin exam, and sunscreen | 3 | Time in sun | Hours spent in sun per day, 1 to 6 per day, 10am-4pm, previous summer, weekdays, mean (SD) | CG | 109 | 1.64 (1.58) | 1.57 (1.41) | p=0.27^l^
Glanz 2015^176^ Fair | Adults (age range 18-91) at increased skin cancer risk | Tailored mailings (3) on risk reduction, skin self-exam, clinical skin exam, and sunscreen | 3 | SSE | Scale: Recency of last SSE, 1 (never) to 4 (within the last mo), mean score (SD) | IG | 83 | 2.39 (1.26) | 3.06 (1.15) | p=0.051^k^
Glanz 2015^176^ Fair | Adults (age range 18-91) at increased skin cancer risk | Tailored mailings (3) on risk reduction, skin self-exam, clinical skin exam, and sunscreen | 3 | SSE | Scale: Recency of last SSE, 1 (never) to 4 (within the last mo), mean score (SD) | CG | 109 | 2.62 (1.32) | 2.98 (1.19) | p=0.051^k^
Glazebrook 2006^177^ Fair | Adults with ≥1 melanoma risk factor | Interactive online program (1) with tailored feedback promoting sun protection and SSE | 6 | Sun protection | Scale: 1 to 8 behaviors, past 6 mo, mean (SD)^m^ | IG | 258 | 4.60 (1.82) | 5.36 (1.72)^n^ | Effect size 0.18; Mean difference 0.30 (95% CI 0.10, 0.51)^n^; p=0.004 (ITT analysis)^o^
Glazebrook 2006^177^ Fair | Adults with ≥1 melanoma risk factor | Interactive online program (1) with tailored feedback promoting sun protection and SSE | 6 | Sun protection | Scale: 1 to 8 behaviors, past 6 mo, mean (SD)^m^ | CG | 325 | 4.66 (1.55) | 5.06 (1.59)^n^ | Effect size 0.18; Mean difference 0.30 (95% CI 0.10, 0.51)^n^; p=0.004 (ITT analysis)^o^
Glazebrook 2006^177^ Fair | Adults with ≥1 melanoma risk factor | Interactive online program (1) with tailored feedback promoting sun protection and SSE | 6 | SSE | Check moles, past 6 mo, N (%) | IG | 259 | 159 (61.9) | 209 (80.7)^n^ | OR 1.67 (95% CI 1.04, 2.7)^n^; p=0.035 (ITT analysis)^o^
Glazebrook 2006^177^ Fair | Adults with ≥1 melanoma risk factor | Interactive online program (1) with tailored feedback promoting sun protection and SSE | 6 | SSE | Check moles, past 6 mo, N (%) | CG | 328 | 215 (65.7) | 243 (74.1)^n^ | OR 1.67 (95% CI 1.04, 2.7)^n^; p=0.035 (ITT analysis)^o^
Heckman 2016^178^ Fair | Young adults age 18-25 at increased skin cancer risk | IG1: Tailored interactive web program (12 modules) IG2: Public website | 3 | Sun protection | Scale: 5 UV exposure behaviors, past mo,1 (never) to 5 (always), mean (SD)^p^ | IG1 | 195 | 1.44 (0.80) | 0.89 (0.73) | IG1: Cohen D effect size IG1 vs CG: 0.43; treatment effect at followup vs CG: -0.30 (SE 0.07, p<0.001) IG2: Treatment effect at followup IG2 vs CG: -0.034, p=0.609 (multinomial logistic regression including time)
Heckman 2016^178^ Fair | Young adults age 18-25 at increased skin cancer risk | IG1: Tailored interactive web program (12 modules) IG2: Public website | 3 | Sun protection | Scale: 5 UV exposure behaviors, past mo,1 (never) to 5 (always), mean (SD)^p^ | IG2 | 205 | 1.50 (0.79) | 1.19 (0.70)
Heckman 2016^178^ Fair | Young adults age 18-25 at increased skin cancer risk | IG1: Tailored interactive web program (12 modules) IG2: Public website | 3 | Sun protection | Scale: 5 UV exposure behaviors, past mo,1 (never) to 5 (always), mean (SD)^p^ | CG | 229 | 1.49 (0.80) | 1.21 (0.73)
Heckman 2016^178^ Fair | Young adults age 18-25 at increased skin cancer risk | IG1: Tailored interactive web program (12 modules) IG2: Public website | 3 | Sun protection | Scale: 7 protection behaviors; 1 (never) to 5 (always), mean (SD)^q^ | IG1 | 195 | 1.94 (0.81) | 2.64 (0.89) | IG1: Cohen D effect size IG1 vs CG: 0.53; Treatment effect at followup: 0.429 (SE 0.090, p<0.001) (multinomial logistic regression including time) IG2: Treatment effect at followup IG2 vs CG: -0.024, SE 0.083, p=0.773 (multinomial logistic regression including time)
Heckman 2016^178^ Fair | Young adults age 18-25 at increased skin cancer risk | IG1: Tailored interactive web program (12 modules) IG2: Public website | 3 | Sun protection | Scale: 7 protection behaviors; 1 (never) to 5 (always), mean (SD)^q^ | IG2 | 205 | 1.83 (0.81) | 2.17 (0.84)
Heckman 2016^178^ Fair | Young adults age 18-25 at increased skin cancer risk | IG1: Tailored interactive web program (12 modules) IG2: Public website | 3 | Sun protection | Scale: 7 protection behaviors; 1 (never) to 5 (always), mean (SD)^q^ | CG | 229 | 1.95 (0.77) | 2.17 (0.87)
Heckman 2016^178^ Fair | Young adults age 18-25 at increased skin cancer risk | IG1: Tailored interactive web program (12 modules) IG2: Public website | 3 | Sunscreen | SPF 15+, past mo, N (%) | IG1 | 195 | 143 (49.8) | 162 (83.1) | IG1: p<0.001 compared to CG at baseline IG2: p=0.019 compared to CG at baseline
Heckman 2016^178^ Fair | Young adults age 18-25 at increased skin cancer risk | IG1: Tailored interactive web program (12 modules) IG2: Public website | 3 | Sunscreen | SPF 15+, past mo, N (%) | IG2 | 205 | 164 (48.5) | 156 (76.1) | IG1: p<0.001 compared to CG at baseline IG2: p=0.019 compared to CG at baseline
Heckman 2016^178^ Fair | Young adults age 18-25 at increased skin cancer risk | IG1: Tailored interactive web program (12 modules) IG2: Public website | 3 | Sunscreen | SPF 15+, past mo, N (%) | CG | 229 | 187 (55.0) | 161 (70.3) | IG1: p<0.001 compared to CG at baseline IG2: p=0.019 compared to CG at baseline
Heckman 2016^178^ Fair | Young adults age 18-25 at increased skin cancer risk | IG1: Tailored interactive web program (12 modules) IG2: Public website | 3 | Tanning (outdoor) | Did not engage in 1-4 hours/week of intentional UV exposure in past mo, N (%) | IG1 | 195 | 212 (74.1) | 175 (90.7) | IG1: p=0.002 IG2: p value NR; NS
Heckman 2016^178^ Fair | Young adults age 18-25 at increased skin cancer risk | IG1: Tailored interactive web program (12 modules) IG2: Public website | 3 | Tanning (outdoor) | Did not engage in 1-4 hours/week of intentional UV exposure in past mo, N (%) | IG2 | 205 | 254 (75.4) | 163 (80.3) | IG1: p=0.002 IG2: p value NR; NS
Heckman 2016^178^ Fair | Young adults age 18-25 at increased skin cancer risk | IG1: Tailored interactive web program (12 modules) IG2: Public website | 3 | Tanning (outdoor) | Did not engage in 1-4 hours/week of intentional UV exposure in past mo, N (%) | CG | 229 | 265 (78.2) | 186 (81.6) | IG1: p=0.002 IG2: p value NR; NS
Heckman 2016^178^ Fair | Young adults age 18-25 at increased skin cancer risk | IG1: Tailored interactive web program (12 modules) IG2: Public website | 3 | Indoor tanning | IT in past mo, N (%) | IG1 | 195 | 26 (9.1) | 8 (4.1) | IG1: p value NR; NS IG2: p value NR; NS
Heckman 2016^178^ Fair | Young adults age 18-25 at increased skin cancer risk | IG1: Tailored interactive web program (12 modules) IG2: Public website | 3 | Indoor tanning | IT in past mo, N (%) | IG2 | 205 | 31 (9.3) | 12 (5.9) | IG1: p value NR; NS IG2: p value NR; NS
Heckman 2016^178^ Fair | Young adults age 18-25 at increased skin cancer risk | IG1: Tailored interactive web program (12 modules) IG2: Public website | 3 | Indoor tanning | IT in past mo, N (%) | CG | 229 | 30 (8.9) | 17 (7.4) | IG1: p value NR; NS IG2: p value NR; NS
Heckman 2016^178^ Fair | Young adults age 18-25 at increased skin cancer risk | IG1: Tailored interactive web program (12 modules) IG2: Public website | 3 | SSE | Total body SSE, past 3 mo, N (%) | IG1 | 195 | 36 (12.5) | 87 (44.6) | IG1: p=0.003 IG2: p value NR; NS
Heckman 2016^178^ Fair | Young adults age 18-25 at increased skin cancer risk | IG1: Tailored interactive web program (12 modules) IG2: Public website | 3 | SSE | Total body SSE, past 3 mo, N (%) | IG2 | 205 | 48 (14.3) | 48 (23.4) | IG1: p=0.003 IG2: p value NR; NS
Heckman 2016^178^ Fair | Young adults age 18-25 at increased skin cancer risk | IG1: Tailored interactive web program (12 modules) IG2: Public website | 3 | SSE | Total body SSE, past 3 mo, N (%) | CG | 229 | 43 (12.6) | 59 (25.8) | IG1: p=0.003 IG2: p value NR; NS
Hillhouse 2008^179, 193, 194^ Fair | Female university students age 17-21 who use indoor tanning | Standard print materials (1) promoting appearance-based alternatives to indoor tanning | 6 | Indoor tanning | IT sessions in past 3 mo, mean (SE) | IG | 195 | 4.67 (0.60) | 6.8 (0.93) | F statistic 12.42; p<0.001^r^
Hillhouse 2008^179, 193, 194^ Fair | Female university students age 17-21 who use indoor tanning | Standard print materials (1) promoting appearance-based alternatives to indoor tanning | 6 | Indoor tanning | IT sessions in past 3 mo, mean (SE) | CG | 217 | 4.48 (0.55) | 10.9 (0.93) | F statistic 12.42; p<0.001^r^
Janda 2011^180, 195^ Fair | Adult men age 50-90 | Standard mailing (1) promoting SSE (video, SSE aids; print materials); reminder postcards | 13 | SSE | Partial SSE, past 6 mo, N (%) | IG | 420 | 222 (47.3) | 298 (71.0) | OR 1.16 (95% CI 0.86, 1.56) p<0.001 (group x time effect)
Janda 2011^180, 195^ Fair | Adult men age 50-90 | Standard mailing (1) promoting SSE (video, SSE aids; print materials); reminder postcards | 13 | SSE | Partial SSE, past 6 mo, N (%) | CG | 411 | 218 (47.4) | 279 (67.8) | OR 1.16 (95% CI 0.86, 1.56) p<0.001 (group x time effect)
Janda 2011^180, 195^ Fair | Adult men age 50-90 | Standard mailing (1) promoting SSE (video, SSE aids; print materials); reminder postcards | 13 | SSE | Total SSE, past 6 mo, N (%)^s^ | IG | 420 | 53 (11.4) | 153 (36.4) | OR 1.29 (95% CI 0.97, 1.72) p=0.85 (group x time effect)
Janda 2011^180, 195^ Fair | Adult men age 50-90 | Standard mailing (1) promoting SSE (video, SSE aids; print materials); reminder postcards | 13 | SSE | Total SSE, past 6 mo, N (%)^s^ | CG | 411 | 48 (10.4) | 126 (30.7) | OR 1.29 (95% CI 0.97, 1.72) p=0.85 (group x time effect)
Mahler 2007^181^ Fair | Adult university students age 18-44 | Facial photos of participant with simulated sun damage (1); appearance-focused video promoting sun protection (1) | 12 | Sun protection | (see results in text) | | NR | NR | NR | (see results in text)
Manne 2010^182^ Fair | Adult (age ≥20) FDRs of melanoma patients | Tailored mailings (3) promoting sun protection and SSE; phone counseling (1) | 12 | Sun protection | Scale: 5 behaviors, last 6 mo, 1 (never) to 5 (always), mean (SD)^t^ | IG | 161 | 2.8 (0.66) | 3.4 (0.79) | NS on multivariable analysis including intentions, perceived barriers and benefits, and self-efficacy [unadjusted p=0.0475]
Manne 2010^182^ Fair | Adult (age ≥20) FDRs of melanoma patients | Tailored mailings (3) promoting sun protection and SSE; phone counseling (1) | 12 | Sun protection | Scale: 5 behaviors, last 6 mo, 1 (never) to 5 (always), mean (SD)^t^ | CG | 161 | 2.8 (0.65) | 3.2 (0.73) | NS on multivariable analysis including intentions, perceived barriers and benefits, and self-efficacy [unadjusted p=0.0475]
Manne 2010^182^ Fair | Adult (age ≥20) FDRs of melanoma patients | Tailored mailings (3) promoting sun protection and SSE; phone counseling (1) | 12 | SSE | Number of times engaging in SSE in past year or since previous assessment, mean (SD) | IG | 193 | 0.42 (0.86) | 8.8 (34.9) | p=0.10 for main effect adjusted for proband being diagnosed at a younger age
Manne 2010^182^ Fair | Adult (age ≥20) FDRs of melanoma patients | Tailored mailings (3) promoting sun protection and SSE; phone counseling (1) | 12 | SSE | Number of times engaging in SSE in past year or since previous assessment, mean (SD) | CG | 161 | 0.34 (0.80) | 6.2 (24.4) | p=0.10 for main effect adjusted for proband being diagnosed at a younger age
Prochaska 2004^184^ Fair | Adults | Tailored mailings (3) promoting sun protection | 24 | Sun protection | Scale: sun avoidance, no. of items and time frame NR, mean (SD)^u^ | IG | 864 | 12.65 (3.86) | 13.99 (3.39) | NS (p>0.05)^v^
Prochaska 2004^184^ Fair | Adults | Tailored mailings (3) promoting sun protection | 24 | Sun protection | Scale: sun avoidance, no. of items and time frame NR, mean (SD)^u^ | CG | 920 | 12.60 (3.90) | 13.35 (3.73) | NS (p>0.05)^v^
Prochaska 2004^184^ Fair | Adults | Tailored mailings (3) promoting sun protection | 24 | Sunscreen | Scale: sunscreen use, no. of items and time frame NR, mean (SD)^u^ | IG | 864 | 8.3 (4.00) | 10.2 (3.94) | p<0.05
Prochaska 2004^184^ Fair | Adults | Tailored mailings (3) promoting sun protection | 24 | Sunscreen | Scale: sunscreen use, no. of items and time frame NR, mean (SD)^u^ | CG | 917 | 8.2 (3.99) | 9.2 (3.82) | p<0.05
Prochaska 2005^183^ Fair | Adults | Tailored mailings (3) promoting sun protection | 24 | Sun protection | Scale: sun avoidance, no. of items and time frame NR, mean (SD)^u^ | IG | 1822 | 12.7 (3.6) | 13.7 (3.5) | p<0.005^w^
Prochaska 2005^183^ Fair | Adults | Tailored mailings (3) promoting sun protection | 24 | Sun protection | Scale: sun avoidance, no. of items and time frame NR, mean (SD)^u^ | CG | 2012 | 12.4 (3.7) | 12.9 (3.6) | p<0.005^w^
Prochaska 2005^183^ Fair | Adults | Tailored mailings (3) promoting sun protection | 24 | Sunscreen | Scale: sunscreen use, no. of items and time frame NR, mean (SD)^u^ | IG | 1822 | 8.6 (3.9) | 10.0 (3.9) | p<0.0001
Prochaska 2005^183^ Fair | Adults | Tailored mailings (3) promoting sun protection | 24 | Sunscreen | Scale: sunscreen use, no. of items and time frame NR, mean (SD)^u^ | CG | 2012 | 8.5 (3.9) | 9.2 (3.9) | p<0.0001
Rat 2014^185^ Fair | Adults at increased melanoma risk | PCP counseling using tailored feedback (1) | 5 | Sun protection | Took protective actions during most recent exposure, N (%) | IG | 97 | NR | 65 (67.0) | p=0.06^x^
Rat 2014^185^ Fair | Adults at increased melanoma risk | PCP counseling using tailored feedback (1) | 5 | Sun protection | Took protective actions during most recent exposure, N (%) | CG | 76 | NR | 42 (55.3) | p=0.06^x^
Rat 2014^185^ Fair | Adults at increased melanoma risk | PCP counseling using tailored feedback (1) | 5 | Tanning (outdoor) | Sunbathed in past year, N (%) | IG | 97 | NR | 24 (24.7) | p=0.040^x^
Rat 2014^185^ Fair | Adults at increased melanoma risk | PCP counseling using tailored feedback (1) | 5 | Tanning (outdoor) | Sunbathed in past year, N (%) | CG | 76 | NR | 31 (40.8) | p=0.040^x^
Rat 2014^185^ Fair | Adults at increased melanoma risk | PCP counseling using tailored feedback (1) | 5 | Indoor tanning | Use of tanning beds, N (%) | IG | 97 | NR | 10 (10.3) | p=0.069^x^
Rat 2014^185^ Fair | Adults at increased melanoma risk | PCP counseling using tailored feedback (1) | 5 | Indoor tanning | Use of tanning beds, N (%) | CG | 76 | NR | 5 (6.6) | p=0.069^x^
Rat 2014^185^ Fair | Adults at increased melanoma risk | PCP counseling using tailored feedback (1) | 5 | SSE | SSE (total/partial not specified), past 12 mo, N (%) | IG | 97 | NR | 51 (52.6) | p=0.02^x^
Rat 2014^185^ Fair | Adults at increased melanoma risk | PCP counseling using tailored feedback (1) | 5 | SSE | SSE (total/partial not specified), past 12 mo, N (%) | CG | 76 | NR | 28 (36.8) | p=0.02^x^
Vuong 2014^186^ Fair | Adults age ≥18 | PCP counseling using tailored feedback; print materials (1) | 13 | Sun protection | Scale: 7 behaviors, usual practice, possible range 5 (low) to 25 (high), mean (SE)^y^ | IG | 37 | 16.70 (0.57) | 16.64 (0.35) | Mean difference 0.26 (95% CI -0.78, 1.29); p=0.63
Vuong 2014^186^ Fair | Adults age ≥18 | PCP counseling using tailored feedback; print materials (1) | 13 | Sun protection | Scale: 7 behaviors, usual practice, possible range 5 (low) to 25 (high), mean (SE)^y^ | CG | 34 | 14.90 (0.49) | 16.39 (0.37) | Mean difference 0.26 (95% CI -0.78, 1.29); p=0.63
Vuong 2014^186^ Fair | Adults age ≥18 | PCP counseling using tailored feedback; print materials (1) | 13 | Time in sun | Hours spent outdoors per day, mean (SE) | IG | 37 | 2.05 (0.24) | 2.07 (0.22) | Mean difference -0.34 hours (95% CI -0.98, 0.3); p=0.29
Vuong 2014^186^ Fair | Adults age ≥18 | PCP counseling using tailored feedback; print materials (1) | 13 | Time in sun | Hours spent outdoors per day, mean (SE) | CG | 33 | 2.66 (0.28) | 2.41 (0.23) | Mean difference -0.34 hours (95% CI -0.98, 0.3); p=0.29
Weinstock 2007^187^ Fair | Adults age ≥18 | Study team counseling (2); materials promoting SSE (print, video); SSE aids; tailored letter (1) | 12 | SSE | Total body SSE, past 2 mo, N (%) | IG | 530 | 124 (18.0) | 254 (55.0) | Mean difference between groups at 12 mo: 19.3 (95% CI 13.0, 25.7); p<0.0001
Weinstock 2007^187^ Fair | Adults age ≥18 | Study team counseling (2); materials promoting SSE (print, video); SSE aids; tailored letter (1) | 12 | SSE | Total body SSE, past 2 mo, N (%) | CG | 487 | 114 (17.0) | 154 (35.0) | Mean difference between groups at 12 mo: 19.3 (95% CI 13.0, 25.7); p<0.0001
Weinstock 2007^187^ Fair | Adults age ≥18 | Study team counseling (2); materials promoting SSE (print, video); SSE aids; tailored letter (1) | 12 | SSE | Number of areas examined (of 7 total), past 2 mo, mean^z^ | IG | 461 | 2.59 | 5.14 | p<0.0001 difference between groups at 12 mo
Weinstock 2007^187^ Fair | Adults age ≥18 | Study team counseling (2); materials promoting SSE (print, video); SSE aids; tailored letter (1) | 12 | SSE | Number of areas examined (of 7 total), past 2 mo, mean^z^ | CG | 440 | 2.46 | 3.83 | p<0.0001 difference between groups at 12 mo
Youl 2015^188, 192^ Good | Adults age 18-42 | IG1: Tailored text messages promoting sun protection (21) IG2: Tailored text messages promoting SSE (21) | 12 | Sun protection | Scale: 6 behaviors, frequency 10am-3pm, 1 rarely/never to 4 always, mean (SD)^aa^ | IG1 | 178 | 2.50 (0.48) | 2.63 (0.46) | IG1: p=0.032 IG2:p=0.05
Youl 2015^188, 192^ Good | Adults age 18-42 | IG1: Tailored text messages promoting sun protection (21) IG2: Tailored text messages promoting SSE (21) | 12 | Sun protection | Scale: 6 behaviors, frequency 10am-3pm, 1 rarely/never to 4 always, mean (SD)^aa^ | IG2 | 168 | 2.50 (0.55) | 2.63 (0.50) | IG1: p=0.032 IG2:p=0.05
Youl 2015^188, 192^ Good | Adults age 18-42 | IG1: Tailored text messages promoting sun protection (21) IG2: Tailored text messages promoting SSE (21) | 12 | Sun protection | Scale: 6 behaviors, frequency 10am-3pm, 1 rarely/never to 4 always, mean (SD)^aa^ | CG | 166 | 2.46 (0.49) | 2.50 (0.50) | IG1: p=0.032 IG2:p=0.05
Youl 2015^188, 192^ Good | Adults age 18-42 | IG1: Tailored text messages promoting sun protection (21) IG2: Tailored text messages promoting SSE (21) | 12 | Tanning (outdoor) | Attempted suntan in past 12 mo, N (%) | IG1 | 173 | 23 (12.3) | 26 (15.0) | IG1: OR 0.95 (95% CI 0.52, 1.71); p=0.421 IG2: OR 1.21 (95% CI 0.68, 2.15); p=0.030
Youl 2015^188, 192^ Good | Adults age 18-42 | IG1: Tailored text messages promoting sun protection (21) IG2: Tailored text messages promoting SSE (21) | 12 | Tanning (outdoor) | Attempted suntan in past 12 mo, N (%) | IG2 | 163 | 39 (22.2) | 30 (18.4) | IG1: OR 0.95 (95% CI 0.52, 1.71); p=0.421 IG2: OR 1.21 (95% CI 0.68, 2.15); p=0.030
Youl 2015^188, 192^ Good | Adults age 18-42 | IG1: Tailored text messages promoting sun protection (21) IG2: Tailored text messages promoting SSE (21) | 12 | Tanning (outdoor) | Attempted suntan in past 12 mo, N (%) | CG | 165 | 19 (10.4) | 26 (15.8) | IG1: OR 0.95 (95% CI 0.52, 1.71); p=0.421 IG2: OR 1.21 (95% CI 0.68, 2.15); p=0.030
Youl 2015^188, 192^ Good | Adults age 18-42 | IG1: Tailored text messages promoting sun protection (21) IG2: Tailored text messages promoting SSE (21) | 12 | SSE | Any SSE, past 3 mo, N (%) | IG1 | 173 | 64 (34.2) | 83 (48.0) | IG1: OR 1.42 (95% CI 0.92, 2.19); p=0.742 IG2: OR 2.64 (95% CI 1.69, 4.13); p=0.001
Youl 2015^188, 192^ Good | Adults age 18-42 | IG1: Tailored text messages promoting sun protection (21) IG2: Tailored text messages promoting SSE (21) | 12 | SSE | Any SSE, past 3 mo, N (%) | IG2 | 163 | 65 (36.9) | 103 (63.2) | IG1: OR 1.42 (95% CI 0.92, 2.19); p=0.742 IG2: OR 2.64 (95% CI 1.69, 4.13); p=0.001
Youl 2015^188, 192^ Good | Adults age 18-42 | IG1: Tailored text messages promoting sun protection (21) IG2: Tailored text messages promoting SSE (21) | 12 | SSE | Any SSE, past 3 mo, N (%) | CG | 165 | 57 (31.1) | 65 (39.2) | IG1: OR 1.42 (95% CI 0.92, 2.19); p=0.742 IG2: OR 2.64 (95% CI 1.69, 4.13); p=0.001
Youl 2015^188, 192^ Good | Adults age 18-42 | IG1: Tailored text messages promoting sun protection (21) IG2: Tailored text messages promoting SSE (21) | 12 | SSE | Total body SSE at time of last SSE, N (%)^bb^ | IG1 | 173 | 20 (10.7) | 24 (13.9) | IG1: OR 1.32 (95% CI 0.69, 2.53); p=0.741 IG2: OR 1.69 (95% CI 0.90, 3.2); p=0.153
Youl 2015^188, 192^ Good | Adults age 18-42 | IG1: Tailored text messages promoting sun protection (21) IG2: Tailored text messages promoting SSE (21) | 12 | SSE | Total body SSE at time of last SSE, N (%)^bb^ | IG2 | 163 | 30 (17.0) | 28 (17.2) | IG1: OR 1.32 (95% CI 0.69, 2.53); p=0.741 IG2: OR 1.69 (95% CI 0.90, 3.2); p=0.153
Youl 2015^188, 192^ Good | Adults age 18-42 | IG1: Tailored text messages promoting sun protection (21) IG2: Tailored text messages promoting SSE (21) | 12 | SSE | Total body SSE at time of last SSE, N (%)^bb^ | CG | 165 | 15 (8.2) | 18 (10.9) | IG1: OR 1.32 (95% CI 0.69, 2.53); p=0.741 IG2: OR 1.69 (95% CI 0.90, 3.2); p=0.153

a Results for individual sun protection behaviors (e.g., hat use, wearing sunglasses, avoiding mid-day sun, etc.) are not reported separately in this table. Statistically significant individual behaviors favoring the intervention group are noted in footnotes.

b Difference in odds at follow-up for IG vs CG, adjusted for baseline, sibship, longitudinal data, skin color and intention to have dermatologist skin exam.

c Behaviors in this scale: Shirt with sleeves, sunglasses, shade-seeking, sunscreen, avoiding midday sun, hat.

d Adjusted for risk level, age, and gender.

e Statistically significant individual behaviors favoring IG at followup: Hat use and wearing sunglasses.

f Adjusted for location, risk level, age, and gender.

g Adjusted for location, age, and gender.

h Behaviors in this scale: shirt with sleeves, sunglasses, shade-seeking, sunscreen, hat.

i Statistically significant individual behaviors favoring IG at followup: Limiting sun exposure and shade-seeking.

j Adjusted for location and risk level.

k After adjusting for social norms, treatment effect was nonsignificant for overall SPB (p value NR, NS); sunscreen (p value NR, NS); sunglasses (p=0.066) and SSE (p=0.051). Without adjustment for social norms, treatment effect was significant for overall SPB (p=0.03); sunscreen (p=0.03); sunglasses (p=0.01) and SSE (p=0.02).

l Effect of treatment group difference scores, adjusted for age.

m Behaviors in this scale: Shade-seeking, SPF 15+ sunscreen, hat, covering skin, sunburn, sunbathing, skin self-exam, skin exam by others at least every few months. Individual behavior scores NR.

n Adjusted for baseline values and clustering.

o Results similar for as-treated analysis.

p Behaviors in this scale: clothes that expose skin to the sun; unintentional tanning; indoor tanning; use of products to deepen tan; sunbathing.

q Behaviors in this scale^189^: SPF 15+ on face; SPF 15+ on body; shirt; long pants; hat; sunglasses; shade-seeking.

r For a subpopulation of 379 students, mean IT frequency increased in both IG and CG between fall and spring (significance NR). There were more significantly more IT abstainers in IG than CG in December and January (p<0.05).^194^

s Defined as checking each of 13 specific areas of the body.

t Behaviors in this scale^189^: Sunscreen, hat, shade-seeking, shirt, sunglasses. Individual item results not reported.

u Authors cite Sun Protection Behavior Scale, sun avoidance inventory;^202-204^ individual items not reported.

v Both group and time alone showed significant increases in sun avoidance over time, interaction NS.

w Statistically significant individual behaviors favoring IG at followup: Avoiding mid-day sun.

x Adjusted for age, gender, education level.

y Behaviors in this scale: Sunscreen, hat, shirt, sunglasses, limiting time in sun. Individual behaviors not reported.

z No variance reported (SE/SD NR).

aa Behaviors in this scale^189^: Shirt, sunglasses, hat, sunscreen, shade-seeking, limiting midday sun. Individual behaviors not reported.

bb For Youl 2015, Total SSE includes partner-assisted skin exam.

Abbreviations: KQ=key question, SPF=sun protection factor, IG=intervention group, CG=control group, OR=odds ratio, NR=not reported, SSE=skin self-exam, mo=month, SE=standard error, SD=standard deviation, UV=ultraviolet, CG1=control group 1, CG2=control group 2, IG1=intervention group 1, IG2=intervention group 2, IT=indoor tanning, NS=non-significant, PCP=primary care provider.

Interventions showing no effect on composite sun protection scores included a single session appearance-focused intervention with university students;^181^ the two trials including a single counseling and risk assessment session with a primary care physician, both conducted outside the U.S.;^185, 186^ a mailed intervention targeting multiple risk behaviors;^184^ and two studies of tailored materials compared to generic materials: one among adult relatives of melanoma survivors^182^ and one among adults at increased skin cancer risk.^176^

Effect sizes were reported inconsistently and were typically small, ranging from 0.07 for mailed materials^173^ to 0.53 for the UV4.me tailored interactive web program (Heckman et al., 2016).^178^ Our calculations of standardized effect sizes included 10 of the 12 studies reporting sun protection behaviors and suggested significant effect sizes for four studies; standardized effect sizes were similarly small, ranging from -0.46 (favoring control group) to 0.57 (favoring the intervention group), between 0.10 and 0.20 for most studies, and suggested a positive effect in only four studies. (Error! Reference source not found.)

Specific sun protection behaviors were reported in half (k=8) of the trials. Sunscreen use was the most commonly reported improved behavior, and increased in four of the seven trials assessing sunscreen use.^173, 178, 183, 184^ However, only one study reported estimates of sunscreen use as the percentage reporting use in the past month (70.3% to 83.1% at followup^178^). The other three used composite measures, and two of the three did not report any information on interpretation beyond direction of effect.^183, 184^ The Project SCAPE family study (Glanz et al., 2013)^173^ found marginal between-group differences at 4 months favoring the intervention group (1–4 scale, 2 is “sometimes,” 3 is “often,” and 4 is “always:” 3.06 in the intervention group and 2.94 in the minimal control group, p=0.04). No intervention effect was observed compared to control conditions for all four adult trials reporting time spent in the sun (n=2339)^173, 175, 176, 186^ (sun protection was reported as improved in intervention versus control groups in two of these studies).^173, 175^ However, three studies found self-reported reductions in intentional outdoor exposure compared to control groups.^178, 185, 188^ Estimates of outdoor tanning practice at followup in efficacious interventions were 15.0 percent^188^ and 24.7 percent;^185^ and 90.7 percent for a measure of avoiding intentional UV exposure.^178^ Other specific behaviors reporting improvement were hat use and sunglasses use (1 study^175^), shade seeking and limiting time in the sun (one study^173^), and avoiding midday sun (1 study^183^).

##### Indoor Tanning

Only one trial showed any indication of effect on indoor tanning rates. In the single-session, appearance-focused study of female university students already using indoor tanning (n=430; Hillhouse et al., 2008), mean indoor tanning sessions increased in both groups at 6 months, but between-group differences favored the intervention group (from 4.67 to 6.8 sessions in the intervention group; from 4.48 to 10.9 sessions in the control group, p<0.001).^179, 193, 194^ The UV4.me trial (Heckman et al., 2016) found no change in the proportion of participants reporting indoor tanning over 3 months, but reported rates were low in both groups (from 9.1% to 4.1% in the intervention group, from 9.3% to 5.9% in the public website group, and from 8.9% to 7.4% in the assessment-only control group, NS).^178^ In the single study reporting indoor tanning outcomes in adults—which involved single-session PCP risk assessment and counseling (n=217; Rat et al, 2014)—there was no difference between the intervention and control groups in use of tanning beds over an unspecified time frame at 5 months (10.3% vs. 6.6%, NS).^185^ However, this study was conducted in southwestern coastal regions of France over 5 months in summer, so low rates of indoor tanning may not be surprising.

##### Skin Self-Exam

Nine trials appeared to increase skin self-exam rates in adult populations over 3- to 13-month followup.^173-175, 177, 178, 180, 185, 187, 188^ Of three interventions with skin self-exam-specific intervention messaging, all three found some effect favoring intervention conditions.^180, 187, 188^ In the Check It Out trial (n=1356; Weinstock et al., 2007), total body skin self-exam increased between baseline and 12-month followup (from 18.0% to 55.0% in the intervention group, from 17.0% to 35.0% in the attention-control group, p<0.0001 at each time point); increases also were noted and sustained at 2 and 6 months. Number of body areas examined also was higher in the intervention group.^187^ In the Healthy Text study (n=546; Youl et al., 2015), any skin self-exam increased more in the skin self-exam-focused text message group over 12-month followup compared to the attention-control group (from 36.9% to 63.2% in the skin self-exam group; OR 2.64, 95% CI 1.69 to 4.13, p=0.001), but total skin self-exam was similar across groups. The Skin Awareness Study (n=930; Janda et al., 2011) promoting skin self-exam in men over age 50 found increases in reported skin self-exam at 6 months in the intervention group compared to the minimal intervention control group, but by 13-month followup, rates of any, partial, and total skin self-exam were similar between groups. However, overall between-group effects for the course of the study remained statistically significant for partial skin self-exam and for any skin self-exam in intervention compared to control conditions.^180, 195^ Among men reporting no history of skin excision at baseline (n=269, 29.0% of population), an intervention effect was observed for any skin self-exam (81.8% vs. 69.5% at 13 months, p=0.028).^180, 195^

Our standardized estimates of odds of skin self-exam in intervention compared to control groups suggested similar, though somewhat more conservative findings. Of the nine studies that could be included, six maintained a significant impact favoring intervention. Odds ratios ranged from 1.16 (95% 1.04, 2.69) for a measure of any skin self-exam over 5 months^185^ to 2.64 (95% CI 1.69 to 4.13) for any skin self-exam in the Healthy Text study promoting skin self-exam (Youl et al., 2015)^188^ (Error! Reference source not found.).

#### KQ3 What Are the Harms of Counseling Interventions for Skin Cancer Prevention?

Two trials, both in adult participants (n=1573), reported potential harms of interventions (Table 9).

Table 9 Harms of Behavioral Counseling for Skin Cancer Prevention (KQ3)

Study | Population | Followup N | Intervention | Followup (months) | Harm | Outcome
Rat 2014^185^ Fair | Adults at increased melanoma risk | 173 | PCP counseling using tailored feedback (1) | 5 | Worry | Greater proportion of patients in the IG worried about developing melanoma (28.9% vs. 18.4%; p=0.16)
Weinstock 2007^187^ Fair | Adults age ≥18 | 901 | Study team counseling (2); materials promoting SSE (print, video); SSE aids; tailored letter (1) | 12 | Number of skin surgeries | At 6 months there was a significant between the number of skin surgeries in the IG compared to the CG (8.0% vs. 3.6%, p=0.0005). There was not a significant difference in the number of skin surgeries between the two groups at 12 months (3.9% vs 3.3%, p=0.5).

Abbreviations: KQ=key question, PCP=primary care provider, IG=intervention group, CG=control group SSE=skin self-exam.

##### Number of Skin Procedures

The Check It Out trial (Weinstock et al., 2007) of counseling plus print materials and skin self-exam aids compared to minimal intervention (n=1356) assessed the number of participants reporting skin procedures (procedures not described) at 6- and 12-months followup. The proportion of participants reporting a procedure was significantly higher in the intervention group compared to the attention-control group at 6 months (p=0.0005): 55 participants (8.0%) in the intervention group compared to 24 participants (3.6%) in the control group. Between 6 and 12 months, the proportion reporting a procedure was similar between groups: 27 people (3.9%) in the intervention group versus 22 people (3.3%) in the control group (NS). As reported in KQ1, similarly few cases of atypical nevi, basal and squamous cell carcinomas, and melanoma were detected in both groups during the study period.^187^

##### Skin Cancer Worry

In the French study of PCP counseling with risk assessment and feedback compared to no intervention (n=217; Rat et al., 2014), a slightly higher proportion of adults in the intervention group versus control group reported worrying about developing melanoma, but this difference was not significant (28.9% vs. 18.4%, p=0.16).^185^

No included trials assessed vitamin D levels or paradoxically increased sun exposure accompanying sun protection behaviors. No studies with physical activity attention-controls suggested reduced physical activity in intervention participants. Of four trials reporting time spent in the sun at followup in intervention compared to control groups, no significant differences were observed.^173, 175, 176, 186^

#### KQ4 What Is the Association Between Skin Self-Examination and Skin Cancer Outcomes?

We found no eligible RCTs, controlled trials or prospective cohort trials that evaluated the impact of skin self-exam on skin cancer or health outcomes. Although the Check It Out trial promoting skin self-exam (Weinstock et al., 2007) reported skin cancer outcomes, the impact was assessed according to intervention group, not according to practice of skin self-exam.^180^ The Skin Awareness trial in men over age 50 (Janda et al., 2011) reported skin cancer outcomes in a followup paper, but was focused on the receipt of clinical skin exam and included 36.3 percent of the study population so was not included here.^196^

#### KQ5 What Are the Harms of Skin Self-Examination?

We found no RCTs, controlled trials, or prospective cohort trials reporting the harms of performing skin-self exam that met our inclusion criteria.