# Evidence Tables

Table D-1 Characteristics of included randomized trials

Table D-2 Characteristics of samples from included randomized trials

Table D-3 Intervention and control components from randomized controlled trials

Table D-4 Clinician administered PTSD scales

Table D-5 Self-administered PTSD scales, remission, and loss of diagnosis

Table D-6 Comorbid conditions, quality of life, impairment, and ability to return to work

Table D-7 Subgroup analysis of included randomized trials: reduction, remission, and loss of diagnosis

Table D-8 Subgroup analysis of included randomized trials: comorbidities, quality of life, and disability

Table D-9 Adverse events/harms reported by included randomized controlled trials

## References for Evidence Tables

1 Akuchekian S, Amanat S. The Comparison of Topiramate and Placebo in the Treatment of Posttraumatic Stress Disorder: A Randomized, Double- Blind Study. Journal of Research in Medical Sciences. 2004;9(5):240-4.
2 Asukai N, Saito A, Tsuruta N, et al. Efficacy of exposure therapy for Japanese patients with posttraumatic stress disorder due to mixed traumatic events: A randomized controlled study. J Trauma Stress. Dec. 2010;23(6):744-50. [pmid: 21171135].
3 Bartzokis G, Lu PH, Turner J, et al. Adjunctive risperidone in the treatment of chronic combat-related posttraumatic stress disorder. Biol Psychiatry. Mar. 1. 2005;57(5):474-9. [pmid: 15737661].
4 Basoglu M, Salcioglu E, Livanou M. A randomized controlled study of single-session behavioural treatment of earthquake-related post-traumatic stress disorder using an earthquake simulator. Psychol Med. Feb. 2007;37(2):203-13. [pmid: 17254365].
5 Becker ME, Hertzberg MA, Moore SD, et al. A placebo-controlled trial of bupropion SR in the treatment of chronic posttraumatic stress disorder. J Clin Psychopharmacol. Apr. 2007;27(2):193-7. [pmid: 17414245].
6 Blanchard EB, Hickling EJ, Devineni T, et al. A controlled evaluation of cognitive behavioural therapy for posttraumatic stress in motor vehicle accident survivors. Behav Res Ther. Jan. 2003;41(1):79-96. [pmid: 12488121].
7 Boden MT, Kimerling R, Jacobs-Lentz J, et al. Seeking Safety treatment for male veterans with a substance use disorder and post-traumatic stress disorder symptomatology. Addiction. Mar. 2012;107(3):578-86. [pmid: 21923756].
8 Brady K, Pearlstein T, Asnis GM, et al. Efficacy and safety of sertraline treatment of posttraumatic stress disorder: a randomized controlled trial. JAMA. Apr. 12. 2000;283(14):1837-44. [pmid: 10770145].
9 Brady KT, Sonne S, Anton RF, et al. Sertraline in the treatment of co-occurring alcohol dependence and posttraumatic stress disorder. Alcohol Clin Exp Res. Mar. 2005;29(3):395-401. [pmid: 15770115].
10 Bryant RA, Moulds ML, Guthrie RM, et al. Imaginal exposure alone and imaginal exposure with cognitive restructuring in treatment of posttraumatic stress disorder. J Consult Clin Psychol. Aug. 2003;71(4):706-12. [pmid: 12924676].
11 Bryant RA, Moulds ML, Guthrie RM, et al. A randomized controlled trial of exposure therapy and cognitive restructuring for posttraumatic stress disorder. J Consult Clin Psychol. Aug. 2008;76(4):695-703. [pmid: 18665697].
12 Butterfield MI, Becker ME, Connor KM, et al. Olanzapine in the treatment of post-traumatic stress disorder: a pilot study. Int Clin Psychopharmacol. Jul. 2001;16(4):197-203. [pmid: 11459333].
13 Carlson JG, Chemtob CM, Rusnak K, et al. Eye movement desensitization and reprocessing (EDMR) treatment for combat-related posttraumatic stress disorder. J Trauma Stress. Jan. 1998;11(1):3-24. [pmid: 9479673].
14 Chard KM. An evaluation of cognitive processing therapy for the treatment of posttraumatic stress disorder related to childhood sexual abuse. J Consult Clin Psychol. Oct. 2005;73(5):965-71. [pmid: 16287396].
15 Cloitre M, Koenen KC, Cohen LR, et al. Skills training in affective and interpersonal regulation followed by exposure: a phase-based treatment for PTSD related to childhood abuse. J Consult Clin Psychol. Oct. 2002;70(5):1067-74. [pmid: 12362957].
16 Cloitre M, Stovall-McClough KC, Nooner K, et al. Treatment for PTSD related to childhood abuse: a randomized controlled trial. Am J Psychiatry. Aug. 2010;167(8):915-24. [pmid: 20595411].
17 Connor KM, Sutherland SM, Tupler LA, et al. Fluoxetine in post-traumatic stress disorder. Randomised, double-blind study. Br J Psychiatry. Jul. 1999;175:17-22. [pmid: 10621763].
18 Meltzer-Brody S, Connor KM, Churchill E, et al. Symptom-specific effects of fluoxetine in post-traumatic stress disorder. Int Clin Psychopharmacol. Jul. 2000;15(4):227-31. [pmid: 10954063].
19 Cook JM, Harb GC, Gehrman PR, et al. Imagery rehearsal for posttraumatic nightmares: a randomized controlled trial. J Trauma Stress. Oct. 2010;23(5):553-63. [pmid: 20839311].
20 Cottraux J, Note I, Yao SN, et al. Randomized controlled comparison of cognitive behavior therapy with Rogerian supportive therapy in chronic post-traumatic stress disorder: a 2-year follow-up. Psychother Psychosom. 2008;77(2):101-10. [pmid: 18230943].
21 Davidson JR, Rothbaum BO, van der Kolk BA, et al. Multicenter, double-blind comparison of sertraline and placebo in the treatment of posttraumatic stress disorder. Arch Gen Psychiatry. May. 2001;58(5):485-92. [pmid: 11343529].
22 Davidson JR, Weisler RH, Butterfield MI, et al. Mirtazapine vs. placebo in posttraumatic stress disorder: a pilot trial. Biol Psychiatry. Jan. 15. 2003;53(2):188-91. [pmid: 12547477].
23 Davidson J, Rothbaum BO, Tucker P, et al. Venlafaxine extended release in posttraumatic stress disorder: a sertraline- and placebo-controlled study. J Clin Psychopharmacol. Jun. 2006;26(3):259-67. [pmid: 16702890].
24 Davidson J, Baldwin D, Stien DJ, et al. Treatment of Posttraumatic Stress Disorder With Venlafaxine Extended Release. Archives of General Psychiatry. 2006;63(10):1158. 2006-13321-012. [pmid: 17015818].
25 Davidson JR, Brady K, Mellman TA, et al. The efficacy and tolerability of tiagabine in adult patients with post-traumatic stress disorder. J Clin Psychopharmacol. Feb. 2007;27(1):85-8. [pmid: 17224720].
26 Davis LL, Davidson JR, Ward LC, et al. Divalproex in the treatment of posttraumatic stress disorder: a randomized, double-blind, placebo-controlled trial in a veteran population. J Clin Psychopharmacol. Feb. 2008;28(1):84-8. [pmid: 18204347].
27 Ehlers A, Clark DM, Hackmann A, et al. A randomized controlled trial of cognitive therapy, a self-help booklet, and repeated assessments as early interventions for posttraumatic stress disorder. Archives of General Psychiatry. 2003;60(10):1024-32. [pmid: 14557148].
28 Ehlers A, Clark DM, Hackmann A, et al. Cognitive therapy for post-traumatic stress disorder: development and evaluation. Behav Res Ther. Apr. 2005;43(4):413-31. [pmid: 15701354].
29 Fecteau G, Nicki R. Cognitive behavioural treatment of post traumatic stress disorder after motor vehicle accident. Behavioural and Cognitive Psychotherapy. 1999;27(3):201-14.
30 Foa EB, Dancu CV, Hembree EA, et al. A comparison of exposure therapy, stress inoculation training, and their combination for reducing posttraumatic stress disorder in female assault victims. J Consult Clin Psychol. Apr. 1999;67(2):194-200. [pmid: 10224729].
31 Zoellner LA, Feeny NC, Fitzgibbons LA, et al. Response of African American and Caucasian women to cognitive behavioral therapy for PTSD. Behavior Therapy. 1999;30(4):581-95.
32 Foa EB, Hembree EA, Cahill SP, et al. Randomized trial of prolonged exposure for posttraumatic stress disorder with and without cognitive restructuring: outcome at academic and community clinics. J Consult Clin Psychol. Oct. 2005;73(5):953-64. [pmid: 16287395].
33 Forbes D, Lloyd D, Nixon RDV, et al. A multisite randomized controlled effectiveness trial of cognitive processing therapy for military-related posttraumatic stress disorder. Journal of Anxiety Disorders. 2012;26(3):442-52. [pmid: 22366446].
34 Ford JD, Steinberg KL, Zhang W. A randomized clinical trial comparing affect regulation and social problem-solving psychotherapies for mothers with victimization-related PTSD. Behavior therapy. 2011;42(4):560-78. 2011-25130-002. First Author & Affiliation: Ford, Julian D. [pmid: 22035986].
35 Friedman MJ, Marmar CR, Baker DG, et al. Randomized, double-blind comparison of sertraline and placebo for posttraumatic stress disorder in a Department of Veterans Affairs setting. J Clin Psychiatry. May. 2007;68(5):711-20. [pmid: 17503980].
36 Gamito P, Oliveira J, Rosa P, et al. PTSD elderly war veterans: a clinical controlled pilot study. Cyberpsychol Behav Soc Netw. Feb. 2010;13(1):43-8. [pmid: 20528292].
37 Gersons BP, Carlier IV, Lamberts RD, et al. Randomized clinical trial of brief eclectic psychotherapy for police officers with posttraumatic stress disorder. J Trauma Stress. Apr. 2000;13(2):333-47. [pmid: 10838679].
38 Hamner MB, Faldowski RA, Ulmer HG, et al. Adjunctive risperidone treatment in post-traumatic stress disorder: a preliminary controlled trial of effects on comorbid psychotic symptoms. Int Clin Psychopharmacol. Jan. 2003;18(1):1-8. [pmid: 12490768].
39 Hien DA, Cohen LR, Miele GM, et al. Promising treatments for women with comorbid PTSD and substance use disorders. Am J Psychiatry. Aug. 2004;161(8):1426-32. [pmid: 15285969].
40 Hien DA, Wells EA, Jiang H, et al. Multisite randomized trial of behavioral interventions for women with co-occurring PTSD and substance use disorders. J Consult Clin Psychol. Aug. 2009;77(4):607-19. [pmid: 19634955].
41 Hien DA, Morgan-Lopez AA, Campbell ANC, et al. Attendance and substance use outcomes for the Seeking Safety program: sometimes less is more. Journal of consulting and clinical psychology. 2012;80(1):29-42. [pmid: 22182262].
42 Hinton DE, Chhean D, Pich V, et al. A randomized controlled trial of cognitive-behavior therapy for Cambodian refugees with treatment-resistant PTSD and panic attacks: a cross-over design. J Trauma Stress. Dec. 2005;18(6):617-29. [pmid: 16382423].
43 Hinton DE, Hofmann SG, Pollack MH, et al. Mechanisms of efficacy of CBT for Cambodian refugees with PTSD: improvement in emotion regulation and orthostatic blood pressure response. CNS Neurosci Ther. Fall. 2009;15(3):255-63. [pmid: 19691545].
44 Hinton DE, Hofmann SG, Rivera E, et al. Culturally adapted CBT (CA-CBT) for Latino women with treatment-resistant PTSD: a pilot study comparing CA-CBT to applied muscle relaxation. Behav Res Ther. Apr. 2011;49(4):275-80. [pmid: 21333272].
45 Hogberg G, Pagani M, Sundin O, et al. On treatment with eye movement desensitization and reprocessing of chronic post-traumatic stress disorder in public transportation workers - A randomized controlled trial. Nordic Journal of Psychiatry. 2007;61(1):54-61. WOS:000245235400009. [pmid: 17365790].
46 Hollifield M, Sinclair-Lian N, Warner TD, et al. Acupuncture for posttraumatic stress disorder: a randomized controlled pilot trial. J Nerv Ment Dis. Jun. 2007;195(6):504-13. [pmid: 17568299].
47 Johnson DM, Zlotnick C, Perez S. Cognitive behavioral treatment of ptsd in residents of battered women’s shelters: Results of a randomized clinical trial. Journal of Consulting and Clinical Psychology. 2011;79(4):542-51. [pmid: 21787052].
48 Krakow B, Hollifield M, Johnston L, et al. Imagery rehearsal therapy for chronic nightmares in sexual assault survivors with posttraumatic stress disorder: a randomized controlled trial. JAMA. Aug. 1. 2001;286(5):537-45. [pmid: 11476655].
49 Kruse J, Joksimovic L, Cavka M, et al. Effects of trauma-focused psychotherapy upon war refugees. J Trauma Stress. Dec. 2009;22(6):585-92. [pmid: 19960519].
50 Krystal JH, Rosenheck RA, Cramer JA, et al. Adjunctive risperidone treatment for antidepressant-resistant symptoms of chronic military service-related PTSD: a randomized trial. JAMA. Aug. 3. 2011;306(5):493-502. [pmid: 21813427].
51 Kubany ES, Hill EE, Owens JA. Cognitive trauma therapy for battered women with PTSD: preliminary findings. J Trauma Stress. Feb. 2003;16(1):81-91. [pmid: 12602656].
52 Kubany ES, Hill EE, Owens JA, et al. Cognitive trauma therapy for battered women with PTSD (CTT-BW). J Consult Clin Psychol. Feb. 2004;72(1):3-18. [pmid: 14756610].
53 Liedl A, Muller J, Morina N, et al. Physical activity within a CBT intervention improves coping with pain in traumatized refugees: results of a randomized controlled design. Pain Med. Feb. 2011;12(2):234-45. [pmid: 21223501].
54 Lindauer RJ, Gersons BP, van Meijel EP, et al. Effects of brief eclectic psychotherapy in patients with posttraumatic stress disorder: randomized clinical trial. J Trauma Stress. Jun. 2005;18(3):205-12. [pmid: 16281214].
55 Litz BT, Engel CC, Bryant RA, et al. A randomized, controlled proof-of-concept trial of an Internet-based, therapist-assisted self-management treatment for posttraumatic stress disorder. Am J Psychiatry. Nov. 2007;164(11):1676-83. [pmid: 17974932].
56 Marks I, Lovell K, Noshirvani H, et al. Treatment of posttraumatic stress disorder by exposure and/or cognitive restructuring: a controlled study. Arch Gen Psychiatry. Apr. 1998;55(4):317-25. [pmid: 9554427].
57 Lovell K, Marks IM, Noshirvani H, et al. Do cognitive and exposure treatments improve various PTSD symptoms differently?: a randomized controlled trial. Behavioural and Cognitive Psychotherapy. 2001;29(1):107-12.
58 Marshall RD, Beebe KL, Oldham M, et al. Efficacy and safety of paroxetine treatment for chronic PTSD: a fixed-dose, placebo-controlled study. Am J Psychiatry. Dec. 2001;158(12):1982-8. [pmid: 11729013].
59 Martenyi F, Brown EB, Zhang H, et al. Fluoxetine versus placebo in posttraumatic stress disorder. J Clin Psychiatry. Mar. 2002;63(3):199-206. [pmid: 11926718].
60 Martenyi F, Soldatenkova V. Fluoxetine in the acute treatment and relapse prevention of combat-related post-traumatic stress disorder: Analysis of the veteran group of a placebo-controlled, randomized clinical trial. Eur Neuropsychopharmacol. Jul. 2006;16(5):340-9. [pmid: 16356696].
61 Martenyi F, Brown EB, Caldwell CD. Failed efficacy of fluoxetine in the treatment of posttraumatic stress disorder: results of a fixed-dose, placebo-controlled study. J Clin Psychopharmacol. Apr. 2007;27(2):166-70. [pmid: 17414240].
62 McDonagh A, Friedman M, McHugo G, et al. Randomized trial of cognitive-behavioral therapy for chronic posttraumatic stress disorder in adult female survivors of childhood sexual abuse. J Consult Clin Psychol. Jun. 2005;73(3):515-24. [pmid: 15982149].
63 Monnelly EP, Ciraulo DA, Knapp C, et al. Low-dose risperidone as adjunctive therapy for irritable aggression in posttraumatic stress disorder. J Clin Psychopharmacol. Apr. 2003;23(2):193-6. [pmid: 12640221].
64 Monson CM, Schnurr PP, Resick PA, et al. Cognitive processing therapy for veterans with military-related posttraumatic stress disorder. J Consult Clin Psychol. Oct. 2006;74(5):898-907. [pmid: 17032094].
65 Mueser KT, Rosenberg SD, Xie H, et al. A randomized controlled trial of cognitive-behavioral treatment for posttraumatic stress disorder in severe mental illness. J Consult Clin Psychol. Apr. 2008;76(2):259-71. [pmid: 18377122].
66 Nacasch N, Foa EB, Huppert JD, et al. Prolonged exposure therapy for combat- and terror-related posttraumatic stress disorder: a randomized control comparison with treatment as usual. J Clin Psychiatry. Sep. 2011;72(9):1174-80. [pmid: 21208581].
67 Neuner F, Schauer M, Klaschik C, et al. A comparison of narrative exposure therapy, supportive counseling, and psychoeducation for treating posttraumatic stress disorder in an african refugee settlement. J Consult Clin Psychol. Aug. 2004;72(4):579-87. [pmid: 15301642].
68 Neuner F, Onyut PL, Ertl V, et al. Treatment of posttraumatic stress disorder by trained lay counselors in an African refugee settlement: a randomized controlled trial. J Consult Clin Psychol. Aug. 2008;76(4):686-94. [pmid: 18665696].
69 Neuner F, Kurreck S, Ruf M, et al. Can asylum-seekers with posttraumatic stress disorder be successfully treated? A randomized controlled pilot study. Cogn Behav Ther. Jun. 2010;39(2):81-91. [pmid: 19816834].
70 Nijdam MJ, Gersons BPR, Reitsma JB, et al. Brief eclectic psychotherapy v. eye movement desensitisation and reprocessing therapy for post-traumatic stress disorder: randomised controlled trial. British Journal of Psychiatry. Mar. 2012;200(3):224-31. WOS:000301829700011. [pmid: 22322458].
71 Panahi Y, Moghaddam BR, Sahebkar A, et al. A randomized, double-blind, placebo-controlled trial on the efficacy and tolerability of sertraline in Iranian veterans with post-traumatic stress disorder. Psychol Med. Oct. 2011;41(10):2159-66. [pmid: 21349225].
72 Petrakis IL, Ralevski E, Desai N, et al. Noradrenergic vs Serotonergic Antidepressant with or without Naltrexone for Veterans with PTSD and Comorbid Alcohol Dependence. Neuropsychopharmacology. Mar. 2012;37(4):996-1004. [pmid: 22089316].
73 Raskind MA, Peskind ER, Kanter ED, et al. Reduction of nightmares and other PTSD symptoms in combat veterans by prazosin: a placebo-controlled study. Am J Psychiatry. Feb. 2003;160(2):371-3. [pmid: 12562588].
74 Raskind MA, Peskind ER, Hoff DJ, et al. A parallel group placebo controlled study of prazosin for trauma nightmares and sleep disturbance in combat veterans with post-traumatic stress disorder. Biol Psychiatry. Apr. 15. 2007;61(8):928-34. [pmid: 17069768].
75 Reich DB, Winternitz S, Hennen J, et al. A preliminary study of risperidone in the treatment of posttraumatic stress disorder related to childhood abuse in women. J Clin Psychiatry. Dec. 2004;65(12):1601-6. [pmid: 15641864].
76 Resick PA, Nishith P, Weaver TL, et al. A comparison of cognitive-processing therapy with prolonged exposure and a waiting condition for the treatment of chronic posttraumatic stress disorder in female rape victims. J Consult Clin Psychol. Aug. 2002;70(4):867-79. [pmid: 12182270].
77 Resick PA, Nishith P, Griffin MG. How well does cognitive-behavioral therapy treat symptoms of complex PTSD? An examination of child sexual abuse survivors within a clinical trial. CNS Spectr. May. 2003;8(5):340-55. [pmid: 12766690].
78 Resick PA, Williams LF, Suvak MK, et al. Long-term outcomes of cognitive-behavioral treatments for posttraumatic stress disorder among female rape survivors. Journal of consulting and clinical psychology. 2012;80(2):201-10. [pmid: 22182261].
79 Rothbaum BO. A controlled study of eye movement desensitization and reprocessing in the treatment of posttraumatic stress disordered sexual assault victims. Bull Menninger Clin. Summer. 1997;61(3):317-34. [pmid: 9260344].
80 Rothbaum BO, Astin MC, Marsteller F. Prolonged Exposure versus Eye Movement Desensitization and Reprocessing (EMDR) for PTSD rape victims. J Trauma Stress. Dec. 2005;18(6):607-16. [pmid: 16382428].
81 Rothbaum BO, Cahill SP, Foa EB, et al. Augmentation of sertraline with prolonged exposure in the treatment of posttraumatic stress disorder. J Trauma Stress. Oct. 2006;19(5):625-38. [pmid: 17075912].
82 Schneier FR, Neria Y, Pavlicova M, et al. Combined prolonged exposure therapy and paroxetine for PTSD related to the World Trade Center attack: a randomized controlled trial. Am J Psychiatry. Jan. 2012;169(1):80-8. [pmid: 21908494].
83 Schnurr PP, Friedman MJ, Foy DW, et al. Randomized trial of trauma-focused group therapy for posttraumatic stress disorder - Results from a Department of Veterans Affairs Cooperative Study. Archives of General Psychiatry. May. 2003;60(5):481-9. WOS:000182735000006. [pmid: 12742869].
84 Schnurr PP, Friedman MJ, Engel CC, et al. Cognitive behavioral therapy for posttraumatic stress disorder in women - A randomized controlled trial. Journal of the American Medical Association. Feb. 2007;297(8):820-30. WOS:000244485000025. [pmid: 17327524].
85 Schnyder U, Muller J, Maercker A, et al. Brief eclectic psychotherapy for PTSD: a randomized controlled trial. J Clin Psychiatry. Apr. 2011;72(4):564-6. [pmid: 21527127].
86 Simon NM, Connor KM, Lang AJ, et al. Paroxetine CR augmentation for posttraumatic stress disorder refractory to prolonged exposure therapy. J Clin Psychiatry. Mar. 2008;69(3):400-5. [pmid: 18348595].
87 Spence J, Titov N, Dear BF, et al. Randomized controlled trial of Internet-delivered cognitive behavioral therapy for posttraumatic stress disorder. Depress Anxiety. Jul. 2011;28(7):541-50. [pmid: 21721073].
88 Stein MB, Kline NA, Matloff JL. Adjunctive olanzapine for SSRI-resistant combat-related PTSD: a double-blind, placebo-controlled study. Am J Psychiatry. Oct. 2002;159(10):1777-9. [pmid: 12359687].
89 Tarrier N, Pilgrim H, Sommerfield C, et al. A randomized trial of cognitive therapy and imaginal exposure in the treatment of chronic posttraumatic stress disorder. J Consult Clin Psychol. Feb. 1999;67(1):13-8. [pmid: 10028204].
90 Tarrier N, Sommerfield C, Pilgrim H, et al. Cognitive therapy or imaginal exposure in the treatment of post-traumatic stress disorder. Twelve-month follow-up. Br J Psychiatry. Dec. 1999;175:571-5. [pmid: 10789356].
91 Taylor S, Thordarson DS, Maxfield L, et al. Comparative efficacy, speed, and adverse effects of three PTSD treatments: exposure therapy, EMDR, and relaxation training. J Consult Clin Psychol. Apr. 2003;71(2):330-8. [pmid: 12699027].
92 Tucker P, Zaninelli R, Yehuda R, et al. Paroxetine in the treatment of chronic posttraumatic stress disorder: results of a placebo-controlled, flexible-dosage trial. J Clin Psychiatry. Nov. 2001;62(11):860-8. [pmid: 11775045].
93 Tucker P, Potter-Kimball R, Wyatt DB, et al. Can physiologic assessment and side effects tease out differences in PTSD trials? A double-blind comparison of citalopram, sertraline, and placebo. Psychopharmacol Bull. Summer. 2003;37(3):135-49. [pmid: 14608246].
94 Tucker P, Ruwe WD, Masters B, et al. Neuroimmune and cortisol changes in selective serotonin reuptake inhibitor and placebo treatment of chronic posttraumatic stress disorder. Biol Psychiatry. Jul. 15. 2004;56(2):121-8. [pmid: 15231444].
95 Tucker P, Trautman RP, Wyatt DB, et al. Efficacy and safety of topiramate monotherapy in civilian posttraumatic stress disorder: a randomized, double-blind, placebo-controlled study. J Clin Psychiatry. Feb. 2007;68(2):201-6. [pmid: 17335317].
96 van der Kolk BA, Dreyfuss D, Michaels M, et al. Fluoxetine in posttraumatic stress disorder. J Clin Psychiatry. Dec. 1994;55(12):517-22. [pmid: 7814344].
97 van der Kolk BA, Spinazzola J, Blaustein ME, et al. A randomized clinical trial of eye movement desensitization and reprocessing (EMDR), fluoxetine, and pill placebo in the treatment of posttraumatic stress disorder: treatment effects and long-term maintenance. J Clin Psychiatry. Jan. 2007;68(1):37-46. [pmid: 17284128].
98 van Emmerik AA, Kamphuis JH, Emmelkamp PM. Treating acute stress disorder and posttraumatic stress disorder with cognitive behavioral therapy or structured writing therapy: a randomized controlled trial. Psychother Psychosom. 2008;77(2):93-100. [pmid: 18230942].
99 Yeh MS, Mari JJ, Costa MC, et al. A double-blind randomized controlled trial to study the efficacy of topiramate in a civilian sample of PTSD. CNS Neurosci Ther. Oct. 2011;17(5):305-10. [pmid: 21554564].
100 Zlotnick C, Johnson J, Najavits LM. Randomized controlled pilot study of cognitive-behavioral therapy in a sample of incarcerated women with substance use disorder and PTSD. Behav Ther. Dec. 2009;40(4):325-36. [pmid: 19892078].
101 Zohar J, Amital D, Miodownik C, et al. Double-blind placebo-controlled pilot study of sertraline in military veterans with posttraumatic stress disorder. J Clin Psychopharmacol. Apr. 2002;22(2):190-5. [pmid: 11910265].