# Excluded Studies

## Excluded for No Original Data

1 Albucher RC, Liberzon I. Psychopharmacological treatment in PTSD: a critical review. Journal of Psychiatric Research. Nov–Dec. 2002;36(6):355-67. WOS:000179271000001. [pmid: 12393304].
2 Allen SN, Bloom SL. Group and Family Treatment of Posttraumatic-Stress-Disorder. Psychiatric Clinics of North America. Jun. 1994;17(2):425-37. WOS:A1994NR15100014. [pmid: 7937368].
3 Allodi FA. Posttraumatic-Stress-Disorder in Hostages and Victims of Torture. Psychiatric Clinics of North America. Jun. 1994;17(2):279-88. WOS:A1994NR15100005. [pmid: 7937359].
4 Arciniegas DB, Silver JM. Pharmacotherapy of posttraumatic cognitive impairments. Behavioural Neurology. 2006;17(1):25-42. WOS:000238773700004. [pmid: 16720958].
5 Bajor LA, Ticlea AN, Osser DN. The Psychopharmacology Algorithm Project at the Harvard South Shore Program: An Update on Posttraumatic Stress Disorder. Harvard Review of Psychiatry. Sep–Oct. 2011;19(5):240-58. WOS:000294921700003. [pmid: 21916826].
6 Bisson J, Andrew M. Psychological treatment of post-traumatic stress disorder (PTSD). Cochrane Database Syst Rev. 2005;(2):CD003388. [pmid: 15846661].
7 Bisson J, Andrew M. Psychological treatment of post-traumatic stress disorder. (Withdrawn Paper. 2007 art. no. CD003388). Cochrane Database of Systematic Reviews. 2007;(3). WOS:000248118000140.
8 Bisson JI, Brayne M, Ochberg FM, et al. Early psychosocial intervention following traumatic events. Am J Psychiatry. Jul. 2007;164(7):1016-9. [pmid: 17606651].
9 Blain LM, Galovski TE, Robinson T. Gender differences in recovery from posttraumatic stress disorder: A critical review. Aggression and Violent Behavior. Nov–Dec. 2010;15(6):463-74. WOS:000284783900007.
10 Brunet A, Poundja J, Tremblay J, et al. Trauma reactivation under the influence of propranolol decreases posttraumatic stress symptoms and disorder: 3 open-label trials. Journal of Clinical Psychopharmacology. 2011;31(4):547. 2011-14240-032. [pmid: 21720237].
11 Byers MG, Allison KM, Wendel CS, et al. Prazosin versus quetiapine for nighttime posttraumatic stress disorder symptoms in veterans: an assessment of long-term comparative effectiveness and safety. J Clin Psychopharmacol. Jun. 2010;30(3):225-9. [pmid: 20473055].
12 Cavaljuga S, Licanin I, Mulabegovic N, et al. Therapeutic effects of two antidepressant agents in the treatment of posttraumatic stress disorder (PTSD). Bosnian Journal of Basic Medical Sciences. 2003;3(2):12-6. [pmid: 16223367].
13 Coupland NJ. Treatment of insomnia in post--traumatic stress disorder. J Psychiatry Neurosci. Sep. 2009;34(5):E5-6. [pmid: 19721842].
14 Daly CM, Doyle ME, Radkind M, et al. Clinical case series: the use of Prazosin for combat-related recurrent nightmares among Operation Iraqi Freedom combat veterans. Mil Med. Jun. 2005;170(6):513-5. [pmid: 16001603].
15 Davidson J, Baldwin DS, Stein DJ, et al. Effects of venlafaxine extended release on resilience in posttraumatic stress disorder: an item analysis of the Connor-Davidson Resilience Scale. Int Clin Psychopharmacol. Sep. 2008;23(5):299-303. [pmid: 18703940].
16 Davidson JR. Remission in post-traumatic stress disorder (PTSD): effects of sertraline as assessed by the Davidson Trauma Scale, Clinical Global Impressions and the Clinician-Administered PTSD scale. Int Clin Psychopharmacol. Mar. 2004;19(2):85-7. [pmid: 15076016].
17 Davidson JRT, Malik ML, Sutherland SN. Response characteristics to antidepressants and placebo in post-traumatic stress disorder. International Clinical Psychopharmacology. 1997;12(6):291. 1997-39087-001. [pmid: 9547130].
18 Deahl MP, Srinivasan M, Jones N, et al. Evaluating psychological debriefing: are we measuring the right outcomes?. J Trauma Stress. Jul. 2001;14(3):527-9. [pmid: 11534883].
19 Difede J, Cukor J, Lee F, et al. Treatments for common psychiatric conditions among adults during acute, rehabilitation, and reintegration phases. International Review of Psychiatry. 2009;21(6):559. 2009-22426-008. [pmid: 19919209].
20 Ehlers A, Bisson J, Clark DM, et al. Do all psychological treatments really work the same in posttraumatic stress disorder?. Clinical Psychology Review. Mar. 2010;30(2):269-76. WOS:000274319600011. [pmid: 20051310].
21 Flicker L, Grimley Evans J. Piracetam for dementia or cognitive impairment. Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2004.
22 Forbes D, Creamer M, Phelps A, et al. Australian guidelines for the treatment of adults with acute stress disorder and post-traumatic stress disorder. Aust N Z J Psychiatry. Aug. 2007;41(8):637-48. [pmid: 17620160].
23 Frank JB, Kosten TR, Giller EL Jr, et al. A randomized clinical trial of phenelzine and imipramine for posttraumatic stress disorder. Am J Psychiatry. Oct. 1988;145(10):1289-91. [pmid: 3048121].
24 Friedman MJ. Toward Rational Pharmacotherapy for Posttraumatic Stress Disorder - an Interim-Report. American Journal of Psychiatry. Mar. 1988;145(3):281-5. WOS:A1988M329100001. [pmid: 2894174].
25 Ghosh Ippen C, Harris WW, Van Horn P, et al. Traumatic and stressful events in early childhood: can treatment help those at highest risk?. Child abuse & neglect. 2011:504-13. [pmid: 21816474].
26 Ginsberg DL. Prazosin reduces nightmares in posttraumatic stress disorder. Primary Psychiatry. 2003;10(4). 2004-12636-007.
27 Gros DF, Strachan M, Ruggiero KJ, et al. Innovative service delivery for secondary prevention of PTSD in at-risk OIF-OEF service men and women. Contemp Clin Trials. Jan. 2011;32(1):122-8. [pmid: 20951235].
28 Hoffman EJ, Mathew SJ. Anxiety disorders: A comprehensive review of pharmacotherapies. Mount Sinai Journal of Medicine. May–Jun. 2008;75(3):248-62. WOS:000258858900005. [pmid: 18704983].
29 Irwin M, Van Putten T, Guze B, et al. Pharmacologic treatment of veterans with posttraumatic stress disorder and concomitant affective disorder. Annals of Clinical Psychiatry. 1989;1(2):127. 1990-31653-001.
30 Jacobs-Rebhun S, Schnurr PP, Friedman MJ, et al. Posttraumatic stress disorder and sleep difficulty. The American Journal of Psychiatry. 2000;157(9):1525. 2000-05835-031. [pmid: 10964881].
31 Katz L, Fleisher W, Kjernisted K, et al. A review of the psychobiology and pharmacotherapy of posttraumatic stress disorder. Canadian Journal of Psychiatry-Revue Canadienne De Psychiatrie. May. 1996;41(4):233-8. WOS:A1996UM03000008. [pmid: 8726789].
32 Keck PE, McElroy SL, Friedman LM. Valproate and Carbamazepine in the Treatment of Panic and Posttraumatic Stress Disorders, Withdrawal States, and Behavioral Dyscontrol Syndromes. Journal of Clinical Psychopharmacology. Feb. 1992;12(1):S36-S41. WOS:A1992HB54700006.
33 Khachiyants N, Ali R, Kovesdy CP, et al. Effectiveness of risperidone for the treatment of nightmares in veterans with posttraumatic stress disorder. J Clin Psychopharmacol. Dec. 2010;30(6):735-7. [pmid: 21057238].
34 Khan A, Shad MU, Preskorn SH. Lack of sertraline efficacy probably due to an interaction with carbamazepine. J Clin Psychiatry. Jul. 2000;61(7):526-7. [pmid: 10937612].
35 Kozaric-Kovacic D. Pharmacotherapy treatment of PTSD and comorbid disorders. Psychiatria Danubina. 2009;21(3):411. 2009-18492-025. [pmid: 19794366].
36 Kreidler MC, Briscoe LA, Beech RR. Pharmacology for post-traumatic stress disorder related to childhood sexual abuse: A literature review. Perspectives in Psychiatric Care. Oct–Dec. 2002;38(4):135-45. WOS:000180292900003. [pmid: 12629952].
37 Krippner S, Colodzin B. Multi-cultural methods of treating Vietnam veterans with post-traumatic stress disorder. International Journal of Psychosomatics. 1989;36(1–4):79. 1990-15211-001. [pmid: 2689376].
38 Labbate LA, Douglas S. Olanzapine for nightmares and sleep disturbance in posttraumatic stress disorder (PTSD). Can J Psychiatry. Sep. 2000;45(7):667-8. [pmid: 11056832].
39 Lamarche LJ, De Koninck J. Sleep disturbance in adults with posttraumatic stress disorder: A review. Journal of Clinical Psychiatry. 2007;68(8):1257. 2007-19244-012. [pmid: 17854251].
40 Lee CW, Schubert S. Omissions and errors in the institute of medicine’s report on scientific evidence of treatment for posttraumatic stress disorder. Journal of EMDR Practice and Research. 2009;3(1):32. 2009-02768-004.
41 Lin KM, Shen WW. Pharmacotherapy for Southeast-Asian Psychiatric-Patients. Journal of Nervous and Mental Disease. Jun. 1991;179(6):346-50. WOS:A1991FR29200007. [pmid: 2051149].
42 Lohr JM, Kleinknecht RA, Tolin DF, et al. The empirical status of the clinical application of eye movement desensitization and reprocessing. J Behav Ther Exp Psychiatry. Dec. 1995;26(4):285-302. [pmid: 8675716].
43 Lohr JM, Lilienfeld SO, Tolin DF, et al. Eye movement desensitization and reprocessing: An analysis of specific versus nonspecific treatment factors. Journal of Anxiety Disorders. Jan–Apr. 1999;13(1–2):185-207. WOS:000079383700011. [pmid: 10225508].
44 Marmar CR. Brief Dynamic Psychotherapy of Posttraumatic-Stress-Disorder. Psychiatric Annals. Jul. 1991;21(7):405-&. WOS:A1991GB08000003.
45 Marom S, Hermesh H. Cognitive behavior therapy (CBT) in anxiety disorders. Israel Journal of Psychiatry and Related Sciences. 2003;40(2):135-44. WOS:000185520300009. [pmid: 14509204].
46 Marshall RD, Klein DF. Pharmacotherapy in the Treatment of Posttraumatic-Stress-Disorder. Psychiatric Annals. Oct. 1995;25(10):588-&. WOS:A1995RZ92100001.
47 Marshall RD, Pierce D. Implications of recent findings in posttraumatic stress disorder and the role of pharmacotherapy. Harvard Review of Psychiatry. Jan–Feb. 2000;7(5):247-56. WOS:000084809200001. [pmid: 10689590].
48 Marshall RD, Printz D, Cardenas D, et al. Adverse events in PTSD patients taking fluoxetine. The American Journal of Psychiatry. 1995;152(8):1238. 1996-92649-001. [pmid: 7625486].
49 McAllister TW. Psychopharmacological issues in the treatment of TBI and PTSD. The Clinical Neuropsychologist. 2009;23(8):1338. 2009-22430-006. [pmid: 19882475].
50 McCabe S. EMDR: Implications of the use of reprocessing therapy in nursing practice. Perspectives in Psychiatric Care. Jul–Sep. 2004;40(3):104-13. WOS:000224288900003. [pmid: 15515291].
51 McFarlane AC. Individual Psychotherapy for Posttraumatic-Stress-Disorder. Psychiatric Clinics of North America. Jun. 1994;17(2):393-408. WOS:A1994NR15100012. [pmid: 7937366].
52 McHugo GJ, Fallot RD. Multisite randomized trial of behavioral interventions for women with co-occurring PTSD and substance use disorders. Journal of Dual Diagnosis. 2011;7(4):280-4.
53 Mellman TA, Bustamante V, David D, et al. Hypnotic medication in the aftermath of trauma. Journal of Clinical Psychiatry. 2002;63(12):1183. 2003-04162-022. [pmid: 12530420].
54 Mello MF, Yeh MS, Barbosa Neto J, et al. A randomized, double-blind, placebo-controlled trial to assess the efficacy of topiramate in the treatment of post-traumatic stress disorder. BMC Psychiatry. 2009;9:28. [pmid: 19480669].
55 Muenzenmaier K, Castille DM, Shelley AM, et al. Comorbid posttraumatic stress disorder and schizophrenia. Psychiatric Annals. Jan. 2005;35(1):50-6. WOS:000226312000013.
56 Oster MI Chapman RA Treating Treatment Failures: Hypnotic Treatment of Posttraumatic Stress Disorder The Clinical Use of Hypnosis in Cognitive Behavior Therapy: A Practitioner’s Casebook 2006 213 2005-13006-008-->
57 Pabst A, Schauer M, Bernhardt K, et al. Treatment of patients with borderline personality disorder and comorbid posttraumatic stress disorder using narrative exposure therapy: a feasibility study. Psychother Psychosom. 2012;81(1):61-3. [pmid: 22123437].
58 Phillips ME, Bruehl S, Harden RN. Work-related post-traumatic stress disorder: use of exposure therapy in work-simulation activities. Am J Occup Ther. Sep. 1997;51(8):696-700. [pmid: 9279441].
59 Ponniah K, Hollon SD. Empirically Supported Psychological Treatments for Adult Acute Stress Disorder and Posttraumatic Stress Disorder: A Review. Depression and Anxiety. Dec. 2009;26(12):1086-109. WOS:000272830500003. [pmid: 19957280].
60 Price JL, Hilsenroth MJ, Petretic-Jackson PA, et al. A review of individual psychotherapy outcomes for adult survivors of childhood sexual abuse (Structured abstract). Clinical Psychology Review. 2001;(7):1095-121. DARE-12001006207. [pmid: 11584517].
61 Prior TI. Treatment of posttraumatic stress disorder with olanzapine. Can J Psychiatry. Mar. 2001;46(2):182. [pmid: 11280089].
62 Resing M. Mental health problems of Vietnam veterans. J Psychosoc Nurs Ment Health Serv. Sep. 1982;20(9):40-3. [pmid: 6922182].
63 Rose DS. A Model for Psychodynamic Psychotherapy with the Rape Victim. Psychotherapy. Spr. 1991;28(1):85-95. WOS:A1991EZ39100011.
64 Rosqvist J, Björgvinsson Ts, Norling DC, et al. Posttraumatic stress disorder. Handbook of clinical interviewing with adults. 2007:238. 2007-00669-016.
65 Roy MJ, Law W, Patt I, et al. Randomized controlled trial of CBT with virtual reality exposure therapy for PTSD. Annual Review of CyberTherapy and Telemedicine. 2006;4:39. 2008-04693-008.
66 Schnurr PP, Friedman MJ, Engel CC, et al. Issues in the design of multisite clinical trials of psychotherapy: VA Cooperative Study No. 494 as an example. Contemporary Clinical Trials. Dec. 2005;26(6):626-36. WOS:000234074000004. [pmid: 16236558].
67 Servan-Schreiber D. Eye movement desensitization and reprocessing psychotherapy: A model for integrative medicine. Alternative Therapies in Health and Medicine. Jul–Aug. 2002;8(4):100-3. WOS:000176772000023. [pmid: 12126160].
68 Shalev AY, Bonne O, Eth S. Treatment of posttraumatic stress disorder: A review. Psychosomatic Medicine. Mar–Apr. 1996;58(2):165-82. WOS:A1996UC05700012. [pmid: 8849635].
69 Silver JM, Sandberg DP, Hales RE. New Approaches in the Pharmacotherapy of Posttraumatic-Stress-Disorder. Journal of Clinical Psychiatry. Oct. 1990;51:33-8. WOS:A1990EF22100007.
70 Silverman JJ. Post-traumatic stress disorder. Adv Psychosom Med. 1986;16:115-40. [pmid: 3521225].
71 Spector J, Read J. The current status of eye movement desensitization and reprocessing (EMDR). Clinical Psychology & Psychotherapy. Jul. 1999;6(3):165-74. WOS:000082001300001.
72 Stein DJ, Ipser J, McAnda N. Pharmacotherapy of Posttraumatic Stress Disorder: A Review of Meta-Analyses and Treatment Guidelines. Cns Spectrums. Jan. 2009;14(1):25-31. WOS:000264852300004. [pmid: 19169191].
73 Strachan M, Gros DF, Yuen E, et al. Home-based telehealth to deliver evidence-based psychotherapy in veterans with PTSD. Contemporary clinical trials. Mar. 2012;33(2):402-9. WOS:000300962000020. [pmid: 22101225].
74 Strauss JL, Calhoun PS, Marx CE, et al. Guided imagery as a therapeutic tool in post-traumatic stress disorder. Post-traumatic stress disorder: Basic science and clinical practice. 2009:363. 2009-04091-017.
75 Sullivan G, Craske MG, Sherbourne C, et al. Design of the Coordinated Anxiety Learning and Management (CALM) study: innovations in collaborative care for anxiety disorders. General Hospital Psychiatry. Sep–Oct. 2007;29(5):379-87. WOS:000249976000001. [pmid: 17888803].
76 Sutherland SM, Davidson JRT. Pharmacotherapy for Posttraumatic-Stress-Disorder. Psychiatric Clinics of North America. Jun. 1994;17(2):409-23. WOS:A1994NR15100013. [pmid: 7937367].
77 Triffleman E, Carroll K, Kellogg S. Substance dependence posttraumatic stress disorder therapy - An integrated cognitive-behavioral approach. Journal of Substance Abuse Treatment. Jul–Sep. 1999;17(1–2):3-14. WOS:000081730600002. [pmid: 10435248].
78 Vargas MA, Davidson J. Posttraumatic-Stress-Disorder. Psychiatric Clinics of North America. Dec. 1993;16(4):737-48. WOS:A1993ML37800006. [pmid: 8309810].
79 Zatzick D, Rivara F, Jurkovich G, et al. Enhancing the population impact of collaborative care interventions: mixed method development and implementation of stepped care targeting posttraumatic stress disorder and related comorbidities after acute trauma. General Hospital Psychiatry. Mar–Apr. 2011;33(2):123-34. WOS:000289183700006. [pmid: 21596205].

## Excluded for Wrong Study Design

1 Aldwin CM, Levenson MR, Spiro A 3rd. Vulnerability and resilience to combat exposure: can stress have lifelong effects?. Psychol Aging. Mar. 1994;9(1):34-44. [pmid: 8185866].
2 Alvarez J, McLean C, Harris AH, et al. The comparative effectiveness of cognitive processing therapy for male veterans treated in a VHA posttraumatic stress disorder residential rehabilitation program. J Consult Clin Psychol. Oct. 2011;79(5):590-9. [pmid: 21744946].
3 Alvarez J, McLean C, Harris AHS, et al. The comparative effectiveness of cognitive processing therapy for male veterans treated in a VHA posttraumatic stress disorder residential rehabilitation program. Journal of Consulting and Clinical Psychology. 2011;79(5):590. 2011-13976-001. [pmid: 21744946].
4 Andrade J, Kavanagh D, Baddeley A. Eye-movements and visual imagery: a working memory approach to the treatment of post-traumatic stress disorder. Br J Clin Psychol. May. 1997;36(Pt 2):209-23. [pmid: 9167862].
5 Back SE, Brady KT, Sonne SC, et al. Symptom improvement in co-occurring PTSD and alcohol dependence. J Nerv Ment Dis. Sep. 2006;194(9):690-6. [pmid: 16971821].
6 Back SE, Jackson JL, Sonne S, et al. Alcohol dependence and posttraumatic stress disorder: differences in clinical presentation and response to cognitive-behavioral therapy by order of onset. J Subst Abuse Treat. Jul. 2005;29(1):29-37. [pmid: 15979529].
7 Ballenger JC. Remission rates in patients with anxiety disorders treated with paroxetine. J Clin Psychiatry. Dec. 2004;65(12):1696-707. [pmid: 15641876].
8 Benish SG, Imel ZE, Wampold BE. The relative efficacy of bona fide psychotherapies for treating post-traumatic stress disorder: A meta-analysis of direct comparisons. Clinical Psychology Review. Jun. 2008;28(5):746-58. WOS:000256137200003. [pmid: 18055080].
9 Bisson J, Andrew M. Psychological treatment of post-traumatic stress disorder (PTSD) - art. no. CD003388.pub2. Cochrane Database of Systematic Reviews. 2005;(2). WOS:000232199200023.
10 Bisson J, Andrew M. Psychological treatment of post-traumatic stress disorder (PTSD). Cochrane Database Syst Rev. 2007;(3):CD003388. [pmid: 17636720].
11 Black JL, Keane TM. Implosive therapy in the treatment of combat related fears in a world war II veteran. J Behav Ther Exp Psychiatry. Jun. 1982;13(2):163-5. [pmid: 7130414].
12 Blake DJ. Treatment of acute posttraumatic stress disorder with tricyclic antidepressants. South Med J. Feb. 1986;79(2):201-4. [pmid: 3945852].
13 Boehnlein JK, Sparr LF. Group therapy with WWII ex-POW’s: long-term posttraumatic adjustment in a geriatric population. Am J Psychother. Spring. 1993;47(2):273-82. [pmid: 8517474].
14 Bossini L, Tavanti M, Calossi S, et al. EMDR treatment for posttraumatic stress disorder, with focus on hippocampal volumes: a pilot study. J Neuropsychiatry Clin Neurosci. Spring. 2011;23(2):E1-2. [pmid: 21677204].
15 Bradley R, Greene J, Russ E, et al. A multidimensional meta-analysis of psychotherapy for PTSD. American Journal of Psychiatry. Feb. 2005;162(2):214-27. WOS:000227210800002. [pmid: 15677582].
16 Brady KT, Clary CM. Affective and anxiety comorbidity in post-traumatic stress disorder treatment trials of sertraline. Compr Psychiatry. Sep–Oct. 2003;44(5):360-9. [pmid: 14505296].
17 Bravo-Mehmedbasic A, Kucukalic A, Kulenovic AD, et al. Impact of chronic Posttraumatic Stress Disorder on the Quality of life of war survivors. Psychiatr Danub. Sep. 2010;22(3):430-5. [pmid: 20856187].
18 Bremner JD, Innis RB, Ng CK, et al. Positron emission tomography measurement of cerebral metabolic correlates of yohimbine administration in combat-related posttraumatic stress disorder. Arch Gen Psychiatry. Mar. 1997;54(3):246-54. [pmid: 9075465].
19 Britvic D, Anticevic V, Urlic I, et al. Psychotherapeutic treatment program for post-traumatic stress disorder: prospective study of 70 war veterans. Group Analysis. 2007;40(4):507-22.
20 Britvic D, Radelic N, Urlic I. Long-term dynamic-oriented group psychotherapy of posttraumatic stress disorder in war veterans: prospective study of five-year treatment. Croat Med J. Feb. 2006;47(1):76-84. [pmid: 16489700].
21 Cates ME, Bishop MH, Davis LL, et al. Clonazepam for treatment of sleep disturbances associated with combat-related posttraumatic stress disorder. Ann Pharmacother. Sep. 2004;38(9):1395-9. [pmid: 15252193].
22 Celik C, Ozdemir B, Ozmenler KN, et al. Efficacy of paroxetine and amitriptyline in posttraumatic stress disorder: An open-label comparative study. Klinik Psikofarmakoloji Bulteni. 2011;21(3):179-85.
23 Celik C, Ozdemir B, Ozmenler KN, et al. Efficacy of Paroxetine and Amitriptyline in Posttraumatic Stress Disorder: An Open-label Comparative Study. Klinik Psikofarmakoloji Bulteni-Bulletin of Clinical Psychopharmacology. Sep. 2011;21(3):179-85. WOS:000296684400002.
24 Chard KM, Schumm JA, Owens GP, et al. A comparison of OEF and OIF veterans and Vietnam veterans receiving cognitive processing therapy. J Trauma Stress. Feb. 2010;23(1):25-32. [pmid: 20146255].
25 Chung MY, Min KH, Jun YJ, et al. Efficacy and tolerability of mirtazapine and sertraline in Korean veterans with posttraumatic stress disorder: a randomized open label trial. Hum Psychopharmacol. Oct. 2004;19(7):489-94. [pmid: 15378676].
26 Clarke SB, Rizvi SL, Resick PA. Borderline personality characteristics and treatment outcome in cognitive-behavioral treatments for PTSD in female rape victims. Behav Ther. Mar. 2008;39(1):72-8. [pmid: 18328872].
27 Cohen LR, Hien DA. Treatment outcomes for women with substance abuse and PTSD who have experienced complex trauma. Psychiatr Serv. Jan. 2006;57(1):100-6. [pmid: 16399969].
28 Connor KM, Davidson JR, Weisler RH, et al. Tiagabine for posttraumatic stress disorder: effects of open-label and double-blind discontinuation treatment. Psychopharmacology (Berl). Jan. 2006;184(1):21-5. [pmid: 16341846].
29 Coupland NJ, Lillywhite A, Bell CE, et al. A pilot controlled study of the effects of flumazenil in posttraumatic stress disorder. Biol Psychiatry. May. 1. 1997;41(9):988-90. [pmid: 9110106].
30 Crumlish N, O’Rourke K. A Systematic Review of Treatments for Post-Traumatic Stress Disorder Among Refugees and Asylum-Seekers. Journal of Nervous and Mental Disease. Apr. 2010;198(4):237-51. WOS:000276836300001. [pmid: 20386252].
31 Cyr M, Farrar MK. Treatment for posttraumatic stress disorder. Annals of Pharmacotherapy. Mar. 2000;34(3):366-76. WOS:000085643200014. [pmid: 10917385].
32 David D, De Faria L, Mellman TA. Adjunctive risperidone treatment and sleep symptoms in combat veterans with chronic PTSD. Depress Anxiety. 2006;23(8):489-91. [pmid: 16845653].
33 Davidson J, Landerman LR, Clary CM. Improvement of anger at one week predicts the effects of sertraline and placebo in PTSD. J Psychiatr Res. Sep–Oct. 2004;38(5):497-502. [pmid: 15380400].
34 Davidson J, Pearlstein T, Londborg P, et al. Efficacy of sertraline in preventing relapse of posttraumatic stress disorder: results of a 28-week double-blind, placebo-controlled study. Am J Psychiatry. Dec. 2001;158(12):1974-81. [pmid: 11729012].
35 Davidson JR, Landerman LR, Farfel GM, et al. Characterizing the effects of sertraline in post-traumatic stress disorder. Psychol Med. May. 2002;32(4):661-70. [pmid: 12102380].
36 Davidson JR, Payne VM, Connor KM, et al. Trauma, resilience and saliostasis: effects of treatment in post-traumatic stress disorder. Int Clin Psychopharmacol. Jan. 2005;20(1):43-8. [pmid: 15602116].
37 Davidson JR, Weisler RH, Malik M, et al. Fluvoxamine in civilians with posttraumatic stress disorder. J Clin Psychopharmacol. Feb. 1998;18(1):93-5. [pmid: 9472854].
38 Devilly GJ, Spence SH, Rapee RM. Statistical and reliable change with eye movement desensitization and reprocessing: treating trauma within a veteran population. Behavior Therapy. 1998;29(3):435-55.
39 Donovan MR, Glue P, Kolluri S, et al. Comparative efficacy of antidepressants in preventing relapse in anxiety disorders - a meta-analysis. J Affect Disord. Jun. 2010;123(1–3):9-16. [pmid: 19616306].
40 Dossa NI, Hatem M. Cognitive-Behavioral Therapy versus Other PTSD Psychotherapies as Treatment for Women Victims of War-Related Violence: A Systematic Review. Scientific World Journal. 2012. WOS:000303521400001.
41 Dow B, Kline N. Antidepressant treatment of posttraumatic stress disorder and major depression in veterans. Ann Clin Psychiatry. Mar. 1997;9(1):1-5. [pmid: 9167830].
42 Ehlers A, Clark DM, Dunmore E, et al. Predicting response to exposure treatment in PTSD: the role of mental defeat and alienation. J Trauma Stress. Jul. 1998;11(3):457-71. [pmid: 9690187].
43 Falcon S, Ryan C, Chamberlain K, et al. Tricyclics: possible treatment for posttraumatic stress disorder. J Clin Psychiatry. Sep. 1985;46(9):385-8. [pmid: 3897205].
44 Falsetti SA, Erwin BA, Resnick HS, et al. Multiple channel exposure therapy of PTSD: impact of treatment on functioning and resources. Taylor Steven, editor. Advances in the treatment of posttraumatic stress disorder: cognitive-behavioral perspectives. New York. Springer. 2004.
45 Felmingham KL, Bryant RA. Gender Differences in the Maintenance of Response to Cognitive Behavior Therapy for Posttraumatic Stress Disorder. J Consult Clin Psychol. Apr. 2012;80(2):196-200. WOS:000301882600003. [pmid: 22309472].
46 Ferdos G, Seyed-Hossein S. The effectiveness of problem solving skills in decreasing PTSD symptoms in suvivors of Bam earthquake. Pakistan Journal of Medical Sciences. 2007;23(5):736-40.
47 Fesler FA. Valproate in combat-related posttraumatic stress disorder. J Clin Psychiatry. Sep. 1991;52(9):361-4. [pmid: 1894587].
48 Foa EB, Hearst-Ikeda D, Perry KJ. Evaluation of a brief cognitive-behavioral program for the prevention of chronic PTSD in recent assault victims. J Consult Clin Psychol. Dec. 1995;63(6):948-55. [pmid: 8543717].
49 Forbes D, Lewis V, Parslow R, et al. Naturalistic comparison of models of programmatic interventions for combat-related post-traumatic stress disorder. Aust N Z J Psychiatry. Dec. 2008;42(12):1051-9. [pmid: 19016093].
50 Gilron I, Wiffen Philip J, Moore RA. Combination pharmacotherapy for the treatment of neuropathic pain in adults. Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2011.
51 Hamburg P, Stelovich S, Sabin J. Managing therapeutic despair. Harv Rev Psychiatry. Nov–Dec. 1993;1(4):238-43. [pmid: 9384853].
52 Hammarberg M, Silver SM. Outcome of treatment for post-traumatic stress disorder in a primary care unit serving Vietnam veterans. J Trauma Stress. Apr. 1994;7(2):195-216. [pmid: 8012743].
53 Hamner M, Ulmer H, Horne D. Buspirone potentiation of antidepressants in the treatment of PTSD. Depress Anxiety. 1997;5(3):137-9. [pmid: 9323455].
54 Hargrave R. Serotonergic agents in the management of dementia and posttraumatic stress disorder. Psychosomatics. Sep–Oct. 1993;34(5):461-2. [pmid: 8140200].
55 Hembree EA, Cahill SP, Foa EB. Impact of personality disorders on treatment outcome for female assault survivors with chronic posttraumatic stress disorder. J Pers Disord. Feb. 2004;18(1):117-27. [pmid: 15061348].
56 Hetrick SE, Purcell R, Garner B, et al. Combined pharmacotherapy and psychological therapies for post traumatic stress disorder (PTSD). Cochrane Database Syst Rev. 2010;(7):CD007316. [pmid: 20614457].
57 Hofmann SG, Smits JA. Cognitive-behavioral therapy for adult anxiety disorders: a meta-analysis of randomized placebo-controlled trials. J Clin Psychiatry. Apr. 2008;69(4):621-32. [pmid: 18363421].
58 Hyer L, Boyd S, Scurfield R, et al. Effects of Outward Bound Experience as an adjunct to inpatient PTSD treatment of war veterans. J Clin Psychol. May. 1996;52(3):263-78. [pmid: 8835688].
59 Ipser J, Seedat S, Stein DJ. Pharmacotherapy for post-traumatic stress disorder - a systematic review and meta-analysis. Samj South African Medical Journal. Oct. 2006;96(10):1088-96. WOS:000241744500027.
60 Izrayelit L. Schizoaffective disorder and PTSD successfully treated with olanzapine and supportive psychotherapy. Psychiatric Annals. Aug. 1998;28(8):424-6. WOS:000075430600002.
61 Johnson DM, Zlotnick C. A cognitive-behavioral treatment for battered women with PTSD in shelters: findings from a pilot study. J Trauma Stress. Aug. 2006;19(4):559-64. [pmid: 16929512].
62 Johnson DR, Lubin H. Treatment preferences of Vietnam veterans with posttraumatic stress disorder. J Trauma Stress. Jul. 1997;10(3):391-405. [pmid: 9246647].
63 Johnson DR, Lubin H, James M, et al. Single session effects of treatment components within a specialized inpatient posttraumatic stress disorder program. J Trauma Stress. Jul. 1997;10(3):377-90. [pmid: 9246646].
64 Kearney DJ, McDermott K, Malte C, et al. Association of participation in a mindfulness program with measures of PTSD, depression and quality of life in a veteran sample. J Clin Psychol. Jan. 2012;68(1):101-16. [pmid: 22125187].
65 Kellner M, Muhtz C, Wiedemann K. Primary add-on of ziprasidone in sertraline treatment of posttraumatic stress disorder: lessons from a stopped trial?. J Clin Psychopharmacol. Aug. 2010;30(4):471-3. [pmid: 20631571].
66 Khoo A, Dent MT, Oei TPS. Group cognitive behaviour therapy for military service-related post-traumatic stress disorder: effectiveness, sustainability and repeatability. Australian and New Zealand Journal of Psychiatry. Aug. 2011;45(8):663-72. WOS:000294324700011. [pmid: 21870924].
67 Kibler JL, Lyons JA. Brief cognition-focused group therapy for depressive symptoms in chronic posttraumatic stress disorder: A pilot study. Journal of Psychological Trauma. 2008;7(2):122. 2008-13617-004.
68 Kim W, Pae CU, Chae JH, et al. The effectiveness of mirtazapine in the treatment of post-traumatic stress disorder: A 24-week continuation therapy. Psychiatry and Clinical Neurosciences. Dec. 2005;59(6):743-7. WOS:000233654800020. [pmid: 16401254].
69 Kinrys G, Wygant LE, Pardo TB, et al. Levetiracetam for treatment-refractory posttraumatic stress disorder. J Clin Psychiatry. Feb. 2006;67(2):211-4. [pmid: 16566615].
70 Kozaric-Kovacic D, Pivac N. Quetiapine treatment in an open trial in combat-related post-traumatic stress disorder with psychotic features. Int J Neuropsychopharmacol. Apr. 2007;10(2):253-61. [pmid: 16945162].
71 Leiner AS, Kearns MC, Jackson JL, et al. Avoidant coping and treatment outcome in rape-related posttraumatic stress disorder. Journal of consulting and clinical psychology. 2012. (Journal Article).
72 Lima AA, Fiszman A, Marques-Portella C, et al. The impact of tonic immobility reaction on the prognosis of posttraumatic stress disorder. Journal of Psychiatric Research. Mar. 2010;44(4):224-8. WOS:000276008200006. [pmid: 19793589].
73 Lipper S, Davidson JR, Grady TA, et al. Preliminary study of carbamazepine in post-traumatic stress disorder. Psychosomatics: Journal of Consultation Liaison Psychiatry. 1986;27(12):849. 1988-05318-001.
74 Ljubotina D, Pantic Z, Franciskovic T, et al. Treatment outcomes and perception of social acknowledgment in war veterans: follow-up study. Croat Med J. Apr. 2007;48(2):157-66. [pmid: 17436380].
75 Londborg PD, Hegel MT, Goldstein S, et al. Sertraline treatment of posttraumatic stress disorder: results of 24 weeks of open-label continuation treatment. J Clin Psychiatry. May. 2001;62(5):325-31. [pmid: 11411812].
76 Macklin ML, Metzger LJ, Lasko NB, et al. Five-year follow-up study of eye movement desensitization and reprocessing therapy for combat-related posttraumatic stress disorder. Compr Psychiatry. Jan–Feb. 2000;41(1):24-7. [pmid: 10646615].
77 Malik ML, Connor KM, Sutherland SM, et al. Quality of life and posttraumatic stress disorder: a pilot study assessing changes in SF-36 scores before and after treatment in a placebo-controlled trial of fluoxetine. J Trauma Stress. Apr. 1999;12(2):387-93. [pmid: 10378176].
78 Martenyi F, Brown EB, Zhang H, et al. Fluoxetine v. placebo in prevention of relapse in post-traumatic stress disorder. Br J Psychiatry. Oct. 2002;181:315-20. [pmid: 12356658].
79 McFarlane AC. The treatment of post-traumatic stress disorder. Br J Med Psychol. Mar. 1989;62(Pt 1):81-90. [pmid: 2706201].
80 Meier VJ, Kennedy J, Hope DA. Working on the railroad: reactions to traumatic and stressful events. Depress Anxiety. 1998;7(3):141-4. [pmid: 9656097].
81 Mellman TA, Byers PM, Augenstein JS. Pilot evaluation of hypnotic medication during acute traumatic stress response. Journal of Traumatic Stress. 1998;11(3):563. 1998-10206-009. [pmid: 9690193].
82 Mendes DD, Mello MF, Ventura P, et al. A systematic review on the effectiveness of cognitive behavioral therapy for posttraumatic stress disorder. Int J Psychiatry Med. 2008;38(3):241-59. [pmid: 19069570].
83 Mendes DD, Mello MF, Ventura P, et al. A systematic review on the effectiveness of cognitive behavioral therapy for posttraumatic stress disorder (Structured abstract). International Journal of Psychiatry in Medicine. 2008;38(3):241-59. DARE-12009103724. [pmid: 19069570].
84 Mirabella RF, Frueh BC, Fossey MD. Exposure therapy and antidepressant medication for treatment of chronic PTSD. Am J Psychiatry. Jun. 1995;152(6):955-6. [pmid: 7755135].
85 Monson CM, Rodriguez BF, Warner R. Cognitive-behavioral therapy for PTSD in the real world: do interpersonal relationships make a real difference?. J Clin Psychol. Jun. 2005;61(6):751-61. [pmid: 15546144].
86 Montgomery RW, Ayllon T. Eye movement desensitization across subjects: subjective and physiological measures of treatment efficacy. J Behav Ther Exp Psychiatry. Sep. 1994;25(3):217-30. [pmid: 7852604].
87 Onder E, Tural U, Aker T. A comparative study of fluoxetine, moclobemide, and tianeptine in the treatment of posttraumatic stress disorder following an earthquake. Eur Psychiatry. Apr. 2006;21(3):174-9. [pmid: 15964747].
88 Orth U, Cahill SP, Foa EB, et al. Anger and posttraumatic stress disorder symptoms in crime victims: a longitudinal analysis. J Consult Clin Psychol. Apr. 2008;76(2):208-18. [pmid: 18377118].
89 Ost LG. Efficacy of the third wave of behavioral therapies: A systematic review and meta-analysis. Behaviour Research and Therapy. Mar. 2008;46(3):296-321. WOS:000254784400002. [pmid: 18258216].
90 Palic S, Elklit A. Psychosocial treatment of posttraumatic stress disorder in adult refugees: a systematic review of prospective treatment outcome studies and a critique. J Affect Disord. Jun. 2011;131(1–3):8-23. [pmid: 20708804].
91 Petty F, Davis LL, Nugent AL, et al. Valproate therapy for chronic, combat-induced posttraumatic stress disorder. J Clin Psychopharmacol. Feb. 2002;22(1):100-1. [pmid: 11799355].
92 Pivac N, Kozaric-Kovacic D. Pharmacotherapy of treatment-resistant combat-related posttraumatic stress disorder with psychotic features. Croatian Medical Journal. Jun. 2006;47(3):440-51. WOS:000238513300012. [pmid: 16758523].
93 Pivac N, Kozaric-Kovacic D, Muck-Seler D. Olanzapine versus fluphenazine in an open trial in patients with psychotic combat-related post-traumatic stress disorder. Psychopharmacology (Berl). Oct. 2004;175(4):451-6. [pmid: 15064916].
94 Powers MB, Halpern JM, Ferenschak MP, et al. A meta-analytic review of prolonged exposure for posttraumatic stress disorder. Clin Psychol Rev. Aug. 2010;30(6):635-41. [pmid: 20546985].
95 Ragsdale KG, Cox RD, Finn P, et al. Effectiveness of short-term specialized inpatient treatment for war-related posttraumatic stress disorder: a role for adventure-based counseling and psychodrama. J Trauma Stress. Apr. 1996;9(2):269-83. [pmid: 8731547].
96 Rapaport MH, Endicott J, Clary CM. Posttraumatic stress disorder and quality of life: results across 64 weeks of sertraline treatment. J Clin Psychiatry. Jan. 2002;63(1):59-65. [pmid: 11838628].
97 Reilly PM, Clark HW, Shopshire MS, et al. Anger management and temper control: critical components of posttraumatic stress disorder and substance abuse treatment. J Psychoactive Drugs. Oct–Dec. 1994;26(4):401-7. [pmid: 7884602].
98 Reist C, Kauffmann CD, Chicz-Demet A, et al. REM latency, dexamethasone suppression test, and thyroid releasing hormone stimulation test in posttraumatic stress disorder. Prog Neuropsychopharmacol Biol Psychiatry. May. 1995;19(3):433-43. [pmid: 7624494].
99 Rogers S, Silver SM, Goss J, et al. A single session, group study of exposure and Eye Movement Desensitization and Reprocessing in treating Posttraumatic Stress Disorder among Vietnam War veterans: preliminary data. J Anxiety Disord. Jan–Apr. 1999;13(1–2):119-30. [pmid: 10225504].
100 Rothbaum BO, Davidson JR, Stein DJ, et al. A pooled analysis of gender and trauma-type effects on responsiveness to treatment of PTSD with venlafaxine extended release or placebo. J Clin Psychiatry. Oct. 2008;69(10):1529-39. [pmid: 19192435].
101 Sachsse U, Vogel C, Leichsenring F. Results of psychodynamically oriented trauma-focused inpatient treatment for women with complex posttraumatic stress disorder (PTSD) and borderline personality disorder (BPD). Bulletin of the Menninger Clinic. 2006;70(2):125-44. [pmid: 16753036].
102 Schnurr PP, Friedman MJ, Lavori PW, et al. Design of Department of Veterans Affairs Cooperative Study no. 420: group treatment of posttraumatic stress disorder. Control Clin Trials. Feb. 2001;22(1):74-88. [pmid: 11165426].
103 Schnurr PP, Hayes AF, Lunney CA, et al. Longitudinal analysis of the relationship between symptoms and quality of life in veterans treated for posttraumatic stress disorder. J Consult Clin Psychol. Aug. 2006;74(4):707-13. [pmid: 16881778].
104 Seo HJ, Jung YE, Bahk WM, et al. A comparison of mirtazapine and paroxetine for the treatment of patients with posttraumatic stress disorder: A randomized open-label trial. Clinical Psychopharmacology and Neuroscience. 2010;8(2):84-9.
105 Shalev AY, Orr SP, Pitman RK. Psychophysiologic response during script-driven imagery as an outcome measure in posttraumatic stress disorder. J Clin Psychiatry. Sep. 1992;53(9):324-6. [pmid: 1355475].
106 Shepherd J, Stein K, Milne R. Eye movement desentitization and reprocessing in the treatment of post-traumatic stress disorder: a review of an emerging therapy. Psychological Medicine. Jul. 2000;30(4):863-71. WOS:000088965900014. [pmid: 11037095].
107 Sherman JJ. Effects of psychotherapeutic treatments for PTSD: A meta-analysis of controlled clinical trials. Journal of Traumatic Stress. 1998;11(3):413. 1998-10206-001. [pmid: 9690185].
108 Silver SM, Brooks A, Obenchain J. Treatment of Vietnam War veterans with PTSD: a comparison of eye movement desensitization and reprocessing, biofeedback, and relaxation training. J Trauma Stress. Apr. 1995;8(2):337-42. [pmid: 7627447].
109 Smajkic A, Weine S, Duric-Bijedic Z, et al. Sertralilne, paroxetine and venlafaxine in refugee post traumatic stress disorder with depression symptoms. Med Arh. 2001;55(1 Suppl 1):35-8. [pmid: 11795192].
110 Sonne SC, Back SE, Diaz Zuniga C, et al. Gender differences in individuals with comorbid alcohol dependence and post-traumatic stress disorder. The American journal on addictions/American Academy of Psychiatrists in Alcoholism and Addictions. 2003;(5):412-23. CN-00472127. [pmid: 14660155].
111 Stalker CA, Palmer SE, Wright DC, et al. Specialized inpatient trauma treatment for adults abused as children: a follow-up study. Am J Psychiatry. Mar. 2005;162(3):552-9. [pmid: 15741473].
112 Stein DJ, Davidson J, Seedat S, et al. Paroxetine in the treatment of post-traumatic stress disorder: Pooled analysis of placebo-controlled studies. Expert Opinion on Pharmacotherapy. 2003;4(10):1829-38. [pmid: 14521492].
113 Stein DJ, Ipser JC, Seedat S. Pharmacotherapy for post traumatic stress disorder (PTSD). Cochrane Database of Systematic Reviews. 2006;(1). WOS:000234978200105.
114 Stein DJ, Pedersen R, Rothbaum BO, et al. Onset of activity and time to response on individual CAPS-SX17 items in patients treated for post-traumatic stress disorder with venlafaxine ER: a pooled analysis. Int J Neuropsychopharmacol. Feb. 2009;12(1):23-31. [pmid: 18544181].
115 Stein DJ, Seedat S, van der Linden GJH, et al. Selective serotonin reuptake inhibitors in the treatment of post-traumatic stress disorder: a metaanalysis of randomized controlled trials. International Clinical Psychopharmacology. Aug. 2000;15:S31-S9. WOS:000165071100006. [pmid: 11110017].
116 Stein DJ, van der Kolk BA, Austin C, et al. Efficacy of sertraline in posttraumatic stress disorder secondary to interpersonal trauma or childhood abuse. Ann Clin Psychiatry. Oct–Dec. 2006;18(4):243-9. [pmid: 17162624].
117 Stein MB, Roy-Byrne PP, Craske MG, et al. Quality of and patient satisfaction with primary health care for anxiety disorders. J Clin Psychiatry. 2011:970-6. [pmid: 21367351].
118 Stewart CL, Wrobel TA. Evaluation of the Efficacy of Pharmacotherapy and Psychotherapy in Treatment of Combat-Related Post-Traumatic Stress Disorder: A Meta-Analytic Review of Outcome Studies. Military Medicine. May. 2009;174(5):460-9. WOS:000278059800004. [pmid: 20731275].
119 Tarrier N, Sommerfield C. Treatment of chronic PTSD by cognitive therapy and exposure: 5-year follow-up. Behavior Therapy. 2004;35(2):231-46.
120 Taylor JE, Harvey ST. A meta-analysis of the effects of psychotherapy with adults sexually abused in childhood. Clin Psychol Rev. Aug. 2010;30(6):749-67. [pmid: 20579790].
121 Taylor S. Outcome predictors for three PTSD treatments: Exposure therapy, EMDR, and relaxation training. Journal of Cognitive Psychotherapy: An International Quarterly. 2003;17(2):149-62.
122 Thorp SR, Stein MB, Jeste DV, et al. Prolonged Exposure Therapy for Older Veterans With Posttraumatic Stress Disorder: A Pilot Study. American Journal of Geriatric Psychiatry. Mar. 2012;20(3):276-80. WOS:000300642300010. [pmid: 22273763].
123 Tucker P, Beebe KL, Burgin C, et al. Paroxetine treatment of depression with posttraumatic stress disorder: effects on autonomic reactivity and cortisol secretion. J Clin Psychopharmacol. Apr. 2004;24(2):131-40. [pmid: 15206659].
124 Tuerk PW, Yoder M, Grubaugh A, et al. Prolonged exposure therapy for combat-related posttraumatic stress disorder: an examination of treatment effectiveness for veterans of the wars in Afghanistan and Iraq. J Anxiety Disord. Apr. 2011;25(3):397-403. [pmid: 21131170].
125 Van Etten ML, Taylor S. Comparative efficacy of treatments for post-traumatic stress disorder: A meta-analysis. Clinical Psychology & Psychotherapy. Sep. 1998;5(3):126-44. WOS:000076455300001.
126 van Minnen A, Foa EB. The effect of imaginal exposure length on outcome of treatment for PTSD. J Trauma Stress. Aug. 2006;19(4):427-38. [pmid: 16929519].
127 Vermetten E, Vythilingam M, Schmahl C, et al. Alterations in stress reactivity after long-term treatment with paroxetine in women with posttraumatic stress disorder. Ann N Y Acad Sci. Jul. 2006;1071:184-202. [pmid: 16891570].
128 Wells A, Welford M, Fraser J, et al. Chronic PTSD treated with metacognitive therapy: An open trial. Cognitive and Behavioral Practice. 2008;15(1):85. 2009-06467-010.
129 White NS. Posttraumatic stress disorder. Hosp Community Psychiatry. Nov. 1983;34(11):1061-2. [pmid: 6642454].
130 Zaidi LY. Group treatment of adult male inpatients abused as children. J Trauma Stress. Oct. 1994;7(4):718-27. [pmid: 7820361].
131 Zimmermann P, Biesold KH, Barre K, et al. Long-term course of post-traumatic stress disorder (PTSD) in German soldiers: effects of inpatient eye movement desensitization and reprocessing therapy and specific trauma characteristics in patients with non-combat-related PTSD. Mil Med. May. 2007;172(5):456-60. [pmid: 17521089].

## Excluded for Wrong Population

1 Abbass Allan A, Hancock Jeffrey T, Henderson J, et al. Short-term psychodynamic psychotherapies for common mental disorders. Cochrane Database of Systematic Reviews. 2006;(4):CD004687.
2 Adenauer H, Catani C, Gola H, et al. Narrative exposure therapy for PTSD increases top-down processing of aversive stimuli - evidence from a randomized controlled treatment trial. Bmc Neuroscience. Dec. 2011:12. WOS:000299090600001. [pmid: 21251262].
3 Amaro H, Dai J, Arevalo S, et al. Effects of integrated trauma treatment on outcomes in a racially/ethnically diverse sample of women in urban community-based substance abuse treatment. J Urban Health. Jul. 2007;84(4):508-22. [pmid: 17356904].
4 Arabia E, Manca ML, Solomon RM. EMDR for survivors of life-threatening cardiac events: results of a pilot study. Journal of EMDR Practice and Research. 2011;5(1):2-13.
5 Bachar E, Canetti L, Yonah I, et al. Group versus individual supportive - Expressive psychotherapy for chronic, symptomatically stabilized outpatients. Psychotherapy Research. 2004;14(2):244-51.
6 Bisson JI, Jenkins PL, Alexander J, et al. Randomised controlled trial of psychological debriefing for victims of acute burn trauma. Br J Psychiatry. Jul. 1997;171:78-81. [pmid: 9328501].
7 Blanchard EB, Hickling EJ, Malta LS, et al. Prediction of response to psychological treatment among motor vehicle accident survivors with PTSD. Behavior Therapy. Sum. 2003;34(3):351-63. WOS:000187894900005.
8 Blanchard EB, Hickling EJ, Veazey CH, et al. Treatment-related changes in cardiovascular reactivity to trauma cues in motor vehicle accident-related PTSD. Behavior Therapy. Sum. 2002;33(3):417-26. WOS:000177020600005.
9 Boals A, Banks JB, Hayslip B. A self-administered, mild form of exposure therapy for older adults. Aging Ment Health. 2012;16(2):154-61. [pmid: 21830863].
10 Bower P, Knowles S, Coventry Peter A, et al. Counselling for mental health and psychosocial problems in primary care. Cochrane Database of Systematic Reviews. 2011;(9):CD001025.
11 Bradley RG, Follingstad DR. Group therapy for incarcerated women who experienced interpersonal violence: a pilot study. J Trauma Stress. Aug. 2003;16(4):337-40. [pmid: 12895016].
12 Bryant RA, Ekasawin S, Chakrabhand S, et al. A randomized controlled effectiveness trial of cognitive behavior therapy for post-traumatic stress disorder in terrorist-affected people in Thailand. World Psychiatry. 2011;10(3):205-9. [pmid: 21991280].
13 Bryant RA, Guthrie RM, Moulds ML, et al. Hypnotizability and posttraumatic stress disorder: a prospective study. Int J Clin Exp Hypn. Oct. 2003;51(4):382-9. [pmid: 14594186].
14 Classen CC, Palesh OG, Cavanaugh CE, et al. A Comparison of Trauma-Focused and Present-Focused Group Therapy for Survivors of Childhood Sexual Abuse: A Randomized Controlled Trial. Psychological Trauma-Theory Research Practice and Policy. Mar. 2011;3(1):84-93. WOS:000289034000012.
15 Cohen LR, Greenfield SF, Gordon S, et al. Survey of eating disorder symptoms among women in treatment for substance abuse. Am J Addict. May–Jun. 2010;19(3):245-51. [pmid: 20525031].
16 Cooper J, Carty J, Creamer M. Pharmacotherapy for posttraumatic stress disorder: empirical review and clinical recommendations. Australian and New Zealand Journal of Psychiatry. Aug. 2005;39(8):674-82. WOS:000230768800005. [pmid: 16050921].
17 Craske MG, Stein MB, Sullivan G, et al. Disorder-specific impact of coordinated anxiety learning and management treatment for anxiety disorders in primary care. Arch Gen Psychiatry. Apr. 2011;68(4):378-88. [pmid: 21464362].
18 Davis JL, Rhudy JL, Pruiksma KE, et al. Physiological predictors of response to exposure, relaxation, and rescripting therapy for chronic nightmares in a randomized clinical trial. J Clin Sleep Med. Dec. 15. 2011;7(6):622-31. [pmid: 22171201].
19 Duffy M, Gillespie K, Clark DM. Post-traumatic stress disorder in the context of terrorism and other civil conflict in Northern Ireland: Randomised controlled trial. British Medical Journal. 2007;334(7604):1147-50. [pmid: 17495988].
20 DuHamel KN, Mosher CE, Winkel G, et al. Randomized clinical trial of telephone-administered cognitive-behavioral therapy to reduce post-traumatic stress disorder and distress symptoms after hematopoietic stem-cell transplantation. J Clin Oncol. Aug. 10. 2010;28(23):3754-61. [pmid: 20625129].
21 Dunn TM, Schwartz M, Hatfield RW, et al. Measuring effectiveness of eye movement desensitization and reprocessing (EMDR) in non-clinical anxiety: a multi-subject, yoked-control design. J Behav Ther Exp Psychiatry. Sep. 1996;27(3):231-9. [pmid: 8959424].
22 Eames P, Wood R. Rehabilitation after severe brain injury: a follow-up study of a behaviour modification approach. J Neurol Neurosurg Psychiatry. Jul. 1985;48(7):613-9. [pmid: 4031905].
23 Edmond T, Rubin A. Assessing the long-term effects of EMDR: results from an 18-month follow-up study with adult female survivors of CSA. J Child Sex Abus. 2004;13(1):69-86. [pmid: 15353377].
24 Edmond T, Rubin A, Wambach KG. The effectiveness of EMDR with adult female survivors of childhood sexual abuse... eye movement desensitization and reprocessing. Social Work Research. 1999;23(2):103-16. Language: English. Entry Date: 19990901. Revision Date: 20091218. Publication Type: journal article.
25 Fava GA, Ruini C, Rafanelli C. Sequential treatment of mood and anxiety disorders. Journal of Clinical Psychiatry. Nov. 2005;66(11):1392-400. WOS:000233628800008. [pmid: 16420076].
26 Foa EB, Zoellner LA, Feeny NC. An evaluation of three brief programs for facilitating recovery after assault. J Trauma Stress. Feb. 2006;19(1):29-43. [pmid: 16568461].
27 Ford JD, Chandler P, Thacker B, et al. Family systems therapy after Operation Desert Storm with European-theater veterans. J Marital Fam Ther. Apr. 1998;24(2):243-50. [pmid: 9583063].
28 Ghee AC, Bolling LC, Johnson CS. The efficacy of a condensed Seeking Safety intervention for women in residential chemical dependence treatment at 30 days posttreatment. Journal of Child Sexual Abuse. 2009;18(5):475-88. [pmid: 20183413].
29 Ginzburg K, Butler LD, Giese-Davis J, et al. Shame, guilt, and posttraumatic stress disorder in adult survivors of childhood sexual abuse at risk for human immunodeficiency virus: outcomes of a randomized clinical trial of group psychotherapy treatment. J Nerv Ment Dis. Jul. 2009;197(7):536-42. [pmid: 19597362].
30 Grainger RD, Levin C, Allen-Byrd L, et al. An empirical evaluation of eye movement desensitization and reprocessing (EMDR) with survivors of a natural disaster. J Trauma Stress. Oct. 1997;10(4):665-71. [pmid: 9391949].
31 Hagenaars MA, Arntz A. Reduced intrusion development after post-trauma imagery rescripting; an experimental study. J Behav Ther Exp Psychiatry. Jun. 2012;43(2):808-14. [pmid: 22178473].
32 Harris JI, Erbes CR, Engdahl BE, et al. The effectiveness of a trauma focused spiritually integrated intervention for veterans exposed to trauma. J Clin Psychol. Apr. 2011;67(4):425-38. [pmid: 21294116].
33 Heide FJJ, Mooren GTM, Kleijn WC, et al. EMDR versus stabilisation in traumatised asylum seekers and refugees: results of a pilot study. European Journal of Psychotraumatology. 2011:2. (Journal Article):Article 5881.
34 Hobbs M, Mayou R, Harrison B, et al. A randomised controlled trial of psychological debriefing for victims of road traffic accidents. BMJ. Dec. 7. 1996;313(7070):1438-9. [pmid: 8973231].
35 Johnson DR, Lubin H. Effect of brief versus long-term inpatient treatment on homecoming stress in combat-related posttraumatic stress disorder: Three-year follow-up. Journal of Nervous and Mental Disease. 2002;190(1):47-51. [pmid: 11838033].
36 Kaiser EM. Efficacy of sensory learning program as treatment modality for complex. PTSD dissertation. University of the Rockies. 2007.
37 Knaevelsrud C, Maercker A. Internet-based treatment for PTSD reduces distress and facilitates the development of a strong therapeutic alliance: a randomized controlled clinical trial. BMC Psychiatry. 2007;7:13. [pmid: 17442125].
38 Kosters M, Burlingame GM, Nachtigall C, et al. A meta-analytic review of the effectiveness of inpatient group psychotherapy. Group Dynamics-Theory Research and Practice. Jun. 2006;10(2):146-63. WOS:000238552200005.
39 Kreidler M. Group therapy for survivors of childhood sexual abuse who have chronic mental illness. Archives of psychiatric nursing. 2005;(4):176-83. CN-00523761. [pmid: 16088856].
40 Lande RG, Williams LB, Francis JL, et al. Efficacy of biofeedback for post-traumatic stress disorder. Complement Ther Med. Dec. 2010;18(6):256-9. [pmid: 21130362].
41 Lange A, Rietdijk D, Hudcovicova M, et al. Interapy: A controlled randomized trial of the standardized treatment of posttraumatic stress through the Internet. Journal of Consulting and Clinical Psychology. Oct. 2003;71(5):901-9. WOS:000185426100005. [pmid: 14516238].
42 Lange A, van de Ven JP, Schrieken B, et al. Interapy, treatment of posttraumatic stress through the Internet: a controlled trial. J Behav Ther Exp Psychiatry. Jun. 2001;32(2):73-90. [pmid: 11764063].
43 Lester KM, Milby JB, Schumacher JE, et al. Impact of behavioral contingency management intervention on coping behaviors and PTSD symptom reduction in cocaine-addicted homeless. J Trauma Stress. Aug. 2007;20(4):565-75. [pmid: 17721968].
44 Levine EG, Eckhardt J, Targ E. Change in post-traumatic stress symptoms following psychosocial treatment for breast cancer. Psychooncology. Aug. 2005;14(8):618-35. [pmid: 15651074].
45 Lundqvist G, Svedin CG, Hansson K, et al. Group therapy for women sexually abused as children: mental health before and after group therapy. J Interpers Violence. Dec. 2006;21(12):1665-77. [pmid: 17065660].
46 Lynch SM, Heath NM, Mathews KC, et al. Seeking safety: an intervention for trauma-exposed incarcerated women?. J Trauma Dissociation. 2012;13(1):88-101. [pmid: 22211443].
47 Macdonald A. Identifying patterns of symptom change during Cognitive Processing Therapy for Posttraumatic Stress Disorder dissertation. Boston University. 2009.
48 Maercker A, Zollner T, Menning H, et al. Dresden PTSD treatment study: randomized controlled trial of motor vehicle accident survivors. BMC Psychiatry. 2006;6:29. [pmid: 16824221].
49 McWhirter PT. Differential therapeutic outcomes of community-based group interventions for women and children exposed to intimate partner violence. J Interpers Violence. 2011:2457-82. [pmid: 20889533].
50 Meffert SM, Abdo AO, Abd Alla OA, et al. A pilot randomized controlled trial of interpersonal psychotherapy for Sudanese refugees in Cairo, Egypt. Psychological Trauma: Theory, Research, Practice, and Policy. 2011. (Journal Article).
51 Michelson L, June K, Vives A, et al. The role of trauma and dissociation in cognitive-behavioral psychotherapy outcome and maintenance for panic disorder with agoraphobia. Behav Res Ther. Nov. 1998;36(11):1011-50. [pmid: 9737056].
52 Mooren TTM, de Jong K, Kleber RJ, et al. The efficacy of a mental health program in Bosnia-Herzegovina: Impact on coping and general health. Journal of Clinical Psychology. Jan. 2003;59(1):57-69. WOS:000180262200005. [pmid: 12508331].
53 Pacella ML, Armelie AP, Boarts JM, et al. The impact of prolonged exposure on PTSD symptoms and associated psychopathology in people living with HIV: a randomized test of concept. AIDS and Behavior. 2011. (Journal Article).
54 Powell GJ, Doan RE. Combat and social support as variables in perceived symptomatology of combat-related posttraumatic stress disorder. Psychol Rep. 1992/06/01. 1992:1187-94. [pmid: 1496093].
55 Reed GL, Enright RD. The effects of forgiveness therapy on depression, anxiety, and posttraumatic stress for women after spousal emotional abuse. J Consult Clin Psychol. Oct. 2006;74(5):920-9. [pmid: 17032096].
56 Renfrey G, Spates CR. Eye movement desensitization: a partial dismantling study. J Behav Ther Exp Psychiatry. Sep. 1994;25(3):231-9. [pmid: 7852605].
57 Resick PA, Jordan CG, Girelli SA, et al. A comparative outcome study of behavioral group therapy for sexual assault victims. Behavior Therapy. 1988;19:385-401.
58 Rhudy JL, Davis JL, Williams AE, et al. Cognitive-behavioral treatment for chronic nightmares in trauma-exposed persons: assessing physiological reactions to nightmare-related fear. J Clin Psychol. Apr. 2010;66(4):365-82. [pmid: 20127794].
59 Roy MJ, Francis J, Friedlander J, et al. Improvement in cerebral function with treatment of posttraumatic stress disorder. Ann N Y Acad Sci. Oct. 2010;1208:142-9. [pmid: 20955336].
60 Ryan M, Nitsun M, Gilbert L, et al. A prospective study of the effectiveness of group and individual psychotherapy for women CSA survivors. Psychol Psychother. Dec. 2005;78(Pt 4):465-79. [pmid: 16354439].
61 Schaal S, Elbert T, Neuner F. Narrative exposure therapy versus interpersonal psychotherapy. A pilot randomized controlled trial with Rwandan genocide orphans. Psychother Psychosom. 2009;78(5):298-306. [pmid: 19628958].
62 Scheck MM, Schaeffer JA, Gillette C. Brief psychological intervention with traumatized young women: the efficacy of eye movement desensitization and reprocessing. J Trauma Stress. Jan. 1998;11(1):25-44. [pmid: 9479674].
63 Schoutrop MJ, Lange A, Hanewald G, et al. Structured writing and processing major stressful events: a controlled trial. Psychotherapy and Psychosomatics. 2002;(3):151-7. CN-00397561. [pmid: 12021557].
64 Shemesh E, Annunziato RA, Weatherley BD, et al. A randomized controlled trial of the safety and promise of cognitive-behavioral therapy using imaginal exposure in patients with posttraumatic stress disorder resulting from cardiovascular illness. J Clin Psychiatry. Feb. 2011;72(2):168-74. [pmid: 20441725].
65 Sijbrandij M, Olff M, Reitsma JB, et al. Treatment of acute posttraumatic stress disorder with brief cognitive behavioral therapy: a randomized controlled trial. Am J Psychiatry. Jan. 2007;164(1):82-90. [pmid: 17202548].
66 Sikkema KJ, Hansen NB, Kochman A, et al. Outcomes from a group intervention for coping with HIV/AIDS and childhood sexual abuse: reductions in traumatic stress. AIDS Behav. Jan. 2007;11(1):49-60. [pmid: 16858634].
67 Solomon Z, Mikulincer M, Avitzur E. Coping, locus of control, social support, and combat-related posttraumatic stress disorder: a prospective study. J Pers Soc Psychol. Aug. 1988;55(2):279-85. [pmid: 3171908].
68 Solomon Z, Mikulincer M, Flum H. Negative life events, coping responses, and combat-related psychopathology: a prospective study. J Abnorm Psychol. Aug. 1988;97(3):302-7. [pmid: 3192822].
69 Spoormaker VI, van den Bout J. Lucid dreaming treatment for nightmares: a pilot study. Psychother Psychosom. 2006;75(6):389-94. [pmid: 17053341].
70 Thompson J, Chung MC, Jackson G, et al. A Comparative Trial of Psychotherapy in the Treatment of Posttrauma Stress Reactions. Clinical Psychology & Psychotherapy. Oct. 1995;2(3):168-76. WOS:A1995TD70200003.
71 Trappler B, Newville H. Trauma healing via cognitive behavior therapy in chronically hospitalized patients. Psychiatric Quarterly. Dec. 2007;78(4):317-25. WOS:000250742900010. [pmid: 17924190].
72 Turner-Stokes L, Nair A, Sedki I, et al. Multi-disciplinary rehabilitation for acquired brain injury in adults of working age. Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2005.
73 Valentine PV, Smith TE. Evaluating traumatic incident reduction therapy with female inmates: A randomized controlled clinical trial. Research on Social Work Practice. 2001;11(1):40. 2000-12588-003.
74 Vaughan K, Armstrong MS, Gold R, et al. A trial of eye movement desensitization compared to image habituation training and applied muscle relaxation in post-traumatic stress disorder. J Behav Ther Exp Psychiatry. Dec. 1994;25(4):283-91. [pmid: 7706505].
75 Verbosky SJ, Ryan DA. Female partners of Vietnam veterans: stress by proximity. Issues Ment Health Nurs. 1988;9(1):95-104. [pmid: 3356550].
76 Wilson DL, Silver SM, Covi WG, et al. Eye movement desensitization and reprocessing: effectiveness and autonomic correlates. J Behav Ther Exp Psychiatry. Sep. 1996;27(3):219-29. [pmid: 8959423].
77 Wilson SA, Becker LA, Tinker RH. Eye movement desensitization and reprocessing (EMDR) treatment for psychologically traumatized individuals. J Consult Clin Psychol. Dec. 1995;63(6):928-37. [pmid: 8543715].
78 Zatzick DF, Roy-Byrne P, Russo JE, et al. Collaborative interventions for physically injured trauma survivors: A pilot randomized effectiveness trial. General Hospital Psychiatry. 2001;23(3):114. 2002-06399-003. [pmid: 11427243].
79 Zhang Y, Feng B, Xie JP, et al. Clinical study on treatment of the earthquake-caused post-traumatic stress disorder by cognitive-behavior therapy and acupoint stimulation. J Tradit Chin Med. Mar. 2011;31(1):60-3. [pmid: 21563510].
80 Ziegenhorn AA, Roepke S, Schommer NC, et al. Clonidine improves hyperarousal in borderline personality disorder with or without comorbid posttraumatic stress disorder: A randomized, double-blind, placebo-controlled trial. Journal of Clinical Psychopharmacology. 2009;29(2):170. 2009-04482-010. [pmid: 19512980].

## Excluded for Wrong Intervention

1 Basoglu M, Salcioglu E, Livanou M, et al. Single-session behavioral treatment of earthquake-related posttraumatic stress disorder: a randomized waiting list controlled trial. J Trauma Stress. Feb. 2005;18(1):1-11. [pmid: 16281190].
2 Bormann JE, Thorp S, Wetherell JL, et al. A spiritually based group intervention for combat veterans with posttraumatic stress disorder: feasibility study. J Holist Nurs. Jun. 2008;26(2):109-16. [pmid: 18356284].
3 Bormann JE, Thorp SR, Wetherell JL, et al. Meditation-based mantram intervention for veterans with posttraumatic stress disorder: a randomized trial. Psychological Trauma: Theory, Research, Practice, and Policy. 2012. (Journal Article).
4 Bostock L, Sheikh AI, Barton S. Posttraumatic growth and optimism in health-related trauma: a systematic review. J Clin Psychol Med Settings. Dec. 2009;16(4):281-96. [pmid: 19730997].
5 Chemtob CM, Novaco RW, Hamada RS, et al. Cognitive-behavioral treatment for severe anger in posttraumatic stress disorder. J Consult Clin Psychol. Feb. 1997;65(1):184-9. [pmid: 9103748].
6 Creamer M, Burgess P, Pattison P. Cognitive processing in post-trauma reactions: some preliminary findings. Psychol Med. Aug. 1990;20(3):597-604. [pmid: 2236368].
7 De Kleine RA, Hendriks GJ, Kusters WJC, et al. A randomized placebo-controlled trial of d-cycloserine to enhance exposure therapy for posttraumatic stress disorder. Biological Psychiatry. 2012;71(11):962-8. [pmid: 22480663].
8 Dunn NJ, Rehm LP, Schillaci J, et al. A randomized trial of self-management and psychoeducational group therapies for comorbid chronic posttraumatic stress disorder and depressive disorder. J Trauma Stress. Jun. 2007;20(3):221-37. [pmid: 17598141].
9 Heresco-Levy U, Kremer I, Javitt DC, et al. Pilot-controlled trial of D-cycloserine for the treatment of post-traumatic stress disorder. International Journal of Neuropsychopharmacology. 2002;5(4):301. 2003-01124-004. [pmid: 12466030].
10 Heresco-Levy U, Vass A, Bloch B, et al. Pilot controlled trial of D-serine for the treatment of post-traumatic stress disorder. International Journal of Neuropsychopharmacology. 2009;12(9):1275. 2009-18028-011. [pmid: 19366490].
11 Igreja V, Kleijn WC, Schreuder BJ, et al. Testimony method to ameliorate post-traumatic stress symptoms. Community-based intervention study with Mozambican civil war survivors. Br J Psychiatry. Mar. 2004;184:251-7. [pmid: 14990524].
12 Johnsen BH, Eid J, Laberg JC, et al. The effect of sensitization and coping style on post-traumatic stress symptoms and quality of life: two longitudinal studies. Scand J Psychol. Apr. 2002;43(2):181-8. [pmid: 12004957].
13 Johnson DR, Rosenheck R, Fontana A, et al. Outcome of intensive inpatient treatment for combat-related posttraumatic stress disorder. Am J Psychiatry. Jun. 1996;153(6):771-7. [pmid: 8633688].
14 Katz R, Lott MH, Arbus P, et al. Pharmacotherapy of Posttraumatic-Stress-Disorder with a Novel Psychotropic. Anxiety. 1994;1(4):169-74. WOS:A1994QV62100003. [pmid: 9160569].
15 Kent M, Davis MC, Stark SL, et al. A resilience-oriented treatment for posttraumatic stress disorder: Results of a preliminary randomized clinical trial. Journal of traumatic stress. 2011;24(5):591-5. [pmid: 21898603].
16 Mathew SJ, Vythilingam M, Murrough JW, et al. A selective neurokinin-1 receptor antagonist in chronic PTSD: A randomized, double-blind, placebo-controlled, proof-of-concept trial. European Neuropsychopharmacology. 2011;21(3):221. 2011-02529-005. [pmid: 21194898].
17 Morland LA, Greene CJ, Rosen CS, et al. Telemedicine for anger management therapy in a rural population of combat veterans with posttraumatic stress disorder: a randomized noninferiority trial. J Clin Psychiatry. Jul. 2010;71(7):855-63. [pmid: 20122374].
18 Murphy RT, Thompson KE, Murray M, et al. Effect of a motivation enhancement intervention on veteransâ€™ engagement in PTSD treatment. Psychological Services. 2009;6(4):264. 2009-21337-003.
19 Murphy SA. Evidence-based interventions for parents following their children's violent deaths. Rynearson Edward K, editor. Violent death: resilience and intervention beyond the crisis. New York. Routledge. 2006.
20 Niles BL, Klunk-Gillis J, Ryngala DJ, et al. Comparing mindfulness and psychoeducation treatments for combat-related ptsd using a telehealth approach. Psychological Trauma: Theory, Research, Practice, and Policy. 2011. (Journal Article).
21 Osuch EA, Benson BE, Luckenbaugh DA, et al. Repetitive TMS combined with exposure therapy for PTSD: A preliminary study. Journal of Anxiety Disorders. 2009;23(1):54-9. [pmid: 18455908].
22 Palic S, Elklit A. An explorative outcome study of CBT-based multidisciplinary treatment in a diverse group of refugees from a Danish treatment centre for rehabilitation of traumatized refugees. Torture. 2009;19(3):248-70. [pmid: 20065543].
23 Rabe S, Zoellner T, Beauducel A, et al. Changes in brain electrical activity after cognitive behavioral therapy for posttraumatic stress disorder in patients injured in motor vehicle accidents. Psychosom Med. Jan. 2008;70(1):13-9. [pmid: 17991819].
24 Salcioglu E, Basoglu M, Livanou M. Effects of live exposure on symptoms of posttraumatic stress disorder: the role of reduced behavioral avoidance in improvement. Behav Res Ther. Oct. 2007;45(10):2268-79. [pmid: 17570342].
25 Shestatzky M, Greenberg D, Lerer B. A controlled trial of phenelzine in posttraumatic stress disorder. Psychiatry Research. 1988;24(2):149. 1989-12914-001. [pmid: 3406235].
26 Sloan DM, Marx BP, Greenberg EM. A test of written emotional disclosure as an intervention for posttraumatic stress disorder. Behav Res Ther. Apr. 2011;49(4):299-304. [pmid: 21367400].
27 Teng EJ, Bailey SD, Chaison AD, et al. Treating comorbid panic disorder in veterans with posttraumatic stress disorder. J Consult Clin Psychol. Aug. 2008;76(4):704-10. [pmid: 18665698].
28 Wells A, Colbear JS. Treating Posttraumatic Stress Disorder With Metacognitive Therapy: A Preliminary Controlled Trial. J Clin Psychol. Apr. 2012;68(4):373-81. WOS:000302073400002.
29 Yeomans PD, Forman EM, Herbert JD, et al. A randomized trial of a reconciliation workshop with and without PTSD psychoeducation in Burundian sample. Journal of traumatic stress. 2010;23(3):305-12. [pmid: 20564362].

## Excluded for Wrong Comparator

1 Abramowitz EG, Barak Y, Ben-Avi I, et al. Hypnotherapy in the treatment of chronic combat-related PTSD patients suffering from insomnia: a randomized, zolpidem-controlled clinical trial. Int J Clin Exp Hypn. Jul. 2008;56(3):270-80. [pmid: 18569138].
2 Boehnlein JK, Kinzie JD, Ben R, et al. One-year follow-up study of posttraumatic stress disorder among survivors of Cambodian concentration camps. Am J Psychiatry. Aug. 1985;142(8):956-9. [pmid: 4025594].
3 Cusack K, Spates CR. The cognitive dismantling of Eye Movement Desensitization and Reprocessing (EMDR) treatment of Posttraumatic Stress Disorder (PTSD). J Anxiety Disord. Jan–Apr. 1999;13(1–2):87-99. [pmid: 10225502].
4 David D, De Faria L, Lapeyra O, et al. Adjunctive risperidone treatment in combat veterans with chronic PTSD. J Clin Psychopharmacol. Oct. 2004;24(5):556-9. [pmid: 15349018].
5 Franciskovic T, Sukovic Z, Janovic S, et al. Tianeptine in the combined treatment of combat related posttraumatic stress disorder. Psychiatr Danub. Sep. 2011;23(3):257-63. [pmid: 21963693].
6 Frueh BC, Monnier J, Yim E, et al. A randomized trial of telepsychiatry for post-traumatic stress disorder. J Telemed Telecare. 2007;13(3):142-7. [pmid: 17519056].
7 Germain V, Marchand A, Bouchard S, et al. Effectiveness of cognitive behavioural therapy administered by videoconference for posttraumatic stress disorder. Cogn Behav Ther. 2009;38(1):42-53. [pmid: 19235601].
8 Gros DF, Yoder M, Tuerk PW, et al. Exposure therapy for PTSD delivered to veterans via telehealth: predictors of treatment completion and outcome and comparison to treatment delivered in person. Behav Ther. Jun. 2011;42(2):276-83. [pmid: 21496512].
9 Grunert BK, Devine CA, Smith CJ, et al. Graded work exposure to promote work return after severe hand trauma: a replicated study. Ann Plast Surg. Dec. 1992;29(6):532-6. [pmid: 1361315].
10 Hembree EA, Street GP, Riggs DS, et al. Do assault-related variables predict response to cognitive behavioral treatment for PTSD?. J Consult Clin Psychol. Jun. 2004;72(3):531-4. [pmid: 15279536].
11 Hofmann SG, Smits JA. Cognitive-behavioral therapy for adult anxiety disorders: a meta-analysis of randomized placebo-controlled trials (Structured abstract). Journal of Clinical Psychiatry. 2008;(4):621-32. DARE-12008107657. [pmid: 18363421].
12 Karatzias A, Power K, McGoldrick T, et al. Predicting treatment outcome on three measures for post-traumatic stress disorder. Eur Arch Psychiatry Clin Neurosci. Feb. 2007;257(1):40-6. [pmid: 16915361].
13 Kinzie JD, Leung P. Clonidine in Cambodian patients with posttraumatic stress disorder. J Nerv Ment Dis. Sep. 1989;177(9):546-50. [pmid: 2769247].
14 Kosten TR, Krystal JH, Giller EL, et al. Alexithymia as a predictor of treatment response in post-traumatic stress disorder. Journal of Traumatic Stress. 1992;5(4):563-73. 1993-18480-001.
15 Labbate LA, Sonne SC, Randal CL, et al. Does comorbid anxiety or depression affect clinical outcomes in patients with post-traumatic stress disorder and alcohol use disorders?. Compr Psychiatry. Jul–Aug. 2004;45(4):304-10. [pmid: 15224273].
16 Lerer B, Bleich A, Kotler M, et al. Posttraumatic stress disorder in Israeli combat veterans. Effect of phenelzine treatment. Arch Gen Psychiatry. Nov. 1987;44(11):976-81. [pmid: 3314769].
17 Lunney CA, Schnurr PP. Domains of quality of life and symptoms in male veterans treated for posttraumatic stress disorder. J Trauma Stress. Dec. 2007;20(6):955-64. [pmid: 18157892].
18 Marmar CR, Schoenfeld F, Weiss DS, et al. Open trial of fluvoxamine treatment for combat-related posttraumatic stress disorder. J Clin Psychiatry. Suppl 8. 1996;57:66-70. discussion 1–2. [pmid: 8698684].
19 Marsh LK, Spates CR. The effects of writing therapy in comparison to EMD/R on traumatic stress: the relationship between hypnotizability and client expectancy to outcome. Professional Psychology: Research and Practice. 2002;33(6):581-6.
20 McDougle CJ, Southwick SM, Charney DS, et al. An open trial of fluoxetine in the treatment of posttraumatic stress disorder. J Clin Psychopharmacol. Oct. 1991;11(5):325-7. [pmid: 1765575].
21 McGovern MP, Lambert-Harris C, Alterman AI, et al. A randomized controlled trial comparing integrated cognitive behavioral therapy versus individual addiction counseling for co-occurring substance use and posttraumatic stress disorders. Journal of Dual Diagnosis. 2011;7(4):207-27. [pmid: 22383864].
22 Monson CM, Gradus JL, Young-Xu Y, et al. Change in posttraumatic stress disorder symptoms: do clinicians and patients agree?. Psychol Assess. Jun. 2008;20(2):131-8. [pmid: 18557690].
23 Morland LA, Hynes AK, Mackintosh MA, et al. Group cognitive processing therapy delivered to veterans via telehealth: a pilot cohort. J Trauma Stress. Aug. 2011;24(4):465-9. [pmid: 21793047].
24 Nagy LM, Morgan CA 3rd, Southwick SM, et al. Open prospective trial of fluoxetine for posttraumatic stress disorder. J Clin Psychopharmacol. Apr. 1993;13(2):107-13. [pmid: 8463442].
25 Otte C, Wiedemann K, Yassouridis A, et al. Valproate monotherapy in the treatment of civilian patients with non-combat-related posttraumatic stress disorder: an open-label study. J Clin Psychopharmacol. Feb. 2004;24(1):106-8. [pmid: 14709964].
26 Perconte ST, Griger ML. Comparison of successful, unsuccessful, and relapsed Vietnam veterans treated for posttraumatic stress disorder. J Nerv Ment Dis. Sep. 1991;179(9):558-62. [pmid: 1919558].
27 Resick PA, Galovski TE, O'Brien Uhlmansiek M, et al. A randomized clinical trial to dismantle components of cognitive processing therapy for posttraumatic stress disorder in female victims of interpersonal violence. J Consult Clin Psychol. Apr. 2008;76(2):243-58. [pmid: 18377121].
28 Richards DA, Lovell K, Marks IM. Post-traumatic stress disorder: evaluation of a behavioral treatment program. J Trauma Stress. Oct. 1994;7(4):669-80. [pmid: 7820356].
29 Servan-Schreiber D, Schooler J, Dew MA, et al. Eye movement desensitization and reprocessing for posttraumatic stress disorder: a pilot blinded, randomized study of stimulation type. Psychother Psychosom. 2006;75(5):290-7. [pmid: 16899965].
30 Spiegel D, Hunt T, Dondershine HE. Dissociation and hypnotizability in posttraumatic stress disorder. Am J Psychiatry. Mar. 1988;145(3):301-5. [pmid: 3344845].
31 van den Berg DP, van der Gaag M. Treating trauma in psychosis with EMDR: a pilot study. J Behav Ther Exp Psychiatry. Mar. 2012;43(1):664-71. [pmid: 21963888].
32 Watson CG, Tuorila JR, Vickers KS, et al. The efficacies of three relaxation regimens in the treatment of PTSD in Vietnam War veterans. J Clin Psychol. Dec. 1997;53(8):917-23. [pmid: 9403395].
33 Wolf GK, Strom TQ, Kehle SM, et al. A Preliminary Examination of Prolonged Exposure Therapy With Iraq and Afghanistan Veterans With a Diagnosis of Posttraumatic Stress Disorder and Mild to Moderate Traumatic Brain Injury. Journal of Head Trauma Rehabilitation. Jan–Feb. 2012;27(1):26-32. WOS:000299326400003. [pmid: 22218201].

## Excluded for Wrong Outcome

1 Classen CC, Koopman C, Nevill-Manning K, et al. A preliminary report comparing trauma-focused and present-focused group therapy against a wait-listed condition among childhood sexual abuse survivors with PTSD. Journal of Aggression, Maltreatment and Trauma. 2001;4(2):265-88.
2 Coffey SF, Stasiewicz PR, Hughes PM, et al. Trauma-focused imaginal exposure for individuals with comorbid posttraumatic stress disorder and alcohol dependence: revealing mechanisms of alcohol craving in a cue reactivity paradigm. Psychol Addict Behav. Dec. 2006;20(4):425-35. [pmid: 17176177].
3 Davidson JR, Connor KM, Hertzberg MA, et al. Maintenance therapy with fluoxetine in posttraumatic stress disorder: a placebo-controlled discontinuation study. Journal of Clinical Psychopharmacology. 2005;(2):166-9. CN-00514906. [pmid: 15738748].
4 Foa EB, Rauch SA. Cognitive changes during prolonged exposure versus prolonged exposure plus cognitive restructuring in female assault survivors with posttraumatic stress disorder. J Consult Clin Psychol. Oct. 2004;72(5):879-84. [pmid: 15482045].
5 Galovski TE, Monson C, Bruce SE, et al. Does cognitive-behavioral therapy for PTSD improve perceived health and sleep impairment?. J Trauma Stress. Jun. 2009;22(3):197-204. [pmid: 19466746].
6 Gerardi M, Rothbaum BO, Astin MC, et al. Cortisol response following exposure treatment for PTSD in rape victims. Journal of Aggression, Maltreatment and Trauma. 2010;19(4):349-56.
7 Glynn SM, Eth S, Randolph ET, et al. A test of behavioral family therapy to augment exposure for combat-related posttraumatic stress disorder. J Consult Clin Psychol. Apr. 1999;67(2):243-51. [pmid: 10224735].
8 Grasso DJ, Cohen LH, Moser JS, et al. Seeing the silver lining: potential benefits of trauma exposure in college students. Anxiety Stress Coping. Mar. 2012;25(2):117-36. [pmid: 21424946].
9 Hertzberg MA, Moore SD, Feldman ME, et al. A preliminary study of bupropion sustained-release for smoking cessation in patients with chronic posttraumatic stress disorder. J Clin Psychopharmacol. Feb. 2001;21(1):94-8. [pmid: 11199956].
10 Hien DA, Campbell AN, Killeen T, et al. The impact of trauma-focused group therapy upon HIV sexual risk behaviors in the NIDA Clinical Trials Network “Women and trauma” multi-site study. AIDS Behav. Apr. 2010;14(2):421-30. [pmid: 19452271].
11 Karl A, Malta LS, Alexander J, et al. Startle responses in motor vehicle accident survivors: A pilot study. Applied Psychophysiology Biofeedback. 2004;29(3):223-31.
12 Knaevelsrud C, Liedl A, Maercker A. Posttraumatic growth, optimism and openness as outcomes of a cognitive-behavioural intervention for posttraumatic stress reactions. J Health Psychol. Oct. 2010;15(7):1030-8. [pmid: 20511285].
13 Lester K, Resick PA, Young-Xu Y, et al. Impact of race on early treatment termination and outcomes in posttraumatic stress disorder treatment. J Consult Clin Psychol. Aug. 2010;78(4):480-9. [pmid: 20658805].
14 Lindauer RJ, Vlieger EJ, Jalink M, et al. Effects of psychotherapy on hippocampal volume in out-patients with post-traumatic stress disorder: a MRI investigation. Psychol Med. Oct. 2005;35(10):1421-31. [pmid: 16164766].
15 Lindauer RT, van Meijel EP, Jalink M, et al. Heart rate responsivity to script-driven imagery in posttraumatic stress disorder: specificity of response and effects of psychotherapy. Psychosom Med. Jan–Feb. 2006;68(1):33-40. [pmid: 16449409].
16 Macdonald A, Monson CM, Doron-Lamarca S, et al. Identifying Patterns of Symptom Change During a Randomized Controlled Trial of Cognitive Processing Therapy for Military-Related Posttraumatic Stress Disorder. Journal of Traumatic Stress. Jun. 2011;24(3):268-76. WOS:000291350300004. [pmid: 21626572].
17 Morgan T, Cummings AL. Change experienced during group therapy by female survivors of childhood sexual abuse. J Consult Clin Psychol. Feb. 1999;67(1):28-36. [pmid: 10028206].
18 Moser JS, Cahill SP, Foa EB. Evidence for poorer outcome in patients with severe negative trauma-related cognitions receiving prolonged exposure plus cognitive restructuring. Journal of Nervous and Mental Disease. 2010;198(1):72-5. [pmid: 20061873].
19 Nishith P, Nixon RD, Resick PA. Resolution of trauma-related guilt following treatment of PTSD in female rape victims: a result of cognitive processing therapy targeting comorbid depression?. J Affect Disord. Jun. 2005;86(2–3):259-65. [pmid: 15935245].
20 Soo C, Tate Robyn L. Psychological treatment for anxiety in people with traumatic brain injury. Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2007.
21 Tarrier N, Humphreys L. Subjective improvement in PTSD patients with treatment by imaginal exposure or cognitive therapy: session by session changes. Br J Clin Psychol. Mar. 2000;39(Pt 1):27-34. [pmid: 10789026].
22 Taylor FB, Lowe K, Thompson C, et al. Daytime prazosin reduces psychological distress to trauma specific cues in civilian trauma posttraumatic stress disorder. Biol Psychiatry. Apr. 1. 2006;59(7):577-81. [pmid: 16460691].
23 Thrasher S, Power M, Morant N, et al. Social support moderates outcome in a randomized controlled trial of exposure therapy and (or) cognitive restructuring for chronic posttraumatic stress disorder. Can J Psychiatry. Mar. 2010;55(3):187-90. [pmid: 20370970].
24 van Liempt S, Vermetten E, Geuze E, et al. Pharmacotherapy for disordered sleep in post-traumatic stress disorder: a systematic review. International Clinical Psychopharmacology. Jul. 2006;21(4):193-202. WOS:000238030800001. [pmid: 16687990].
25 Weine S, Kulauzovic Y, Klebic A, et al. Evaluating a multiple-family group access intervention for refugees with PTSD. J Marital Fam Ther. Apr. 2008;34(2):149-64. [pmid: 18412823].

## Excluded for Wrong Duration

1 Jensen JA. An investigation of eye movement desensitization and reprocessing (EMD/R) as a treatment for posttraumatic stress disorder (PTSD) symptoms of Vietnam combat veterans. Behavior Therapy. 1994;25(2):311-25.
2 Suns A, North C, Adinoff B, et al. Effects of exogenous glucocorticoid on combat-related PTSD symptoms. Annals of Clinical Psychiatry. 2010;22(4):274. 2010-26843-006. [pmid: 21180658].
3 Taylor FB, Martin P, Thompson C, et al. Prazosin effects on objective sleep measures and clinical symptoms in civilian trauma posttraumatic stress disorder: a placebo-controlled study. Biol Psychiatry. Mar. 15. 2008;63(6):629-32. [pmid: 17868655].

## Studies at High Risk of Bias

(These studies were excluded from detailed analysis, and included in sensitivity analysis when possible.)

1 Arntz A, Tiesema M, Kindt M. Treatment of PTSD: a comparison of imaginal exposure with and without imagery rescripting. J Behav Ther Exp Psychiatry. Dec. 2007;38(4):345-70. [pmid: 18005935].
2 Beck JG, Coffey SF, Foy DW, et al. Group cognitive behavior therapy for chronic posttraumatic stress disorder: an initial randomized pilot study. Behavior Therapy. 2009;40(1):82-92. [pmid: 19187819].
3 Beidel DC, Frueh BC, Uhde TW, et al. Multicomponent behavioral treatment for chronic combat-related posttraumatic stress disorder: A randomized controlled trial. Journal of Anxiety Disorders. 2011;25(2):224. 2011-01965-008. [pmid: 20951543].
4 Bichescu D, Neuner F, Schauer M, et al. Narrative exposure therapy for political imprisonment-related chronic posttraumatic stress disorder and depression. Behav Res Ther. Sep. 2007;45(9):2212-20. [pmid: 17288990].
5 Braun P, Greenberg D, Dasberg H, et al. Core symptoms of posttraumatic stress disorder unimproved by alprazolam treatment. J Clin Psychiatry. Jun. 1990;51(6):236-8. [pmid: 2189869].
6 Brom D, Kleber RJ, Defares PB. Brief psychotherapy for posttraumatic stress disorders. J Consult Clin Psychol. Oct. 1989;57(5):607-12. [pmid: 2571625].
7 Davidson J, Kudler H, Smith R, et al. Treatment of posttraumatic stress disorder with amitriptyline and placebo. Archives of General Psychiatry. 1990;47(3):259. 1990-17938-001. [pmid: 2407208].
8 Davidson JR, Kudler HS, Saunders WB, et al. Predicting response to amitriptyline in posttraumatic stress disorder. Am J Psychiatry. Jul. 1993;150(7):1024-9. [pmid: 8317571].
9 Davis LL, Jewell ME, Ambrose S, et al. A placebo-controlled study of nefazodone for the treatment of chronic posttraumatic stress disorder: a preliminary study. J Clin Psychopharmacol. Jun. 2004;24(3):291-7. [pmid: 15118483].
10 Devilly GJ, Spence SH. The relative efficacy and treatment distress of EMDR and a cognitive-behavior trauma treatment protocol in the amelioration of posttraumatic stress disorder. J Anxiety Disord. Jan–Apr. 1999;13(1–2):131-57. [pmid: 10225505].
11 Difede J, Cukor J, Jayasinghe N, et al. Virtual reality exposure therapy for the treatment of posttraumatic stress disorder following September 11, 2001. J Clin Psychiatry. Nov. 2007;68(11):1639-47. [pmid: 18052556].
12 Difede J, Malta LS, Best S, et al. A randomized controlled clinical treatment trial for World Trade Center attack-related PTSD in disaster workers. J Nerv Ment Dis. Oct. 2007;195(10):861-5. [pmid: 18043528].
13 Echeburua E, De Corral P, Sarasua B, et al. Treatment of acute posttraumatic stress disorder in rape victims: An experimental study. Journal of Anxiety Disorders. 1996;10(3):185-99.
14 Echeburua E, de Corral P, Zubizarreta I, et al. Psychological treatment of chronic posttraumatic stress disorder in victims of sexual aggression. Behav Modif. Oct. 1997;21(4):433-56. [pmid: 9337600].
15 Feske U. Treating low-income and minority women with posttraumatic stress disorder: a pilot study comparing prolonged exposure and treatment as usual conducted by community therapists. J Interpers Violence. Aug. 2008;23(8):1027-40. [pmid: 18292398].
16 Foa EB, Rothbaum BO, Riggs DS, et al. Treatment of posttraumatic stress disorder in rape victims: a comparison between cognitive-behavioral procedures and counseling. J Consult Clin Psychol. Oct. 1991;59(5):715-23. [pmid: 1955605].
17 Frommberger U, Stieglitz RD, Nyberg E, et al. Comparison between paroxetine and behaviour therapy in patients with posttraumatic stress disorder (PTSD): A pilot study. International Journal of Psychiatry in Clinical Practice. 2004;8(1):19-23.
18 Hamner MB, Faldowski RA, Robert S, et al. A preliminary controlled trial of divalproex in posttraumatic stress disorder. Ann Clin Psychiatry. Apr–Jun. 2009;21(2):89-94. [pmid: 19439158].
19 Hensel-Dittmann D, Schauer M, Ruf M, et al. Treatment of traumatized victims of war and torture: A randomized controlled comparison of narrative exposure therapy and stress inoculation training. Psychother Psychosom. 2011;80(6):345-52. 2011-29267-004. First Author & Affiliation: Hensel-Dittmann, D. [pmid: 21829046].
20 Hertzberg MA, Butterfield MI, Feldman ME, et al. A preliminary study of lamotrigine for the treatment of posttraumatic stress disorder. Biol Psychiatry. May. 1. 1999;45(9):1226-9. [pmid: 10331117].
21 Hertzberg MA, Feldman ME, Beckham JC, et al. Lack of efficacy for fluoxetine in PTSD: a placebo controlled trial in combat veterans. Ann Clin Psychiatry. Jun. 2000;12(2):101-5. [pmid: 10907802].
22 Ironson G, Freund B, Strauss JL, et al. Comparison of two treatments for traumatic stress: A community-based study of EMDR and prolonged exposure. Journal of Clinical Psychology. 2002;58(1):113-28. [pmid: 11748600].
23 Johnson DR, Lubin H. The Counting Method: applying the rule of parsimony to the treatment of posttraumatic stress disorder. Traumatology. 2006;12(1):83-99.
24 Karatzias T, Power K, Brown K, et al. A controlled comparison of the effectiveness and efficiency of two psychological therapies for posttraumatic stress disorder: eye movement desensitization and reprocessing vs. emotional freedom techniques. J Nerv Ment Dis. Jun. 2011;199(6):372-8. [pmid: 21629014].
25 Keane TM, Fairbank JA, Caddell JM, et al. Implosive (flooding) therapy reduces symptoms of PTSD in Vietnam combat veterans. Behavior Therapy. 1989;20(2):245-60.
26 Kosten TR, Frank JB, Dan E, et al. Pharmacotherapy for posttraumatic stress disorder using phenelzine or imipramine. J Nerv Ment Dis. Jun. 1991;179(6):366-70. [pmid: 2051152].
27 Krakow B, Hollifield M, Schrader R, et al. A controlled study of imagery rehearsal for chronic nightmares in sexual assault survivors with PTSD: a preliminary report. J Trauma Stress. Oct. 2000;13(4):589-609. [pmid: 11109233].
28 Krupnick JL, Green BL, Stockton P, et al. Group interpersonal psychotherapy for low-income women with posttraumatic stress disorder. Psychother Res. Sep. 2008;18(5):497-507. [pmid: 18816001].
29 Lee C, Gavriel H, Drummond P, et al. Treatment of PTSD: stress inoculation training with prolonged exposure compared to EMDR. J Clin Psychol. Sep. 2002;58(9):1071-89. [pmid: 12209866].
30 Lindley SE, Carlson EB, Hill K. A randomized, double-blind, placebo-controlled trial of augmentation topiramate for chronic combat-related posttraumatic stress disorder. J Clin Psychopharmacol. Dec. 2007;27(6):677-81. [pmid: 18004136].
31 Marcus SV, Marquis P, Sakai C. Controlled study of treatment of PTSD using EMDR in an HMO setting. Psychotherapy. Fal. 1997;34(3):307-15. WOS:000071116000010.
32 Marshall RD, Lewis-Fernandez R, Blanco C, et al. A controlled trial of paroxetine for chronic PTSD, dissociation, and interpersonal problems in mostly minority adults. Depress Anxiety. 2007;24(2):77-84. [pmid: 16892419].
33 McLay RN, Wood DP, Webb-Murphy JA, et al. A randomized, controlled trial of virtual reality-graded exposure therapy for post-traumatic stress disorder in active duty service members with combat-related post-traumatic stress disorder. Cyberpsychol Behav Soc Netw. Apr. 2011;14(4):223-9. [pmid: 21332375].
34 McRae AL, Brady KT, Mellman TA, et al. Comparison of nefazodone and sertraline for the treatment of posttraumatic stress disorder. Depress Anxiety. 2004;19(3):190-6. [pmid: 15129422].
35 Otto MW, Hinton D, Korbly NB, et al. Treatment of pharmacotherapy-refractory posttraumatic stress disorder among Cambodian refugees: a pilot study of combination treatment with cognitive-behavior therapy vs sertraline alone. Behav Res Ther. Nov. 2003;41(11):1271-6. [pmid: 14527527].
36 Padala PR, Madison J, Monnahan M, et al. Risperidone monotherapy for post-traumatic stress disorder related to sexual assault and domestic abuse in women. Int Clin Psychopharmacol. Sep. 2006;21(5):275-80. [pmid: 16877898].
37 Paunovic N, Ost LG. Cognitive-behavior therapy vs exposure therapy in the treatment of PTSD in refugees. Behav Res Ther. Oct. 2001;39(10):1183-97. [pmid: 11579988].
38 Power K, McGoldrick T, Brown K, et al. A controlled comparison of eye movement desensitization and reprocessing versus exposure plus cognitive restructuring versus waiting list in the treatment of post-traumatic stress disorder. Clinical Psychology & Psychotherapy. Sep–Oct. 2002;9(5):299-318. WOS:000178998300001.
39 Rauch SA, Grunfeld TE, Yadin E, et al. Changes in reported physical health symptoms and social function with prolonged exposure therapy for chronic posttraumatic stress disorder. Depress Anxiety. 2009;26(8):732-8. [pmid: 18781660].
40 Ready DJ, Gerardi RJ, Backscheider AG, et al. Comparing virtual reality exposure therapy to present-centered therapy with 11 U.S. Vietnam veterans with PTSD. Cyberpsychol Behav Soc Netw. Feb. 2010;13(1):49-54. [pmid: 20528293].
41 Reist C, Kauffmann CD, Haier RJ, et al. A controlled trial of desipramine in 18 men with posttraumatic stress disorder. Am J Psychiatry. Apr. 1989;146(4):513-6. [pmid: 2648867].
42 Rothbaum BO, Killeen TK, Davidson JR, et al. Placebo-controlled trial of risperidone augmentation for selective serotonin reuptake inhibitor-resistant civilian posttraumatic stress disorder. J Clin Psychiatry. Apr. 2008;69(4):520-5. [pmid: 18278987].
43 Spivak B, Strous RD, Shaked G, et al. Reboxetine versus fluvoxamine in the treatment of motor vehicle accident-related posttraumatic stress disorder: a double-blind, fixed-dosage, controlled trial. J Clin Psychopharmacol. Apr. 2006;26(2):152-6. [pmid: 16633143].
44 Ulmer CS, Edinger JD, Calhoun PS. A multi-component cognitive-behavioral intervention for sleep disturbance in veterans with PTSD: a pilot study. J Clin Sleep Med. Feb. 15. 2011;7(1):57-68. [pmid: 21344046].
45 Wagner AW, Zatzick DF, Ghesquiere A, et al. Behavioral Activation as an Early Intervention for Posttraumatic Stress Disorder and Depression Among Physically Injured Trauma Survivors. Cognitive and Behavioral Practice. 2007;14(4):341-9.
46 Zlotnick C, Shea TM, Rosen K, et al. An affect-management group for women with posttraumatic stress disorder and histories of childhood sexual abuse. Journal of Traumatic Stress. 1997;10(3):425-36. [pmid: 9246650].