# Risk of Bias Assessment

In general terms, a “low” risk of bias study has the least risk of bias and its results are considered to be valid. A “medium” risk of bias study is susceptible to some bias but probably not sufficient to invalidate its results. A “high” risk of bias study has significant risk of bias (e.g., stemming from serious errors in design, conduct, or analysis) that may invalidate its results.

Two independent reviewers assigned risk of bias ratings for each study. For each article, one of the two reviewers was always an experienced investigator (DJ, JS, BG, KC, or CF). Disagreements between the two reviewers were resolved by discussion and consensus or by consulting a third member of the team. We gave high risk of bias ratings to studies that had a fatal flaw (defined as a methodological shortcoming that leads to a very high risk of bias) in one or more categories. The most common methodologic shortcomings contributing to high risk of bias ratings were high rates of attrition or differential attrition, inadequate methods used to handle missing data, and lack of intention-to-treat analysis. Below we list the 12 questions used to assess risk of bias. Then, Table E-1 provides the answers to these questions for each study. Following the table is a description of our rational for all high risk of bias ratings.

Table E-1 Quality ratings for efficacy/effectiveness trials

Author, Year | RADQ | ACA | Similar at BS | AMsk | ProvMsk | PatMsk | % Comp Overall G1 G2 G3 G4 | Overall Attrition ≥20% | Diff. Attrition ≥15% | ITT | MFD | Meas. Equal, Valid and Reliable | Fid | ROB
Akuchekian et al., 2004^1^ | Unclear | Unclear | Unclear | Unclear | Unclear | Yes | 93 94 91 | No | No | No | CA | Yes | NA | Med
Arntz et al., 2007^2^ | Unclear | Unclear | Yes | Unclear | No | No | 45 72 | Yes | Yes | Yes | LOCF | Yes | No | High
Asukai et al., 2010^3^ | Yes | Unclear | Yes | Yes | No | No | 75 92 | No | Yes | Yes | MI | Yes | Mixed | Med
Bartzokis et al., 2005^4^ | Unclear | Unclear | Unclear | Yes | Yes | Yes | 74 67 81 | Yes | No | No | Other | Yes | NA | Med
Basoglu et al., 2007^5^ | Yes | Yes | Yes | No | No | No | 100 100 100 | No | No | No | NA | Yes | No | Med
Beck et al., 2009^6^ | Unclear | Unclear | Unclear | Unclear | No | No | 75 65 89 | Yes | Yes | No | CA | Yes | Yes | High
Becker et al., 2007^7^ | Unclear | Unclear | Unclear | Yes | Unclear | Yes | 90 to 100 83 to 100 | No | No | Yes | LOCF | Yes | NA | Med
Beidel et al., 2011^8^ | Unclear | Unclear | Unclear | Unclear | No | No | 86 78 94 | No | Yes | No | CA | Yes | Yes | High
Bichescu et al., 2007^9^ | Unclear | Unclear | Yes | No | No | No | 100 100 100 | No | No | NA | NA | Yes | No | High
Blanchard et al., 2003^10^ | Unclear | Unclear | Yes | Yes | No | No | 80 73 75 96 | Yes | Yes | Yes | LOCF | Yes | Yes | Med
Boden et al., 2012^11^ | Yes | Unclear | No | Yes | No | No | 84 83 85 | Yes | No | Yes | Unclear | Yes | Yes | Med
Brady et al., 2000^12^ | Unclear | Unclear | No | Unclear | Unclear | Yes | 69 68 70 | Yes | No | Yes | LOCF | Yes | NA | Med
Brady et al., 2005^13^ | Yes | Unclear | Yes | Unclear | Yes | Yes | 63 69 | Yes | No | Yes | Other | Yes | NA | Med
Braun et al., 1990^14^ | Unclear | Unclear | Unclear | Yes | Unclear | Yes | 63 57 67 | Yes | No | No | CA | No | NA | High
Brom et al., 1989^15^ | Unclear | Unclear | Unclear | Unclear | No | No | 89 90 90 90 87 | No | No | No | CA | Mixed | No | High
Bryant, et al., 2003^16^ | Unclear | Unclear | Yes | Yes | No | No | 78 75 75 83 | Yes | No | Yes | LOCF | Yes | Yes | Med
Bryant et al., 2008^17^ | Yes | Yes | Yes | Yes | No | No | 76 74 79 68 86 | Yes | No | Yes | LOCF | Yes | Yes | Med
Butterfield et al., 2001^18^ | Unclear | Unclear | Unclear | Unclear | Unclear | Yes | 73 70 80 | Yes | No | Yes | CA | Yes | NA | Med
Carlson et al., 1998^19^ | Unclear | Unclear | No | No | No | No | 97 92 100 100 | No | No | No | Unclear | Yes | No | Med (post-treatment) High (3- & 9-mth)
Chard et al., 2005^20^ | Unclear | Unclear | Yes | Yes | No | No | 82 83 80 | No | No | Yes | LOCF | Yes | Yes | Med
Cloitre et al., 2002^21^ | Unclear | Unclear | Unclear | Yes | No | No | 79 71 89 | Yes | Yes | Yes | LOCF | Yes | Yes | Med
Cloitre et al., 2010^22^ | Unclear | No | Yes | Yes | No | Unclear | 73 85 74 61 3 Month 68 76 68 61 6 Month 63 70 61 61 | Yes | Yes | Yes | MI | Yes | Yes | Med
Connor et al., 1999^23^ Meltzer-Brody et al., 2000^24^ | Yes | Yes | No | Yes | Yes | Yes | 67 78 59 | Yes | Yes | Yes | LOCF | Mixed | NA | Med
Cook et al., 2010^25^ | Yes | Unclear | Yes | Yes | No | Unclear | 73 81 64 | Yes | Yes | Yes | MI | Yes | Yes | Med
Cottraux, 2008^26^ | Yes | Yes | Yes | Yes | No | No | 70 87 52 | Yes | Yes | Yes | LOCF | Yes | No | Med
Davidson et al., 1990^27^ Davidson, et al., 1993^28^ | Unclear | Unclear | Yes | Yes | Yes | Yes | 72 68 76 | Yes | No | No | CA | Yes | NA | High
Davidson et al., 2001^29^ | Yes | Unclear | Yes | Unclear | Unclear | Yes | 66 67 66 | Yes | No | Yes | Other | Yes | NA | Med
Davidson et al., 2003^30^ | Unclear | Unclear | Yes | Unclear | Yes | Yes | 82 67 | Yes | Yes | Yes | LOCF | Yes | NA | Med
Davidson et al., 2006^31^ | Unclear | Unclear | Unclear | Unclear | Yes | Yes | 65 NR NR | Yes | No | Yes | LOCF | Yes | NA | Med
Davidson et al., 2006^32^ | Yes | Unclear | Yes | Unclear | Yes | Yes | 68 70 67 | Yes | No | Yes | LOCF | Yes | NA | Med
Davidson et al., 2007^33^ | Unclear | Unclear | Unclear | Yes | Yes | Yes | 61 66 55 | Yes | No | No | LOCF | Yes | NA | Med
Davis et al., 2004^34^ | Unclear | Yes | No | Yes | Yes | Yes | 55 52 60 | Yes | No | Yes | LOCF | Yes | NA | High
Davis et al., 2008^35^ | Yes | Yes | Yes | Yes | Yes | Yes | 77 83 | Yes | No | Yes | LOCF | Yes | NA | Low
Devilly et al., 1999^36^ | No | No | No | Unclear | No | No | 72 80 64 | Yes | Yes | No | NA | Yes | Yes | High
Difede et al., 2007^37^ | No | No | No | Yes | No | No | 86 77 100 | No | Yes | No | CA | Yes | Mixed | High
Difede et al., 2007^38^ | Unclear | Yes | Yes | Yes | No | No | 68 47 88 | Yes | Yes | Yes | LOCF | Yes | Yes | High
Echeburua et al., 1996^39^ | Unclear | Unclear | Unclear | No | No | No | 100 100 100 | No | No | Yes | NA | No | No | High
Echeburua et al., 1997^40^ | No | No | Unclear | Unclear | No | No | 100 100 100 | No | No | Yes | NA | Yes | No | High
Ehlers et al., 2003^41^ | Yes | Yes | Unclear | Yes | No | No | 100 89 90 | No | No | Yes | Unclear | Yes | No | Med
Ehlers et al., 2005^42^ | Unclear | Unclear | Yes | Yes | No | No | 100 100 100 | No | No | No | NA | Yes | Mixed | Med
Fecteau et al., 1999^43^ | Unclear | Unclear | No | No | No | No | 83 91 | No | No | No | CA | Yes | Yes | Med
Feske et al., 2008^44^ | Unclear | Unclear | Yes | Unclear | No | No | 78 69 86 | Yes | Yes | No | CA | Yes | No | High
Foa et al., 1991^45^ | Unclear | Unclear | No | Yes | No | No | 82 82 71 79 100 | No | Yes | No | CA | Yes | No | High
Foa et al., 2005^46^ | No | Yes | No | Yes | No | No | 64 66 59 96 | Yes | Yes | Yes | LOCF | Yes | Yes | Med
Foa et al., 1999^47^ Zoellner et al., 1999^48^ | Unclear | Unclear | Unclear | Yes | No | No | 82 92 73 73 100 | No | Yes | Yes | LOCF | Yes | Yes | Med
Forbes et al., 2012^49^ | Yes | Yes | Yes | Yes | No | No | 78 80 79 | Yes | No | Yes | LOCF | Yes | Yes | Med
Ford et al., 2011^50^ | Yes | Yes | Unclear | No | No | No | 71 71 66 78 | Yes | No | Yes | Mixed model regression | Yes | Yes | Med
Friedman et al., 2007^51^ | Yes | Unclear | Yes | Yes | Unclear | Yes | 70 83 | Yes | No | Yes | LOCF | Yes | NA | Med
Frommberger et al., 2004^52^ | Unclear | Unclear | Unclear | Unclear | Unclear | No | 76 80 73 | Yes | No | No | CA | Yes | No | High
Gamito et al., 2010^53^ | Unclear | Unclear | Unclear | No | No | No | 90 80 100 100 | No | No | No | CA | Yes | No | Med
Gersons et al., 2000^54^ | Unclear | Unclear | No | Yes | No | No | 98 100 95 | No | No | NR | Unclear | Yes | Yes | Med
Hamner et al., 2003^55^ | Unclear | Unclear | Yes | Yes | Yes | Yes | 53 67 | Yes | No | Yes | LOCF | Yes | Yes | Med
Hamner et al., 2009^56^ | Unclear | Unclear | Yes | Yes | No | Unclear | 56 46 | Yes | No | Yes | Other | Yes | NA | High
Hensel-Dittmann et al., 2011^57^ | Yes | Yes | No | No | No | No | 75 73 77 | Yes | No | Yes | Mixed effects models | Yes | No | High
Hertzberg et al., 1999^58^ | Unclear | Unclear | Unclear | Unclear | Unclear | Yes | 93 91 100 | No | No | No | CA | Mixed | NA | High
Hertzberg et al., 2000^59^ | Unclear | Unclear | Unclear | Unclear | Unclear | Yes | 92 100 83 | No | Yes | No | Other | Mixed | NA | High
Hien et al., 2004^60^ | Unclear | Unclear | Yes | Unclear | No | No | 76 61 71 100 | Yes | No | Yes | LOCF | Yes | Yes | Med
Hien et al., 2009^61^ Hien et al., 2012^62^ | Yes | Yes | Yes | Yes | No | No | 1 week 63 61 64 3 mos. 63 58 12 mos. 63 59 | Yes | No | Yes | Other | Yes | Yes | Med
Hinton et al., 2005^63^ | Unclear | Unclear | Yes | Yes | No | No | 100 100 100 | No | No | No | NA | Yes | No | Med
Hinton et al., 2009^64^ | Yes | Unclear | Yes | Yes | No | No | 100 100 100 | No | No | No | NA | Yes | No | Med
Hinton et al., 2011^65^ | Unclear | Unclear | Yes | Unclear | No | Unclear | 100 100 100 | No | No | No | NA | Yes | No | Med
Hogberg et al., 2007^66^ | Yes | Yes | Yes | Yes | No | No | 88 92 82 | No | No | No | CA | Yes | Yes | Med
Hollifield et al., 2007^67^ | Yes | Yes | Yes | Yes | No | No | 78 66 75 | Yes | No | Yes | LOCF | Yes | No | Med
Ironson et al., 2002^68^ | No | Unclear | No | No | No | No | 73 50 100 | Yes | Yes | No | CA | Yes | No | High
Johnson et al., 2006^69^ | Unclear | Unclear | No | Yes | No | No | 75 73 79 | Yes | No | No | CA | Yes | No | High
Johnson et al., 2011^70^ | Yes | Unclear | No | No | No | No | 91 97 | No | No | Yes | Other | Yes | Yes | Med
Karatzias et al., 2011^71^ | Unclear | Unclear | Yes | Yes | No | No | 59 57 61 F/U 50 48 52 | Yes | No | Yes | Other | Yes | Mixed | High
Keane et al., 1989^72^ | Unclear | Unclear | No | No | No | No | NR NR NR | NR | NR | NR | NR | No | No | High
Kosten et al., 1991^73^ | Unclear | Unclear | No | Yes | Yes | Yes | 52 39 79 33 | Yes | Yes | Yes | LOCF | Yes | NA | High
Krakow et al., 2000^74^ | Unclear | Unclear | Yes | Unclear | No | No | 54 49 59 | Yes | No | No | CA | Yes | No | High
Krakow et al., 2001^75^ | Yes | Unclear | Yes | Yes | No | No | 68 61 75 | Yes | No | Yes | LOCF | Yes | No | Med
Krupnick et al., 2008^76^ | Unclear | Unclear | Unclear | Unclear | No | No | 63 44 | Yes | Yes | Yes | Other | Yes | No | High
Kruse et al., 2009^77^ | NA | NA | No | Unclear | No | No | 91 97 86 | No | No | No | CA | Yes | No | Med
Krystal et al., 2011^78^ | Yes | Yes | Yes | Unclear | Yes | Yes | 83 84 83 | No | No | Yes | MI | Yes | NA | Low
Kubany et al., 2003^79^ | Unclear | Unclear | Yes | Yes | No | No | 86 95 78 | No | Yes | Yes | LOCF | Yes | No | Med
Kubany et al., 2004^80^ | Unclear | Unclear | Unclear | Yes | No | No | 65 73 56 | Yes | Yes | Yes | Main analysis: CA Some from ITT analysis: LOCF | Yes | No | Med
Lee et al., 2002^81^ | No | No | Unclear | No | No | No | 89 NR NR | No | No | NR | Unclear | Yes | Yes | High
Liedl et al., 2011^82^ | Unclear | Unclear | Yes | Unclear | No | Unclear | 94 92 92 100 3 Month 83 83 83 83 | No | No | No | NA | Yes | No | Med
Lindauer et al., 2005^83^ | Yes | Yes | Yes | Yes | No | No | 75 58 92 | Yes | Yes | Yes | LOCF | Yes | Yes | Med
Lindley et al., 2007^84^ | Unclear | Unclear | Yes | Yes | Yes | Yes | 45 75 | Yes | Yes | No | Unclear | Yes | NA | High
Litz et al., 2007^85^ | Unclear | Unclear | Yes | Yes | No | No | 73 Unclear Unclear | Yes | No | Yes | Other | Yes | No | Med
Marcus et al., 1997^86^ | Yes | Unclear | NR | No | No | No | NR | NR | NR | No | Other | Yes | No | High
Marks et al., 1998^87^ Lovell et al., 2001^88^ | Yes | Unclear | No | Yes | No | No | 89 87 95 79 95 | No | Yes | Yes | LOCF | Yes | Yes | Med
Marshall et al., 2001^89^ | Unclear | Unclear | Unclear | Unclear | Yes | Yes | 63 65 61 64 | Yes | No | Yes | LOCF | Yes | NA | Med
Marshall et al., 2007^90^ | Unclear | Unclear | Unclear | Yes | Yes | Yes | 47 Unclear Unclear | Yes | Yes | Yes | Other | Yes | NA | High
Martenyi et al., 2002^91^ Martenyi et al., 2006^92^ | Yes | Unclear | Yes | Unclear | Unclear | Yes | NR | NR | NR | Yes | LOCF | Yes | NA | Med
Martenyi et al., 2007^93^ | Unclear | Unclear | Yes | Yes | Unclear | Yes | 86 90 88 | No | No | Yes | LOCF | Yes | NA | Med
McDonagh et al., 2005^94^ | Unclear | Unclear | Yes | Yes | No | No | 67 59 91 91 77 | Yes | Yes | Yes | LOCF | Yes | Yes | Med
McLay et al., 2011^95^ | Unclear | Unclear | Unclear | Unclear | No | No | 95 100 90 | No | No | No | CA | Mixed | No | High
McRae et al., 2004^96^ | Unclear | Unclear | Unclear | Unclear | Yes | Yes | 70 68 72 | Yes | No | No | None | Yes | NA | High
Monnelly et al., 2003^97^ | Unclear | Unclear | Unclear | Yes | Yes | Yes | 88 100 | No | No | No | CA | Yes | NA | Med
Monson et al., 2006^98^ | Unclear | Unclear | Yes | Yes | No | No | 83 80 87 | No | No | Yes | Other | Yes | Yes | Med
Mueser et al., 2008^99^ ^391^ | Yes | Yes | Yes | Yes | No | Yes | 68 70 65 | Yes | Yes | Yes | MI | Yes | NR | Med
Nacasch et al., 2011^100^ | Unclear | Yes | Yes | Yes | No | No | 87 87 87 | No | No | Yes | Unclear | Yes | No | Med
Neuner et al., 2004^101^ | Yes | Yes | Yes | Yes | No | No | 93 88 93 100 | No | No | Yes | Other | Yes | Mixed | Med
Neuner et al., 2008^102^ | No | Yes | Yes | Yes | No | No | 91 96 80 100 | Yes | Yes | Yes | Other | Yes | Yes | Med
Neuner et al., 2010^103^ | Unclear | Unclear | Yes | Yes | No | No | 94 88 100 | No | No | Yes | Other | Yes | No | Med
Nijdam et al., 2012^104^ | Yes | Yes | Yes | Yes | No | No | 64 60 69 | Yes | No | Yes | Mixed linear models | Yes | Yes | Med
Panahi et al., 2011^105^ | Yes | Unclear | Yes | Yes | Yes | Yes | 89 91 86 | No | No | Yes | LOCF & MI | Yes | NA | Low
Otto et al., 2003^106^ | Unclear | Unclear | No | Unclear | No | No | NR NR NR | No | No | Unclear | Other | Yes | No | High
Padala et al., 2006^107^ | Unclear | Unclear | No | Unclear | Yes | Yes | 75 82 67 | Yes | Yes | No | CA | Yes | NA | High
Paunovic et al., 2001^108^ | Unclear | Unclear | Unclear | No | No | No | 80 89 73 | Yes | Yes | NR | Unclear | Yes | No | High
Petrakis et al., 2011^109^ | Unclear | Yes | No | Yes | Yes | Yes | 64 80 73 67 | Yes | Yes | Yes | Other | Yes | Yes | Med
Power et al., 2002^110^ | Yes | Yes | Yes | Yes | No | No | 69 69 57 83 | Yes | Yes | No | CA | Yes | No | High
Raskind et al., 2003^111^ | Unclear | Unclear | Unclear | Yes | Yes | Yes | 100 60 (only 20% of those who received placebo 2nd completed) | Yes | Yes | No | LOCF | Yes | NA | Med
Raskind et al., 2007^112^ | Yes | Unclear | Unclear | Yes | Yes | Yes | 85 80 85 | No | No | Yes | LOCF | Yes | Yes | Med
Rauch et al., 2009^113^ | Unclear | Unclear | No | Yes | No | No | 68 66 60 96 | Yes | Yes | No | CA | Yes | No | High
Ready et al., 2010^114^ | Unclear | Unclear | No | Yes | No | No | 82 83 80 | No | No | No | CA | Yes | No | High
Reich, 2005^115^ | Unclear | Unclear | Yes | Unclear | Yes | Yes | 76 75 78 | Yes | No | Yes | LOCF | Yes | NA | Med
Reist, 1989^116^ | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | 67 NR NR | Yes | NR | No | CA | No | NA | High
Resick, 2002^117^ Resick, 2003^118^ Resick et al., 2012^119^ | Unclear | Unclear | Yes | Yes | No | No | 67 66 65 85 | Yes | Yes | Yes | LOCF | Yes | Yes | Med
Rothbaum, 1997^120^ | Unclear | Unclear | No | Yes | No | No | 86 NR NR | No | Unclear | No | Unclear | Yes | Yes | Med
Rothbaum, 2005^121^ | Unclear | Unclear | No | Yes | No | No | 81 NR NR NR | No | No | No | CA | Yes | Yes | Med
Rothbaum, 2006^122^ | Unclear | Unclear | Yes | Yes | No | No | 89 97 82 | No | No | Yes | LOCF | Yes | No | Med
Rothbaum, 2008^123^ | Unclear | Unclear | Yes | Unclear | Unclear | Yes | 64 100 | Yes | Yes | No | CA | Yes | NA | High
Schneier, 2012^124^ | Yes | Yes | Yes | Yes | No | No | 70 68 72 | Yes | No | Yes | CA | Yes | Yes | Med
Schnurr, 2003^125^ | Yes | Yes | Yes | Yes | No | No | 84 77 91 Booster treatment 92 96 91 | No | No | Yes | Other | Yes | Yes | Low
Schnurr, 2007^126^ | Yes | Yes | Yes | Yes | No | No | 71 62 79 | Yes | Yes | Yes | MI | Yes | Yes | Med
Schnyder, 2011^127^ | Unclear | Unclear | No | Yes | No | No | 93 94 93 | Yes | No | Yes | LOCF | Yes | Yes | Med
Simon, 2008^128^ | Unclear | Unclear | Yes | Yes | Yes | Yes | 80 73 86 | Yes | No | Yes | LOCF | Yes | No | Med
Spence, 2011^129^ | Yes | Unclear | No | No | Unclear | No | 81 78 86 | No | No | Yes | Other | Yes | No | Med
Spivak, 2006^130^ | Yes | Unclear | Yes | Yes | Yes | Yes | 70 55 85 | Yes | Yes | No | CA | Yes | NA | High
Stein, 2002^131^ | Unclear | Unclear | Yes | Yes | Yes | Yes | 70 78 | Yes | No | Yes | LOCF | Yes | NA | Med
Tarrier, 1999^132^ Tarrier, 1999^133^ | Yes | Yes | No | Yes | No | No | 86 83 89 | No | No | No | CA | Yes | Yes | Med
Taylor, 2003^134^ | Unclear | Unclear | Yes | Yes | Yes | No | 75 68 79 79 | Yes | No | No | CA | Yes | Yes | Med
Tucker, 2001^135^ | Unclear | Unclear | Yes | Unclear | Unclear | Yes | 61 62 60 | Yes | No | Yes | LOCF | Yes | NA | Med
Tucker, 2003^136^ Tucker, 2004^137^ | Unclear | Unclear | Yes | Yes | Yes | Yes | 76 80 74 70 | Yes | No | No | LOCF | Yes | NA | Med
Tucker, 2007^138^ | Yes | Yes | Yes | Yes | Unclear | Yes | 74 84 | Yes | No | Yes | LOCF | Yes | NA | Med
Ulmer, 2011^139^ | Unclear | Unclear | Yes | No | No | Unclear | 82 67 100 | No | Yes | Yes | Other | Yes | No | High
van der Kolk, 1994^140^ | Unclear | Unclear | Unclear | Unclear | Unclear | Yes | 73 64 87 | Yes | Yes | No | CA | Yes | NA | Med
van der Kolk, 2007^141^ | Unclear | Unclear | Yes | Yes | Yes | Yes | 83 87 90 | No | No | Yes | LOCF | Yes | NA | Med
van Emmerik, 2008^142^ | Yes | Yes | Yes | Yes | No | No | 68 NR NR | Yes | No | Yes | LOCF | Yes | No | Med
Wagner, 2007^143^ | Unclear | Unclear | No | Yes | No | No | 88 75 100 | No | No | Yes | LOCF | Yes | No | High
Yeh, 2011^144^ | Yes | Yes | No | Yes | Yes | Yes | 74 82 67 | Yes | Yes | No | LOCF | Yes | NA | Med
Zlotnick, 1997^145^ | Unclear | Unclear | No | No | No | No | 69 71 67 | Yes | No | No | CA | Mixed | No | High
Zlotnick, 2009^146^ | Unclear | Unclear | No | No | No | No | 90 85 95 | No | No | No | CA | Yes | No | Med
Zohar, 2002^147^ | Unclear | Unclear | No | Yes | Yes | Yes | 74 79 | Yes | No | Yes | Unclear | Yes | Yes | Med

Abbreviations: ACA = allocation concealment adequate; AMsk = assessor masked; BS = baseline; CA = Completer Analyses; Diff = differential; Fid = Reported adequate treatment fidelity; ITT = intent-to-treat; LOCF = Last Observation Carried Forward = Med = Medium; MFD = Method of handling dropouts; MI = Multiple Imputation; NA = not applicable; NR = not reported; PatMsk = patient masked; Prov Msk = provider masked; RADQ = Randomization adequate; ROB = Risk of Bias.

## Randomized Controlled Trials

### Criteria

Was randomization adequate?

Was allocation concealment adequate?

Were groups similar at baseline?

Were outcome assessors masked?

Were care providers masked?

Were patients masked?

Was overall attrition 20% or higher?

Was differential attrition 15% or higher?

Did the study use intention-to-treat analysis?

Did the study use adequate methods for handling missing data?

Were outcome measures equal, valid, and reliable?

Did study report adequate treatment fidelity (therapist adherence) based on measurement by independent raters?

## Additional Comments on Trials Rated High Risk of Bias

Arntz et al., 2007:^2^ Very high attrition and high differential attrition (just 45% completed in one group, 72% in the other); outcome assessor and randomization procedures unclear; outcome assessors not described as masked; no description of treatment fidelity.

Beck et al., 2009.^6^ High risk of attrition bias, due to the overall and the differential attrition (24% difference between groups). Unclear whether groups were similar at baseline for demographics and most potential confounders (as the information is not provided). In addition, inadequate handling of missing data (used completers analysis). No description of randomization method or allocation concealment.

Beidel et al., 2011:^8^ High risk of selection bias; completers analysis in a small trial (N=35) with high differential dropout; and risk of bias from no masking.

Bichescu et al., 2007:^9^ No attempt to create similar groups, this subsequently affected assessor blinding. Few details of randomization process beyond “were randomized”.

Braun et al., 1990:^14^ High attrition, non-standard outcome measures, baseline data not reported to allow determination of similarity or differences between groups.

Brom et al., 1989:^15^ Appears to be completers analysis with no approach to handling missing data reported; no data reported to allow comparison of groups at baseline; no masking of outcome assessors reported; no information on treatment fidelity; methods of randomization and allocation concealment not reported; potential measurement bias due to differences in timing of assessments across groups.

Davidson et al., 1993;^28^ Davidson, 1990:^27^ Completer analysis for all subjects completing minimum of 4 weeks (40/46 subjects did so and were included in the analyses, 87%); and separately for the 33/46 (71.1%) that completed 8 weeks; no treatment of missing data; with high attrition. It was also unclear whether randomization or allocation concealment were adequate.

Davis et al., 2004:^34^ Very high attrition (close to 50% overall); groups mostly similar at baseline but differed in prior treatments (with just 1 subject in the placebo group previously treated with an antidepressant vs. 15 to 27% of subjects with previous treatment with antidepressants, benzodiazepines, or other medication in the nefazodone group); ITT analysis with LOCF (with exception of 1 patient).

Devilly et al., 1999:^36^ High risk of selection bias, attrition bias; inadequate handling of missing data; inadequate randomization procedure (alternating for much of the assignment); inadequate allocation concealments; baseline differences between groups for several of the reported characteristics (age, psychotropic medications, marital status, living partners, IES); high overall and differential attrition (over 15%) in a head to head study with already small N (32 randomized); completers analysis for the 23 that completed.

Difede et al., 2007:^37^ High attrition and differential attrition (% completing were 68% vs. 47% vs. 88%); differences in baseline PTSD severity between groups (scores on CAPS).

Difede et al., 2007:^38^ Very high attrition, and high differential attrition; over 1/2 for the CBT group did not complete treatment.

Echeburua et al., 1996:^39^ Inadequate randomization; similar description to the other study by the same author where subjects were actually assigned by alternating, rather than at random; delivered by a single therapist and no mention of assuring treatment fidelity/therapist adherence; no masking of outcome assessors reported and not using validated measure--thus high risk of measurement bias; high risk of selection bias in this very small (N=20) head to head study due to inadequate randomization, inadequate information reported to determine if groups were comparable at baseline; no mention of co-interventions (e.g., medications) that could confound the findings.

Echeburua et al., 1997:^40^ Study was not actually an RCT, it used alternating to assign subjects to groups (personal communication with author on 2/7/2012, email); high risk of selection bias and confounding with small sample size, method of group assignment, and no data reported to determine if groups similar at baseline; single therapist used and unclear whether there was a separate masked outcome assessor.

Feske et al., 2008:^44^ High risk of selection bias and confounding; already small sample size and the high overall and differential attrition with completer analysis; attrition bias; 4 of 13 randomized subjects in the prolonged exposure group (31%) dropped out, 2 were withdrawn due to medication changes and 2 for unknown reasons; 2/14 treatment as usual clients withdrawn.

Foa et al., 1991:^45^ High attrition for some groups and high differential attrition; completer analysis only; study did not report adequate treatment fidelity; some baseline differences between groups for income, assault characteristics; high risk of selection bias and confounding.

Frommberger et al., 2004:^52^ High risk of selection bias and confounding; attrition bias; no reporting of adequate fidelity; Small sample size with no data shown on baseline covariates across groups; outcome assessment not masked; over 20% attrition and nothing done for missing data (completer analysis).

Hamner et al., 2009:^56^ Substantial dropout, limited description of randomization; study reported as double blind, but write up suggests VPA folks got a lot more blood draws/monitoring; also, study physician told by pharmacist to adjust doses, so not blind to treatment arm.

Hensel-Dittman et al., 2011.^57^ High risk of selection bias and confounding. First, no data were reported to allow baseline comparison of groups for most variables, and this is a fairly small sample size, making baseline differences more likely. The authors only report baseline data for a few of the outcome measures, and there was an 11-point difference between groups for baseline CAPS score. They did some matching during the randomization, but it is unclear if that worked to produce comparable groups at baseline. Next, the study did not report adequate treatment fidelity based on measurement by independent raters; no information was reported about treatment fidelity. They report that they videotaped all sessions, but there is no information reported to confirm to support adequate treatment fidelity, which would be very important since all of the same therapists delivered both interventions and it would be fairly easy to have some of the components of one therapy introduced into the other therapy. Next, lack of masking; the authors report that they attempted to keep outcome assessors blind, but that treatment condition was occasionnally revealed to them, but it is unclear how frequently this occurred.

Hertzberg et al., 1999:^58^ Baseline characteristics not reported for important potential confounders in this small study (n =15) to allow for determination of potential selection bias; in addition, unclear whether randomization or allocation concealment were adequate; unclear whether outcome assessors were masked. Completers analysis.

Hertzberg et al., 2000:^59^ Baseline characteristics not reported for important potential confounders in this small study (n=12) to allow for determination of potential selection bias (described as “non-significant difference”, but given small sample size, almost any difference will be non-significant). In addition, unclear whether randomization or allocation concealment were adequate; unclear whether outcome assessors were masked. Instruments of uncertain validity used to assess outcomes.

Ironson et al., 2002:^68^ High risk of selection bias; randomization compromised by adding more participants to PE group to achieve equal group numbers; high overall and differential attrition (and 50% dropouts from the PE group); marked differences in baseline severity of PTSD and depression between groups (otherwise, minimal baseline data reported to allow comparison of groups); completer analysis; no handling of missing data.

Johnson et al., 2006^69^ Inadquate methods of handling missing data, completers analysis; did not report adequate treatment fidelity based on measurement by independent raters; high potential for selection bias with small numbers in each treatment arm and no reporting of baseline demographics (only reported in aggregate for the three interventino groups) and potential confounders for comparison, and there were differences in the baseline values for the measures of PTSD symptoms (e.g., baseline CAPS scores were 82 for Counting and 61.7 for EMDR, 64.2 for waitlist). The authors describe the study as a randomized trial. However, from their description of the design, it appears that the participants for the waitlist control group were recruited separately from the group recruited to the active treatments. In other words, participants recruited to the active condition were randomized to one of three active treatments, but the persons recruited to the control condition were not assigned to that group randomly. Accordingly, it’s not really a randomized trial for the comparisons with the control condition.

Karatzias et al., 2011:^71^ Very high attrition rate (over 40%); unclear whether randomization or allocation concealment were adequate.

Keane et al., 1989.^72^ High risk of selection bias: Baseline differences between groups included race (for Intervention vs. waitlist: 0% vs. 31% Black), and service connection (36% vs. 69%) possibly biasing control group toward reporting greater severity of symptoms; difference between group in co-interventions/medications administered over the course of the study (42.9% [6/14] in intervention group received anxiolytic, sleep, or pain meds at some point during the study vs. 76.9% [10/13] in the control group received anxiolytic medications at some point during waiting; and some evidence suggests worse outcomes for those with PTSD treated with anxiolytics). The PTSD ratings were completed by therapists who were administering the therapy and thus were not blinded. Of note, the study found no difference between active intervention and control group in self-reported PTSD symptoms but a substantial differences in PTSD ratings completed by the non-blinded therapists. Potential measurement bias with no masking or independence of outcome assessors and outcomes assessed at different timepoints for the two groups. Unclear whether randomization, allocation concealment, and masking were adequate. Attrition information not reported, nor was approach to handling missing data. No description of methods to ensure treatment fidelity.

Kosten et al., 1991:^73^ High attrition, almost 50%; and high differential attrition (% completers by group: 52 vs. 39 vs. 79 vs. 33).

Krakow et al., 2000:^74^ Very high attrition, around 50%; did not report adequate treatment fidelity.

Krupnick et al., 2008:^76^ High risk of selection bias due to attrition. Very high attrition and high differential attrition (% completers by group: 63 vs. 44). Regarding “other” method of handling dropouts: imputed missing scores as the application of the observed group mean change.

Lee et al., 2002:^81^ Inadequate randomization procedure (alternating); no allocation concealment, no blinding of outcome assessors; unclear whether groups were similar at baseline for several characteristics; details of analysis and missing data were NR; differential attrition data unclear.

Lindley et al., 2007:^84^ High attrition and high differential attrition (30%), method of handling dropouts/missing data was unclear.

Marcus et al., 1997:^86^ No data reported to allow assessment of how groups compare at baseline, how many patients dropped out after randomization, or how many people are in the 2 groups. Attrition information not reported; does not describe use of ITT analysis; Outcome assessors were not masked, increasing potential for measurement bias; did not report adequate treatment fidelity.

Marshall et al., 2007:^90^ High risk of selection bias due to high rate of attrition. Also, not clear if groups were similar at baseline (article does not show the data--it just has a sentence that says that patient demographics did not differ significantly between groups; although later Tables do show similar baseline PTSD severity for CAPS and some other measures).

McLay et al., 2011:^95^ Unclear adequacy of randomization or allocation concealment; unclear whether or not outcome assessors were masked; small sample with possible significant differences in prior deployments between treatment groups, raising risk of selection bias. The measures themselves were reliable but post assessments were reported to be given sporadically over a 36 week period. Study did not report adequate treatment fidelity.

McRae et al., 2004.^96^ Completers analysis with inadequate handling of missing data in this head-to-head study that found no difference between treatments; high risk of selection bias; unable to determine if randomized groups were similar at baseline (data only reported for completers; 26/37 subjects); unclear whether randomization and allocation concealment were adequate.

Otto et al., 2003:^106^ No masking; no reporting of handling of missing data; no reporting of attrition data; not sure if ITT or completers analysis.

Padala et al., 2006:^107^ High risk of selection bias and confounding; differential attrition along with small sample size (N=20); completer analysis; only reports age, race, mean TOP-8, and mean CAPS at baseline---the race characteristics were quite different (55% Caucasian in Risperidone group vs. 89% in the Placebo group).

Paunovic et al., 2001:^108^ High risk of selection bias and confounding; high differential attrition in this small (N=20) head to head study comparing two types of psychotherapy that found no difference between the two, and was not powered to find a small to moderate difference between treatments; no assessor masking; did not reported whether ITT; handling of missing data NR.

Power et al., 2002:^110^ High overall and differential attrition; completers analysis; no approach to handling missing data; no assessment of treatment fidelity; in the two active treatment groups, about 31% and 43% did not complete treatment, respectively.

Rauch et al., 2009:^113^ High risk of selection bias and confounding; completers analysis, using just the set of subjects that completed an RCT (Foa et al 2005, J Consul Clin Psychol); baseline differences in race and income.

Ready et al., 2010:^114^ High risk of selection bias and confounding. This small study (N = 11) did not report differences in many baseline covariates across intervention groups. However, there were large differences in some of the few that they did report (CAPS, BDI), which strongly suggests that there were important differences in baseline covariates.

Reist et al., 1989:^116^ Non-standard outcome measures, high attrition, only overall attrition not group-specific attrition reported, completer analysis.

Rothbaum et al., 2008:^123^ Randomization unclear, high differential attrition (36% differential), completer’s analysis; unclear whether outcome assessor were masked.

Spivak et al., 2006:^130^ Completers analysis; and high overall and differential attrition with already small sample size (40 randomized, 11/20 completed in the reboxetine group vs. 17/20 in the fluvoxamine group).

Ulmer et al., 2011:^139^ High risk of selection bias and confounding in this small study (N=22); differential attrition (% completers: 82 vs. 67 vs. 100); no description of treatment fidelity; unclear adequacy of randomization and allocation concealment; no masking of outcome assessors. Also, participants received a range of treatments outside of the study varying in intensity and type.

Wagner et al., 2007:^143^ High risk of selection bias and confounding in this small study (N=8) with randomization method unclear, and groups different at baseline (younger in treatment group: mean age 28 vs. 39; more males 75% vs. 0%; more prior trauma and greater injury severity); no description of treatment fidelity; single therapist.

Zlotnick et al., 1997:^145^ High attrition (31%) with completers analysis; no masking of outcome assessors; baseline data not reported to allow comparison of groups for many things (they did run statistical tests for some demographic variables, and report no statistically significant differences); higher baseline scores for DTS, CR-PTSD, and DES for the wait list group.

## References

1 Akuchekian S, Amanat S. The Comparison of Topiramate and Placebo in the Treatment of Posttraumatic Stress Disorder: A Randomized, Double- Blind Study. Journal of Research in Medical Sciences. 2004;9(5):240-4.
2 Arntz A, Tiesema M, Kindt M. Treatment of PTSD: a comparison of imaginal exposure with and without imagery rescripting. J Behav Ther Exp Psychiatry. Dec. 2007;38(4):345-70. [pmid: 18005935].
3 Asukai N, Saito A, Tsuruta N, et al. Efficacy of exposure therapy for Japanese patients with posttraumatic stress disorder due to mixed traumatic events: A randomized controlled study. J Trauma Stress. Dec. 2010;23(6):744-50. [pmid: 21171135].
4 Bartzokis G, Lu PH, Turner J, et al. Adjunctive risperidone in the treatment of chronic combat-related posttraumatic stress disorder. Biol Psychiatry. Mar. 1. 2005;57(5):474-9. [pmid: 15737661].
5 Basoglu M, Salcioglu E, Livanou M. A randomized controlled study of single-session behavioural treatment of earthquake-related post-traumatic stress disorder using an earthquake simulator. Psychol Med. Feb. 2007;37(2):203-13. [pmid: 17254365].
6 Beck JG, Coffey SF, Foy DW, et al. Group cognitive behavior therapy for chronic posttraumatic stress disorder: an initial randomized pilot study. Behavior Therapy. 2009;40(1):82-92. [pmid: 19187819].
7 Becker ME, Hertzberg MA, Moore SD, et al. A placebo-controlled trial of bupropion SR in the treatment of chronic posttraumatic stress disorder. J Clin Psychopharmacol. Apr. 2007;27(2):193-7. [pmid: 17414245].
8 Beidel DC, Frueh BC, Uhde TW, et al. Multicomponent behavioral treatment for chronic combat-related posttraumatic stress disorder: A randomized controlled trial. Journal of Anxiety Disorders. 2011;25(2):224. 2011-01965-008. [pmid: 20951543].
9 Bichescu D, Neuner F, Schauer M, et al. Narrative exposure therapy for political imprisonment-related chronic posttraumatic stress disorder and depression. Behav Res Ther. Sep. 2007;45(9):2212-20. [pmid: 17288990].
10 Blanchard EB, Hickling EJ, Devineni T, et al. A controlled evaluation of cognitive behavioural therapy for posttraumatic stress in motor vehicle accident survivors. Behav Res Ther. Jan. 2003;41(1):79-96. [pmid: 12488121].
11 Boden MT, Kimerling R, Jacobs-Lentz J, et al. Seeking Safety treatment for male veterans with a substance use disorder and post-traumatic stress disorder symptomatology. Addiction. Mar. 2012;107(3):578-86. [pmid: 21923756].
12 Brady K, Pearlstein T, Asnis GM, et al. Efficacy and safety of sertraline treatment of posttraumatic stress disorder: a randomized controlled trial. JAMA. Apr. 12. 2000;283(14):1837-44. [pmid: 10770145].
13 Brady KT, Sonne S, Anton RF, et al. Sertraline in the treatment of co-occurring alcohol dependence and posttraumatic stress disorder. Alcohol Clin Exp Res. Mar. 2005;29(3):395-401. [pmid: 15770115].
14 Braun P, Greenberg D, Dasberg H, et al. Core symptoms of posttraumatic stress disorder unimproved by alprazolam treatment. J Clin Psychiatry. Jun. 1990;51(6):236-8. [pmid: 2189869].
15 Brom D, Kleber RJ, Defares PB. Brief psychotherapy for posttraumatic stress disorders. J Consult Clin Psychol. Oct. 1989;57(5):607-12. [pmid: 2571625].
16 Bryant RA, Moulds ML, Guthrie RM, et al. Imaginal exposure alone and imaginal exposure with cognitive restructuring in treatment of posttraumatic stress disorder. J Consult Clin Psychol. Aug. 2003;71(4):706-12. [pmid: 12924676].
17 Bryant RA, Moulds ML, Guthrie RM, et al. A randomized controlled trial of exposure therapy and cognitive restructuring for posttraumatic stress disorder. J Consult Clin Psychol. Aug. 2008;76(4):695-703. [pmid: 18665697].
18 Butterfield MI, Becker ME, Connor KM, et al. Olanzapine in the treatment of post-traumatic stress disorder: a pilot study. Int Clin Psychopharmacol. Jul. 2001;16(4):197-203. [pmid: 11459333].
19 Carlson JG, Chemtob CM, Rusnak K, et al. Eye movement desensitization and reprocessing (EDMR) treatment for combat-related posttraumatic stress disorder. J Trauma Stress. Jan. 1998;11(1):3-24. [pmid: 9479673].
20 Chard KM. An evaluation of cognitive processing therapy for the treatment of posttraumatic stress disorder related to childhood sexual abuse. J Consult Clin Psychol. Oct. 2005;73(5):965-71. [pmid: 16287396].
21 Cloitre M, Koenen KC, Cohen LR, et al. Skills training in affective and interpersonal regulation followed by exposure: a phase-based treatment for PTSD related to childhood abuse. J Consult Clin Psychol. Oct. 2002;70(5):1067-74. [pmid: 12362957].
22 Cloitre M, Stovall-McClough KC, Nooner K, et al. Treatment for PTSD related to childhood abuse: a randomized controlled trial. Am J Psychiatry. Aug. 2010;167(8):915-24. [pmid: 20595411].
23 Connor KM, Sutherland SM, Tupler LA, et al. Fluoxetine in post-traumatic stress disorder. Randomised, double-blind study. Br J Psychiatry. Jul. 1999;175:17-22. [pmid: 10621763].
24 Meltzer-Brody S, Connor KM, Churchill E, et al. Symptom-specific effects of fluoxetine in post-traumatic stress disorder. Int Clin Psychopharmacol. Jul. 2000;15(4):227-31. [pmid: 10954063].
25 Cook JM, Harb GC, Gehrman PR, et al. Imagery rehearsal for posttraumatic nightmares: a randomized controlled trial. J Trauma Stress. Oct. 2010;23(5):553-63. [pmid: 20839311].
26 Cottraux J, Note I, Yao SN, et al. Randomized controlled comparison of cognitive behavior therapy with Rogerian supportive therapy in chronic post-traumatic stress disorder: a 2-year follow-up. Psychother Psychosom. 2008;77(2):101-10. [pmid: 18230943].
27 Davidson J, Kudler H, Smith R, et al. Treatment of posttraumatic stress disorder with amitriptyline and placebo. Archives of General Psychiatry. 1990;47(3):259. [pmid: 2407208].
28 Davidson JR, Kudler HS, Saunders WB, et al. Predicting response to amitriptyline in posttraumatic stress disorder. Am J Psychiatry. Jul. 1993;150(7):1024-9. [pmid: 8317571].
29 Davidson JR, Rothbaum BO, van der Kolk BA, et al. Multicenter, double-blind comparison of sertraline and placebo in the treatment of posttraumatic stress disorder. Arch Gen Psychiatry. May. 2001;58(5):485-92. [pmid: 11343529].
30 Davidson JR, Weisler RH, Butterfield MI, et al. Mirtazapine vs. placebo in posttraumatic stress disorder: a pilot trial. Biol Psychiatry. Jan. 15. 2003;53(2):188-91. [pmid: 12547477].
31 Davidson J, Rothbaum BO, Tucker P, et al. Venlafaxine extended release in posttraumatic stress disorder: a sertraline- and placebo-controlled study. J Clin Psychopharmacol. Jun. 2006;26(3):259-67. [pmid: 16702890].
32 Davidson J, Baldwin D, Stien DJ, et al. Treatment of Posttraumatic Stress Disorder With Venlafaxine Extended Release. Archives of General Psychiatry. 2006;63(10):1158. 2006-13321-012. [pmid: 17015818].
33 Davidson JR, Brady K, Mellman TA, et al. The efficacy and tolerability of tiagabine in adult patients with post-traumatic stress disorder. J Clin Psychopharmacol. Feb. 2007;27(1):85-8. [pmid: 17224720].
34 Davis LL, Jewell ME, Ambrose S, et al. A placebo-controlled study of nefazodone for the treatment of chronic posttraumatic stress disorder: a preliminary study. J Clin Psychopharmacol. Jun. 2004;24(3):291-7. [pmid: 15118483].
35 Davis LL, Davidson JR, Ward LC, et al. Divalproex in the treatment of posttraumatic stress disorder: a randomized, double-blind, placebo-controlled trial in a veteran population. J Clin Psychopharmacol. Feb. 2008;28(1):84-8. [pmid: 18204347].
36 Devilly GJ, Spence SH. The relative efficacy and treatment distress of EMDR and a cognitive-behavior trauma treatment protocol in the amelioration of posttraumatic stress disorder. J Anxiety Disord. Jan–Apr. 1999;13(1–2):131-57. [pmid: 10225505].
37 Difede J, Cukor J, Jayasinghe N, et al. Virtual reality exposure therapy for the treatment of posttraumatic stress disorder following September 11, 2001. J Clin Psychiatry. Nov. 2007;68(11):1639-47. [pmid: 18052556].
38 Difede J, Malta LS, Best S, et al. A randomized controlled clinical treatment trial for World Trade Center attack-related PTSD in disaster workers. J Nerv Ment Dis. Oct. 2007;195(10):861-5. [pmid: 18043528].
39 Echeburua E, De Corral P, Sarasua B, et al. Treatment of acute posttraumatic stress disorder in rape victims: An experimental study. Journal of Anxiety Disorders. 1996;10(3):185-99.
40 Echeburua E, de Corral P, Zubizarreta I, et al. Psychological treatment of chronic posttraumatic stress disorder in victims of sexual aggression. Behav Modif. Oct. 1997;21(4):433-56. [pmid: 9337600].
41 Ehlers A, Clark DM, Hackmann A, et al. A randomized controlled trial of cognitive therapy, a self-help booklet, and repeated assessments as early interventions for posttraumatic stress disorder. Archives of General Psychiatry. 2003;60(10):1024-32. [pmid: 14557148].
42 Ehlers A, Clark DM, Hackmann A, et al. Cognitive therapy for post-traumatic stress disorder: development and evaluation. Behav Res Ther. Apr. 2005;43(4):413-31. [pmid: 15701354].
43 Fecteau G, Nicki R. Cognitive behavioural treatment of post traumatic stress disorder after motor vehicle accident. Behavioural and Cognitive Psychotherapy. 1999;27(3):201-14.
44 Feske U. Treating low-income and minority women with posttraumatic stress disorder: a pilot study comparing prolonged exposure and treatment as usual conducted by community therapists. J Interpers Violence. Aug. 2008;23(8):1027-40. [pmid: 18292398].
45 Foa EB, Rothbaum BO, Riggs DS, et al. Treatment of posttraumatic stress disorder in rape victims: a comparison between cognitive-behavioral procedures and counseling. J Consult Clin Psychol. Oct. 1991;59(5):715-23. [pmid: 1955605].
46 Foa EB, Hembree EA, Cahill SP, et al. Randomized trial of prolonged exposure for posttraumatic stress disorder with and without cognitive restructuring: outcome at academic and community clinics. J Consult Clin Psychol. Oct. 2005;73(5):953-64. [pmid: 16287395].
47 Foa EB, Dancu CV, Hembree EA, et al. A comparison of exposure therapy, stress inoculation training, and their combination for reducing posttraumatic stress disorder in female assault victims. J Consult Clin Psychol. Apr. 1999;67(2):194-200. [pmid: 10224729].
48 Zoellner LA, Feeny NC, Fitzgibbons LA, et al. Response of African American and Caucasian women to cognitive behavioral therapy for PTSD. Behavior Therapy. 1999;30(4):581-95.
49 Forbes D, Lloyd D, Nixon RDV, et al. A multisite randomized controlled effectiveness trial of cognitive processing therapy for military-related posttraumatic stress disorder. Journal of Anxiety Disorders. 2012;26(3):442-52. [pmid: 22366446].
50 Ford JD, Steinberg KL, Zhang W. A randomized clinical trial comparing affect regulation and social problem-solving psychotherapies for mothers with victimization-related PTSD. Behavior therapy. 2011;42(4):560-78. First Author & Affiliation: Ford, Julian D. [pmid: 22035986].
51 Friedman MJ, Marmar CR, Baker DG, et al. Randomized, double-blind comparison of sertraline and placebo for posttraumatic stress disorder in a Department of Veterans Affairs setting. J Clin Psychiatry. May. 2007;68(5):711-20. [pmid: 17503980].
52 Frommberger U, Stieglitz RD, Nyberg E, et al. Comparison between paroxetine and behaviour therapy in patients with posttraumatic stress disorder (PTSD): A pilot study. International Journal of Psychiatry in Clinical Practice. 2004;8(1):19-23.
53 Gamito P, Oliveira J, Rosa P, et al. PTSD elderly war veterans: a clinical controlled pilot study. Cyberpsychol Behav Soc Netw. Feb. 2010;13(1):43-8. [pmid: 20528292].
54 Gersons BP, Carlier IV, Lamberts RD, et al. Randomized clinical trial of brief eclectic psychotherapy for police officers with posttraumatic stress disorder. J Trauma Stress. Apr. 2000;13(2):333-47. [pmid: 10838679].
55 Hamner MB, Faldowski RA, Ulmer HG, et al. Adjunctive risperidone treatment in post-traumatic stress disorder: a preliminary controlled trial of effects on comorbid psychotic symptoms. Int Clin Psychopharmacol. Jan. 2003;18(1):1-8. [pmid: 12490768].
56 Hamner MB, Faldowski RA, Robert S, et al. A preliminary controlled trial of divalproex in posttraumatic stress disorder. Ann Clin Psychiatry. Apr–Jun. 2009;21(2):89-94. [pmid: 19439158].
57 Hensel-Dittmann D, Schauer M, Ruf M, et al. Treatment of traumatized victims of war and torture: A randomized controlled comparison of narrative exposure therapy and stress inoculation training. Psychother Psychosom. 2011;80(6):345-52. 2011-29267-004. First Author & Affiliation: Hensel-Dittmann, D. [pmid: 21829046].
58 Hertzberg MA, Butterfield MI, Feldman ME, et al. A preliminary study of lamotrigine for the treatment of posttraumatic stress disorder. Biol Psychiatry. May. 1. 1999;45(9):1226-9. [pmid: 10331117].
59 Hertzberg MA, Feldman ME, Beckham JC, et al. Lack of efficacy for fluoxetine in PTSD: a placebo controlled trial in combat veterans. Ann Clin Psychiatry. Jun. 2000;12(2):101-5. [pmid: 10907802].
60 Hien DA, Cohen LR, Miele GM, et al. Promising treatments for women with comorbid PTSD and substance use disorders. Am J Psychiatry. Aug. 2004;161(8):1426-32. [pmid: 15285969].
61 Hien DA, Wells EA, Jiang H, et al. Multisite randomized trial of behavioral interventions for women with co-occurring PTSD and substance use disorders. J Consult Clin Psychol. Aug. 2009;77(4):607-19. [pmid: 19634955].
62 Hien DA, Morgan-Lopez AA, Campbell ANC, et al. Attendance and substance use outcomes for the Seeking Safety program: sometimes less is more. Journal of consulting and clinical psychology. 2012;80(1):29-42. [pmid: 22182262].
63 Hinton DE, Chhean D, Pich V, et al. A randomized controlled trial of cognitive-behavior therapy for Cambodian refugees with treatment-resistant PTSD and panic attacks: a cross-over design. J Trauma Stress. Dec. 2005;18(6):617-29. [pmid: 16382423].
64 Hinton DE, Hofmann SG, Pollack MH, et al. Mechanisms of efficacy of CBT for Cambodian refugees with PTSD: improvement in emotion regulation and orthostatic blood pressure response. CNS Neurosci Ther. Fall. 2009;15(3):255-63. [pmid: 19691545].
65 Hinton DE, Hofmann SG, Rivera E, et al. Culturally adapted CBT (CA-CBT) for Latino women with treatment-resistant PTSD: a pilot study comparing CA-CBT to applied muscle relaxation. Behav Res Ther. Apr. 2011;49(4):275-80. [pmid: 21333272].
66 Hogberg G, Pagani M, Sundin O, et al. On treatment with eye movement desensitization and reprocessing of chronic post-traumatic stress disorder in public transportation workers - A randomized controlled trial. Nordic Journal of Psychiatry. 2007;61(1):54-61. WOS:000245235400009. [pmid: 17365790].
67 Hollifield M, Sinclair-Lian N, Warner TD, et al. Acupuncture for posttraumatic stress disorder: a randomized controlled pilot trial. J Nerv Ment Dis. Jun. 2007;195(6):504-13. [pmid: 17568299].
68 Ironson G, Freund B, Strauss JL, et al. Comparison of two treatments for traumatic stress: A community-based study of EMDR and prolonged exposure. Journal of Clinical Psychology. 2002;58(1):113-28. [pmid: 11748600].
69 Johnson DR, Lubin H. The Counting Method: applying the rule of parsimony to the treatment of posttraumatic stress disorder. Traumatology. 2006;12(1):83-99.
70 Johnson DM, Zlotnick C, Perez S. Cognitive behavioral treatment of ptsd in residents of battered women’s shelters: Results of a randomized clinical trial. Journal of Consulting and Clinical Psychology. 2011;79(4):542-51. [pmid: 21787052].
71 Karatzias T, Power K, Brown K, et al. A controlled comparison of the effectiveness and efficiency of two psychological therapies for posttraumatic stress disorder: eye movement desensitization and reprocessing vs. emotional freedom techniques. J Nerv Ment Dis. Jun. 2011;199(6):372-8. [pmid: 21629014].
72 Keane TM, Fairbank JA, Caddell JM, et al. Implosive (flooding) therapy reduces symptoms of PTSD in Vietnam combat veterans. Behavior Therapy. 1989;20(2):245-60.
73 Kosten TR, Frank JB, Dan E, et al. Pharmacotherapy for posttraumatic stress disorder using phenelzine or imipramine. J Nerv Ment Dis. Jun. 1991;179(6):366-70. [pmid: 2051152].
74 Krakow B, Hollifield M, Schrader R, et al. A controlled study of imagery rehearsal for chronic nightmares in sexual assault survivors with PTSD: a preliminary report. J Trauma Stress. Oct. 2000;13(4):589-609. [pmid: 11109233].
75 Krakow B, Hollifield M, Johnston L, et al. Imagery rehearsal therapy for chronic nightmares in sexual assault survivors with posttraumatic stress disorder: a randomized controlled trial. JAMA. Aug. 1. 2001;286(5):537-45. [pmid: 11476655].
76 Krupnick JL, Green BL, Stockton P, et al. Group interpersonal psychotherapy for low-income women with posttraumatic stress disorder. Psychother Res. Sep. 2008;18(5):497-507. [pmid: 18816001].
77 Kruse J, Joksimovic L, Cavka M, et al. Effects of trauma-focused psychotherapy upon war refugees. J Trauma Stress. Dec. 2009;22(6):585-92. [pmid: 19960519].
78 Krystal JH, Rosenheck RA, Cramer JA, et al. Adjunctive risperidone treatment for antidepressant-resistant symptoms of chronic military service-related PTSD: a randomized trial. JAMA. Aug. 3. 2011;306(5):493-502. [pmid: 21813427].
79 Kubany ES, Hill EE, Owens JA. Cognitive trauma therapy for battered women with PTSD: preliminary findings. J Trauma Stress. Feb. 2003;16(1):81-91. [pmid: 12602656].
80 Kubany ES, Hill EE, Owens JA, et al. Cognitive trauma therapy for battered women with PTSD (CTT-BW). J Consult Clin Psychol. Feb. 2004;72(1):3-18. [pmid: 14756610].
81 Lee C, Gavriel H, Drummond P, et al. Treatment of PTSD: stress inoculation training with prolonged exposure compared to EMDR. J Clin Psychol. Sep. 2002;58(9):1071-89. [pmid: 12209866].
82 Liedl A, Muller J, Morina N, et al. Physical activity within a CBT intervention improves coping with pain in traumatized refugees: results of a randomized controlled design. Pain Med. Feb. 2011;12(2):234-45. [pmid: 21223501].
83 Lindauer RJ, Gersons BP, van Meijel EP, et al. Effects of brief eclectic psychotherapy in patients with posttraumatic stress disorder: randomized clinical trial. J Trauma Stress. Jun. 2005;18(3):205-12. [pmid: 16281214].
84 Lindley SE, Carlson EB, Hill K. A randomized, double-blind, placebo-controlled trial of augmentation topiramate for chronic combat-related posttraumatic stress disorder. J Clin Psychopharmacol. Dec. 2007;27(6):677-81. [pmid: 18004136].
85 Litz BT, Engel CC, Bryant RA, et al. A randomized, controlled proof-of-concept trial of an Internet-based, therapist-assisted self-management treatment for posttraumatic stress disorder. Am J Psychiatry. Nov. 2007;164(11):1676-83. [pmid: 17974932].
86 Marcus SV, Marquis P, Sakai C. Controlled study of treatment of PTSD using EMDR in an HMO setting. Psychotherapy. Fal. 1997;34(3):307-15. WOS:000071116000010.
87 Marks I, Lovell K, Noshirvani H, et al. Treatment of posttraumatic stress disorder by exposure and/or cognitive restructuring: a controlled study. Arch Gen Psychiatry. Apr. 1998;55(4):317-25. [pmid: 9554427].
88 Lovell K, Marks IM, Noshirvani H, et al. Do cognitive and exposure treatments improve various PTSD symptoms differently?: a randomized controlled trial. Behavioural and Cognitive Psychotherapy. 2001;29(1):107-12.
89 Marshall RD, Beebe KL, Oldham M, et al. Efficacy and safety of paroxetine treatment for chronic PTSD: a fixed-dose, placebo-controlled study. Am J Psychiatry. Dec. 2001;158(12):1982-8. [pmid: 11729013].
90 Marshall RD, Lewis-Fernandez R, Blanco C, et al. A controlled trial of paroxetine for chronic PTSD, dissociation, and interpersonal problems in mostly minority adults. Depress Anxiety. 2007;24(2):77-84. [pmid: 16892419].
91 Martenyi F, Brown EB, Zhang H, et al. Fluoxetine versus placebo in posttraumatic stress disorder. J Clin Psychiatry. Mar. 2002;63(3):199-206. [pmid: 11926718].
92 Martenyi F, Soldatenkova V. Fluoxetine in the acute treatment and relapse prevention of combat-related post-traumatic stress disorder: Analysis of the veteran group of a placebo-controlled, randomized clinical trial. Eur Neuropsychopharmacol. Jul. 2006;16(5):340-9. [pmid: 16356696].
93 Martenyi F, Brown EB, Caldwell CD. Failed efficacy of fluoxetine in the treatment of posttraumatic stress disorder: results of a fixed-dose, placebo-controlled study. J Clin Psychopharmacol. Apr. 2007;27(2):166-70. [pmid: 17414240].
94 McDonagh A, Friedman M, McHugo G, et al. Randomized trial of cognitive-behavioral therapy for chronic posttraumatic stress disorder in adult female survivors of childhood sexual abuse. J Consult Clin Psychol. Jun. 2005;73(3):515-24. [pmid: 15982149].
95 McLay RN, Wood DP, Webb-Murphy JA, et al. A randomized, controlled trial of virtual reality-graded exposure therapy for post-traumatic stress disorder in active duty service members with combat-related post-traumatic stress disorder. Cyberpsychol Behav Soc Netw. Apr. 2011;14(4):223-9. [pmid: 21332375].
96 McRae AL, Brady KT, Mellman TA, et al. Comparison of nefazodone and sertraline for the treatment of posttraumatic stress disorder. Depress Anxiety. 2004;19(3):190-6. [pmid: 15129422].
97 Monnelly EP, Ciraulo DA, Knapp C, et al. Low-dose risperidone as adjunctive therapy for irritable aggression in posttraumatic stress disorder. J Clin Psychopharmacol. Apr. 2003;23(2):193-6. [pmid: 12640221].
98 Monson CM, Schnurr PP, Resick PA, et al. Cognitive processing therapy for veterans with military-related posttraumatic stress disorder. J Consult Clin Psychol. Oct. 2006;74(5):898-907. [pmid: 17032094].
99 Mueser KT, Rosenberg SD, Xie H, et al. A randomized controlled trial of cognitive-behavioral treatment for posttraumatic stress disorder in severe mental illness. J Consult Clin Psychol. Apr. 2008;76(2):259-71. [pmid: 18377122].
100 Nacasch N, Foa EB, Huppert JD, et al. Prolonged exposure therapy for combat- and terror-related posttraumatic stress disorder: a randomized control comparison with treatment as usual. J Clin Psychiatry. Sep. 2011;72(9):1174-80. [pmid: 21208581].
101 Neuner F, Schauer M, Klaschik C, et al. A comparison of narrative exposure therapy, supportive counseling, and psychoeducation for treating posttraumatic stress disorder in an african refugee settlement. J Consult Clin Psychol. Aug. 2004;72(4):579-87. [pmid: 15301642].
102 Neuner F, Onyut PL, Ertl V, et al. Treatment of posttraumatic stress disorder by trained lay counselors in an African refugee settlement: a randomized controlled trial. J Consult Clin Psychol. Aug. 2008;76(4):686-94. [pmid: 18665696].
103 Neuner F, Kurreck S, Ruf M, et al. Can asylum-seekers with posttraumatic stress disorder be successfully treated? A randomized controlled pilot study. Cogn Behav Ther. Jun. 2010;39(2):81-91. [pmid: 19816834].
104 Nijdam MJ, Gersons BPR, Reitsma JB, et al. Brief eclectic psychotherapy v. eye movement desensitisation and reprocessing therapy for post-traumatic stress disorder: randomised controlled trial. British Journal of Psychiatry. Mar. 2012;200(3):224-31. WOS:000301829700011. [pmid: 22322458].
105 Panahi Y, Moghaddam BR, Sahebkar A, et al. A randomized, double-blind, placebo-controlled trial on the efficacy and tolerability of sertraline in Iranian veterans with post-traumatic stress disorder. Psychol Med. Oct. 2011;41(10):2159-66. [pmid: 21349225].
106 Otto MW, Hinton D, Korbly NB, et al. Treatment of pharmacotherapy-refractory posttraumatic stress disorder among Cambodian refugees: a pilot study of combination treatment with cognitive-behavior therapy vs sertraline alone. Behav Res Ther. Nov. 2003;41(11):1271-6. [pmid: 14527527].
107 Padala PR, Madison J, Monnahan M, et al. Risperidone monotherapy for post-traumatic stress disorder related to sexual assault and domestic abuse in women. Int Clin Psychopharmacol. Sep. 2006;21(5):275-80. [pmid: 16877898].
108 Paunovic N, Ost LG. Cognitive-behavior therapy vs exposure therapy in the treatment of PTSD in refugees. Behav Res Ther. Oct. 2001;39(10):1183-97. [pmid: 11579988].
109 Petrakis IL, Ralevski E, Desai N, et al. Noradrenergic vs Serotonergic Antidepressant with or without Naltrexone for Veterans with PTSD and Comorbid Alcohol Dependence. Neuropsychopharmacology. Mar. 2012;37(4):996-1004. [pmid: 22089316].
110 Power K, McGoldrick T, Brown K, et al. A controlled comparison of eye movement desensitization and reprocessing versus exposure plus cognitive restructuring versus waiting list in the treatment of post-traumatic stress disorder. Clinical Psychology & Psychotherapy. Sep–Oct. 2002;9(5):299-318. WOS:000178998300001.
111 Raskind MA, Peskind ER, Kanter ED, et al. Reduction of nightmares and other PTSD symptoms in combat veterans by prazosin: a placebo-controlled study. Am J Psychiatry. Feb. 2003;160(2):371-3. [pmid: 12562588].
112 Raskind MA, Peskind ER, Hoff DJ, et al. A parallel group placebo controlled study of prazosin for trauma nightmares and sleep disturbance in combat veterans with post-traumatic stress disorder. Biol Psychiatry. Apr. 15. 2007;61(8):928-34. [pmid: 17069768].
113 Rauch SA, Grunfeld TE, Yadin E, et al. Changes in reported physical health symptoms and social function with prolonged exposure therapy for chronic posttraumatic stress disorder. Depress Anxiety. 2009;26(8):732-8. [pmid: 18781660].
114 Ready DJ, Gerardi RJ, Backscheider AG, et al. Comparing virtual reality exposure therapy to present-centered therapy with 11 U.S. Vietnam veterans with PTSD. Cyberpsychol Behav Soc Netw. Feb. 2010;13(1):49-54. [pmid: 20528293].
115 Reich DB, Winternitz S, Hennen J, et al. A preliminary study of risperidone in the treatment of posttraumatic stress disorder related to childhood abuse in women. J Clin Psychiatry. Dec. 2004;65(12):1601-6. [pmid: 15641864].
116 Reist C, Kauffmann CD, Haier RJ, et al. A controlled trial of desipramine in 18 men with posttraumatic stress disorder. Am J Psychiatry. Apr. 1989;146(4):513-6. [pmid: 2648867].
117 Resick PA, Nishith P, Weaver TL, et al. A comparison of cognitive-processing therapy with prolonged exposure and a waiting condition for the treatment of chronic posttraumatic stress disorder in female rape victims. J Consult Clin Psychol. Aug. 2002;70(4):867-79. [pmid: 12182270].
118 Resick PA, Nishith P, Griffin MG. How well does cognitive-behavioral therapy treat symptoms of complex PTSD? An examination of child sexual abuse survivors within a clinical trial. CNS Spectr. May. 2003;8(5):340-55. [pmid: 12766690].
119 Resick PA, Williams LF, Suvak MK, et al. Long-term outcomes of cognitive-behavioral treatments for posttraumatic stress disorder among female rape survivors. Journal of consulting and clinical psychology. 2012;80(2):201-10. [pmid: 22182261].
120 Rothbaum BO. A controlled study of eye movement desensitization and reprocessing in the treatment of posttraumatic stress disordered sexual assault victims. Bull Menninger Clin. Summer. 1997;61(3):317-34. [pmid: 9260344].
121 Rothbaum BO, Astin MC, Marsteller F. Prolonged Exposure versus Eye Movement Desensitization and Reprocessing (EMDR) for PTSD rape victims. J Trauma Stress. Dec. 2005;18(6):607-16. [pmid: 16382428].
122 Rothbaum BO, Cahill SP, Foa EB, et al. Augmentation of sertraline with prolonged exposure in the treatment of posttraumatic stress disorder. J Trauma Stress. Oct. 2006;19(5):625-38. [pmid: 17075912].
123 Rothbaum BO, Killeen TK, Davidson JR, et al. Placebo-controlled trial of risperidone augmentation for selective serotonin reuptake inhibitor-resistant civilian posttraumatic stress disorder. J Clin Psychiatry. Apr. 2008;69(4):520-5. [pmid: 18278987].
124 Schneier FR, Neria Y, Pavlicova M, et al. Combined prolonged exposure therapy and paroxetine for PTSD related to the World Trade Center attack: a randomized controlled trial. Am J Psychiatry. Jan. 2012;169(1):80-8. [pmid: 21908494].
125 Schnurr PP, Friedman MJ, Foy DW, et al. Randomized trial of trauma-focused group therapy for posttraumatic stress disorder - Results from a Department of Veterans Affairs Cooperative Study. Archives of General Psychiatry. May. 2003;60(5):481-9. WOS:000182735000006. [pmid: 12742869].
126 Schnurr PP, Friedman MJ, Engel CC, et al. Cognitive behavioral therapy for posttraumatic stress disorder in women - A randomized controlled trial. Journal of the American Medical Association. Feb. 2007;297(8):820-30. WOS:000244485000025. [pmid: 17327524].
127 Schnyder U, Muller J, Maercker A, et al. Brief eclectic psychotherapy for PTSD: a randomized controlled trial. J Clin Psychiatry. Apr. 2011;72(4):564-6. [pmid: 21527127].
128 Simon NM, Connor KM, Lang AJ, et al. Paroxetine CR augmentation for posttraumatic stress disorder refractory to prolonged exposure therapy. J Clin Psychiatry. Mar. 2008;69(3):400-5. [pmid: 18348595].
129 Spence J, Titov N, Dear BF, et al. Randomized controlled trial of Internet-delivered cognitive behavioral therapy for posttraumatic stress disorder. Depress Anxiety. Jul. 2011;28(7):541-50. [pmid: 21721073].
130 Spivak B, Strous RD, Shaked G, et al. Reboxetine versus fluvoxamine in the treatment of motor vehicle accident-related posttraumatic stress disorder: a double-blind, fixed-dosage, controlled trial. J Clin Psychopharmacol. Apr. 2006;26(2):152-6. [pmid: 16633143].
131 Stein MB, Kline NA, Matloff JL. Adjunctive olanzapine for SSRI-resistant combat-related PTSD: a double-blind, placebo-controlled study. Am J Psychiatry. Oct. 2002;159(10):1777-9. [pmid: 12359687].
132 Tarrier N, Pilgrim H, Sommerfield C, et al. A randomized trial of cognitive therapy and imaginal exposure in the treatment of chronic posttraumatic stress disorder. J Consult Clin Psychol. Feb. 1999;67(1):13-8. [pmid: 10028204].
133 Tarrier N, Sommerfield C, Pilgrim H, et al. Cognitive therapy or imaginal exposure in the treatment of post-traumatic stress disorder. Twelve-month follow-up. Br J Psychiatry. Dec. 1999;175:571-5. [pmid: 10789356].
134 Taylor S, Thordarson DS, Maxfield L, et al. Comparative efficacy, speed, and adverse effects of three PTSD treatments: exposure therapy, EMDR, and relaxation training. J Consult Clin Psychol. Apr. 2003;71(2):330-8. [pmid: 12699027].
135 Tucker P, Zaninelli R, Yehuda R, et al. Paroxetine in the treatment of chronic posttraumatic stress disorder: results of a placebo-controlled, flexible-dosage trial. J Clin Psychiatry. Nov. 2001;62(11):860-8. [pmid: 11775045].
136 Tucker P, Potter-Kimball R, Wyatt DB, et al. Can physiologic assessment and side effects tease out differences in PTSD trials? A double-blind comparison of citalopram, sertraline, and placebo. Psychopharmacol Bull. Summer. 2003;37(3):135-49. [pmid: 14608246].
137 Tucker P, Ruwe WD, Masters B, et al. Neuroimmune and cortisol changes in selective serotonin reuptake inhibitor and placebo treatment of chronic posttraumatic stress disorder. Biol Psychiatry. Jul. 15. 2004;56(2):121-8. [pmid: 15231444].
138 Tucker P, Trautman RP, Wyatt DB, et al. Efficacy and safety of topiramate monotherapy in civilian posttraumatic stress disorder: a randomized, double-blind, placebo-controlled study. J Clin Psychiatry. Feb. 2007;68(2):201-6. [pmid: 17335317].
139 Ulmer CS, Edinger JD, Calhoun PS. A multi-component cognitive-behavioral intervention for sleep disturbance in veterans with PTSD: a pilot study. J Clin Sleep Med. Feb. 15. 2011;7(1):57-68. [pmid: 21344046].
140 van der Kolk BA, Dreyfuss D, Michaels M, et al. Fluoxetine in posttraumatic stress disorder. J Clin Psychiatry. Dec. 1994;55(12):517-22. [pmid: 7814344].
141 van der Kolk BA, Spinazzola J, Blaustein ME, et al. A randomized clinical trial of eye movement desensitization and reprocessing (EMDR), fluoxetine, and pill placebo in the treatment of posttraumatic stress disorder: treatment effects and long-term maintenance. J Clin Psychiatry. Jan. 2007;68(1):37-46. [pmid: 17284128].
142 van Emmerik AA, Kamphuis JH, Emmelkamp PM. Treating acute stress disorder and posttraumatic stress disorder with cognitive behavioral therapy or structured writing therapy: a randomized controlled trial. Psychother Psychosom. 2008;77(2):93-100. [pmid: 18230942].
143 Wagner AW, Zatzick DF, Ghesquiere A, et al. Behavioral Activation as an Early Intervention for Posttraumatic Stress Disorder and Depression Among Physically Injured Trauma Survivors. Cognitive and Behavioral Practice. 2007;14(4):341-9.
144 Yeh MS, Mari JJ, Costa MC, et al. A double-blind randomized controlled trial to study the efficacy of topiramate in a civilian sample of PTSD. CNS Neurosci Ther. Oct. 2011;17(5):305-10. [pmid: 21554564].
145 Zlotnick C, Shea TM, Rosen K, et al. An affect-management group for women with posttraumatic stress disorder and histories of childhood sexual abuse. Journal of Traumatic Stress. 1997;10(3):425-36. [pmid: 9246650].
146 Zlotnick C, Johnson J, Najavits LM. Randomized controlled pilot study of cognitive-behavioral therapy in a sample of incarcerated women with substance use disorder and PTSD. Behav Ther. Dec. 2009;40(4):325-36. [pmid: 19892078].
147 Zohar J, Amital D, Miodownik C, et al. Double-blind placebo-controlled pilot study of sertraline in military veterans with posttraumatic stress disorder. J Clin Psychopharmacol. Apr. 2002;22(2):190-5. [pmid: 11910265].