# Secondary Stone Recurrence Outcomes Tables

Appendix E. Table 1a Secondary stone recurrence outcomes for diet trials

Study | Definition of Stone Recurrence | Stone Recurrence Rate | | Change in Stone Size | | Residual or Stone Fragment Clearance
Study | Definition of Stone Recurrence | Diet | Control or Diet B | Diet | Control or Diet B | Diet | Control or Diet B
Dussol 2008^1^ | [underlined: Composite]: a) symptomatic - passage of stone or stone confirmed radio-logically based on colic or hematuria or b) silent- appearance of a new stone or a >50% increase in size of a previously present stone on radiological or ultrasound exams. | NR | NR | 3 patients had an increase of >50% (silent recurrence) but the authors did not report to which study arms the patients were randomized. | | NR | NR
Sarica 2006^2^ | [underlined: Radiographic]: Plain abdominal X-ray (including renal tomography), kidney sonography or excretory urogram at regular intervals (3, 6, and 12 months after stone disintegration) | NR | NR | NR | NR
Borghi 2002^3^ | [underlined: Composite]: Passage of stone or stone identified by annual ultrasound and abdominal flat-plate examinations | NR | NR | NR | NR | NR | NR
Di Silverio 2000^4^ | [underlined: Radiographic]: X-ray and abdominal echographic studies upon recruitment and thereafter every 6 months until the onset of recurrence. | NR | NR | NR | NR | NR | NR
Kocvara 1999^5^ | [underlined: Composite]: radiography and ultrasonography (but over half of the stones were “asymptomatic”) so symptomatic passage also | NR | NR | NR | NR | NR | NR
Borghi 1996^6^ | [underlined: Composite]: Passage of stone, renal colic, annual x-ray and ultrasound screening | Mean time to 1^st^ recurrence (months) 38.7 (SD 13.2) P=0.016 | Mean time to 1^st^ recurrence (months) 25.1 (SD 16.4) | NR | NR | NR | NR
Hiatt 1996^7^ | [underlined: Composite]: Passage of stone, surgical removal or annual radiological detection of previously unrecognized stone | 7.1 per 100 person-years P=0.006 | 1.2 per 100 person-years | NR | NR | NR | NR
Shuster 1992^8^ | [underlined: Symptomatic]: Self reported stone episode, possibly confirmed by physician | NR | NR | NR | NR | NR | NR

Abbreviation: NR = not reported

Appendix E. Table 1b Health outcomes for diet trials

Study | Pain % (n/N) | | Urinary Tract Obstruction with Acute Renal Failure % (n/N) | | Infection % (n/N) | | Procedure-Related Morbidity % (n/N)
Study | Diet | Control or Diet B | Diet | Control or Diet B | Diet | Control or Diet B | Diet | Control or Diet B
Dussol 2008^1^ | NR | NR | NR | NR | NR | NR | NR | NR
Sarica 2006^2^ | NR | NR | NR | NR | NR | NR | NR | NR
Borghi 2002^3^ | NR | NR | NR | NR | NR | NR | NR | NR
Di Silverio 2000^4^ | NR | NR | NR | NR | NR | NR | NR | NR
Kocvara 1999^5^ | NR | NR | NR | NR | NR | NR | NR | NR
Borghi 1996^6^ | NR | NR | NR | NR | NR | NR | NR | NR
Hiatt 1996^7^ | NR | NR | NR | NR | NR | NR | NR | NR
Shuster 1992^8^ | NR | NR | NR | NR | NR | NR | NR | NR

Abbreviation: NR = not reported

Appendix E. Table 1c Health outcomes for diet trials

Study | Emergency Room Treatment Related to Stone Recurrence (e.g., renal colic) % (n/N) | | Hospitalizations Related to Stone Recurrence (e.g., renal colic) % (n/N) | | Quality of Life
Study | Diet | Control or Diet B | Diet | Control or Diet B | Diet | Control or Diet B
Dussol 2008^1^ | NR | NR | NR | NR | NR | NR
Sarica 2006^2^ | NR | NR | NR | NR | NR | NR
Borghi 2002^3^ | NR | NR | NR | NR | NR | NR
Di Silverio 2000^4^ | NR | NR | NR | NR | NR | NR
Kocvara 1999^5^ | NR | NR | NR | NR | NR | NR
Borghi 1996^6^ | NR | NR | NR | NR | NR | NR
Hiatt 1996^7^ | NR | NR | NR | NR | NR | NR
Shuster 1992^8^ | NR | NR | NR | NR | NR | NR

Abbreviation: NR = not reported

Appendix E. Table 2a Secondary stone recurrence outcomes for thiazide trials

Study | Definition of Stone Recurrence | Stone Recurrence Rate | | Change in Stone Size | | Stone Fragment Clearance
Study | Definition of Stone Recurrence | Thiazide | Control(s) | Thiazide | Control(s) | Thiazide | Control(s)
Fernández-Rodriguez, 2006^9^ | [underlined: Composite]: Passage or removal of any stone; radiologically detected new stone (plain x-ray every 6 months for 3 years). | NR | NR | NR | NR | NR | NR
Ahlstrand, 1995^10^ | [underlined: Composite]: x-ray examinations annually and “at clinical events” | NR | NR | NR | NR | NR | NR
Borghi, 1993^11^ | [underlined: Composite]: Passage or removal of any stone; radiologically detected new stone (x-ray abdominal falte plate with renal tomograms at 6 & 12 months, then annually through 3 years). | NR | NR | NR | NR | NR | NR
Ettinger, 1988^12^ | [underlined: Composite]: Passage of previously unrecognized stone >3 months after baseline; or radiologically detected new stone or enlargement in residual fragment (annual x-ray) | NR | NR | NR | NR | NR | NR
Ala-Opas, 1987^13^ | [underlined: Composite]: Passage or removal of stone; or radiologically detected new stone (x-ray every 6 months). | Normocalciuric patients 0.18 stones per patient year; reduction from pretreatment of 0.41 stones per patient year P<0.0005 versus pretreatment Hypercalciuric patients 0.21 stones per patient year; reduction from pretreatment of 0.30 stones per patient year P<0.10 versus pretreatment | Normocalciuric patients 0.17 stones per patient year; reduction from pretreatment of 0.30 stones per patient year P<0.0005 versus pretreatment Hypercalciuric patients 0.25 stones per patient year; reduction from pretreatment of 0.54 stones per patient year P<0.05 versus pretreatment | NR | NR | NR | NR
Laerum, 1984^14^ | [underlined: Composite]: Passage of new stone; or radiologically detected new stone (annual plain abdominal x-ray plus pyelography and tomography in ambiguous cases). | NR | NR | NR | NR | NR | NR
Scholz, 1982^15^ | [underlined: Symptomatic]: Passage of new stone. | NR | NR | NR | NR | NR | NR

Abbreviation: NR = not reported

Appendix E. Table 2b Health outcomes for thiazide trials

Study | Pain % (n/N) | | Urinary Tract Obstruction with Acute Renal Failure % (n/N) | | Infection % (n/N) | | Procedure-related Morbidity % (n/N)
Study | Thiazide | Control(s) | Thiazide | Control(s) | Thiazide | Control(s) | Thiazide | Control(s)
Fernández-Rodriguez, 2006^9^ | NR | NR | NR | NR | NR | NR | NR | NR
Ahlstrand, 1995^10^ | NR | NR | NR | NR | NR | NR | NR | NR
Borghi, 1993^11^ | NR | NR | NR | NR | NR | NR | NR | NR
Ettinger, 1988^12^ | NR | NR | NR | NR | NR | NR | NR | NR
Ala-Opas, 1987^13^ | NR | NR | NR | NR | NR | NR | NR | NR
Laerum, 1984^14^ | NR | NR | NR | NR | NR | NR | NR | NR
Scholz, 1982^15^ | NR | NR | NR | NR | NR | NR | NR | NR

Abbreviation: NR = not reported

Appendix E. Table 2c Health outcomes for thiazide trials

Study | Emergency Room Treatment Related to Stone Recurrence (e.g., renal colic) % (n/N) | | Hospitalizations Related to Stone Recurrence (e.g., renal colic) % (n/N) | | Quality of Life
Study | Thiazide | Control(s) | Thiazide | Control(s) | Thiazide | Control(s)
Fernández-Rodriguez, 2006^9^ | NR | NR | NR | NR | NR | NR
Borghi, 1993^11^ | NR | NR | NR | NR | NR | NR
Ettinger, 1988^12^ | NR | NR | NR | NR | NR | NR
Ala-Opas, 1987^13^ | NR | NR | NR | NR | NR | NR
Laerum, 1984^14^ | NR | NR | NR | NR | NR | NR
Scholz, 1982^15^ | NR | NR | NR | NR | NR | NR

Abbreviation: NR = not reported

Appendix E. Table 3a Secondary stone recurrence outcomes for citrate trials

Study | Definition of Stone Recurrence | Stone Recurrence Rate | | Change in Stone Size | | Stone Fragment Clearance
Study | Definition of Stone Recurrence | Citrate | Control(s) | Citrate | Control(s) | Citrate | Control(s)
Lojanapiwat, 2011^16^ | [underlined: Composite]: Spontaneous stone passage and/or radiologically detected new stone (KUB x-ray at 12 months). | NR | NR | NR | NR | NR | NR
Fernández-Rodriguez, 2006^9^ | [underlined: Composite]: Passage or removal of any stone; radiologically detected new stone (x-ray every 6 months for 3 years). | NR | NR | NR | NR | NR | NR
Soygur, 2002^17^ | [underlined: Composite]: Passage of previously unrecognized stone; or any radiologically detected new stone or >2mm increase in residual fragment (ultrasound + plain abdominal x-ray at 1 year post-baseline). | NR | NR | NR | NR | NR | NR
Premgamone, 2001^18^ | [underlined: Radiologic]: Percentage reduction in stone diameter per year (ultrasound every 5–7 weeks). | NR | NR | 38.5% diameter reduction per year at 18 months P^*^=NS | 40.9% diameter reduction per year at 18 months | NR | NR
Ettinger, 1997^19^ | [underlined: Composite]: Passage of previously unrecognized stone >1m after baseline; or radio-logically detected new stone or enlargement in residual fragment (annual x-ray). | NR | NR | NR | NR | NR | NR
Hofbauer, 1994^20^ | [underlined: Radiologic]: Detection by ultrasound + x-ray every 6 months for 3 years. | 0.7 stones per patient year P=0.65^*^ | 0.9 stones per patient year | NR | NR | NR | NR
Barcelo, 1993^21^ | [underlined: Composite]: Passage of previously unrecognized stone; new stone requiring SWL or surgery; or radiologically detected new stone (every 6 months, x-ray for 3 years). | 0.1 stones per patient year (p<0.001) | 1.1 stones per patient year | NR | NR | NR | NR

* P versus control

Abbreviations: HCTZ = hydrochlorothiazide; NR = not reported; NS = not significant

Appendix E. Table 3b Health outcomes for the citrate trials

Study | Pain% (n/N) | | Urinary Tract Infection with Acute Renal Failure % (n/N) | | Infection % (n/N) | | Procedure-related Morbidity % (n/N)
Study | Citrate | Control(s) | Citrate | Control(s) | Citrate | Control(s) | Citrate | Control(s)
Lojanapiwat, 2011 16 | NR | NR | NR | NR | NR | NR | NR | NR
Fernández-Rodriguez, 2006^9^ | NR | NR | NR | NR | NR | NR | NR | NR
Soygur, 2002^17^ | NR | NR | NR | NR | NR | NR | NR | NR
Premgamone, 2001^18^ | NR | NR | NR | NR | NR | NR | NR | NR
Ettinger, 1997^19^ | NR | NR | NR | NR | NR | NR | NR | NR
Hofbauer, 1994^20^ | 9 of 16 (56%) subjects reported spontaneous stone elimination to be painless P=0.001^*^ | 1 of 22 (4%) subjects reported spontaneous stone elimination to be painless | NR | NR | NR | NR | NR | NR
Barcelo, 1993^21^ | NR | NR | NR | NR | NR | NR | NR | NR

* versus control

Abbreviation: NR = not reported

Appendix E. Table 3c Health outcomes for citrate trials

Study | Emergency Treatment Related to Stone Recurrence (e.g., renal colic) % (n/N) | | Hospitalizations Related to Stone Recurrence (e.g., renal colic) % (n/N) | | Quality of Life
Study | Citrate | Control(s) | Citrate | Control(s) | Citrate | Control(s)
Lojanapiwat, 2011^16^ | NR | NR | NR | NR | NR | NR
Fernández- Rodriguez, 2006^9^ | NR | NR | NR | NR | NR | NR
Soygur, 2002^17^ | NR | NR | NR | NR | NR | NR
Premgamone, 2001^18^ | NR | NR | NR | NR | NR | NR
Ettinger, 1997^19^ | NR | NR | NR | NR | NR | NR
Hofbauer, 1994^20^ | NR | NR | NR | NR | NR | NR
Barcelo, 1993^21^ | NR | NR | NR | NR | NR | NR

Abbreviation: NR = not reported

Appendix E. Table 4a Secondary Stone recurrence outcomes for allopurinol trials

Study | Definition of Stone Recurrence | Stone Recurrence Rate | | Change in Stone Size | | Stone Fragment Clearance
Study | Definition of Stone Recurrence | Allopurinol | Control(s) | Allopurinol | Control(s) | Allopurinol | Control(s)
Borghi, 1993^11^ | [underlined: Composite]: Passage or removal of any stone; radiologically detected new stone (x-ray at 6 & 12 months, then annually through 3 years). | NR | NR | NR | NR | NR | NR
Ettinger, 1986^22^ | [underlined: Composite] (Beginning 6 months post-baseline): Passage of new stone; or radiologically detected new stone or enlargement of pre-existing stone (annual x-ray). | *0.12 stones per patient year; *Mean time to first recurrence 33.3 months p not reported for stones per patient year; p for time to recurrence <0.05 vs. control | *0.26 stones per patient year; *Mean time to first recurrence 27.4 months | 13.8% (4/29) | 22.6% (7/31) | NR | NR
Miano, 1985^23^ | [underlined: Symptomatic]: Passage of new stone. | 0.96 stones per patient year; Mean percent reduction in passed stones 72.2% compared to before treatment p not reported for stones per patient year; p =NS for percent reduction in passed stones vs. placebo | 0.66 stones per patient year; Mean percent reduction in passed stones 63.2% | NR | NR | NR | NR
Robertson, 1985^24^ | [underlined: Symptomatic]: Passage or removal of any stone. | 0.54 stones per patient year no p values provided | 0.58 stones per patient year | NR | NR | NR | NR
Smith, 1977^25^ | [underlined: Composite]: Passage of new stone; or radiologically detected new stone (study did not report type or frequency of imaging modality utilized | NR | NR | NR | NR | NR | NR

* Rate reported only for composite stone recurrence outcome that includes symptomatic and radiographic recurrences as well as incidences of stone growth.

Abbreviations: HCTZ = hydrochlorothiazide; NR = not reported; NS = not significant

Appendix E. Table 4b Health outcomes for the allopurinol trials

Study | Pain % (n/N) | | Urinary Tract Obstruction with Acute Renal Failure % (n/N) | | Infection % (n/N) | | Procedure-related Morbidity % (n/N)
Study | Allopurinol | Control(s) | Allopurinol | Control(s) | Allopurinol | Control(s) | Allopurinol | Control(s)
Borghi, 1993^11^ | NR | NR | NR | NR | NR | NR | NR | NR
Ettinger, 1986^22^ | NR | NR | NR | NR | NR | NR | NR | NR
Miano, 1985^23^ | NR | NR | NR | NR | NR | NR | NR | NR
Robertson, 1985^24^ | NR | NR | NR | NR | NR | NR | NR | NR
Smith, 1977^25^ | NR | NR | NR | NR | NR | NR | NR | NR

Abbreviation: NR = not reported

Appendix E. Table 4c Health outcomes for allopurinol trials

Study | Emergency Room Treatment Related to Stone Recurrence (e.g., renal colic) % (n/N) | | Hospitalizations Related to Stone Recurrence (e.g., renal colic) % (n/N) | | Quality of Life | | Other? % (n/N)
Study | Allopurinol | Control(s) | Allopurinol | Control(s) | Allopurinol | Control(s) | Allopurinol | Control(s)
Borghi, 1993^11^ | NR | NR | NR | NR | NR | NR | NR | NR
Ettinger, 1986^22^ | NR | NR | NR | NR | NR | NR | NR | NR
Miano, 1985^23^ | NR | NR | NR | NR | NR | NR | NR | NR
Robertson, 1985^24^ | NR | NR | NR | NR | NR | NR | NR | NR
Smith, 1977^25^ | NR | NR | NR | 2.9 (2/67) | NR | NR | NR | NR

Abbreviation: NR = not reported

Appendix E. Table 5a Secondary stone recurrence outcomes for the acetohydroxamic acid trials

Study | Definition of Stone Recurrence | Stone Recurrence Rate | | Change in Stone Size | | Stone Fragment Clearance
Study | Definition of Stone Recurrence | AHA | Control(s) | AHA | Control(s) | AHA | Control(s)
Griffith, 1991^26^ | [underlined: Radiologic]: X-ray. Stone growth (>25% increase in area) or new stone formation detected by abdominal radiographs at 3 and 12m, then annually) | NR | NR | 19.0% (8/42) stone growth^*^ P < 0.05 | 50.0% (21/42) stone growth^*^ | NR | NR
Griffith, 1988^27^ | [underlined: Radiologic]: X-ray. Definite (>50% increase in area) or possible (10–50% increase in area) stone growth or new stone formation detected by abdominal radiographs every 3 months | NR | NR | 33.3% (14/42) definite or possible stone growth at 1 yr^*^ p=0.017 41.7% (10/24) definite or possible stone growth at 2 yrs^*^ p=0.26 | 60.5% (26/43) definite or possible stone growth at 1 yr^*^ 60.0% (21/35) definite or possible stone growth at 2 yrs^*^ | 2.7 (3/109) at 1yr 3.7 (4/106) at 2yrs P=NS at both time intervals | 3.9 (3/76) at 1yr 1.7 (1/75) at 2yrs
Williams, 1984^28^ | [underlined: Composite]: Radiologically detected new stone or stone growth (>100% increase in area by planimetry) on x-ray every 3 months or surgical intervention for stone obstruction or infection | NR | NR | 0% (0/18) stone area doubling^†^ P=0.008 | 39% (7/19) stone area doubling^†^ | NR | NR

* Study reported these results for subset of participants with residual stones at baseline

† Study reported results for all participants, without providing separate results for participants with residual stones at baseline.

Abbreviations: NR = not reported; NS = not significant

Appendix E. Table 5b Health outcomes for acetohydroxamic acid trials

Study | Pain% (n/N) | | Urinary Tract Obstruction with Acute Renal Failure % (n/N) | | Infection % (n/N) | | Procedure-related Morbidity% (n/N)
Study | AHA | Control | AHA | Control | AHA | Control | AHA | Control
Griffith, 1991^26^ | NR | NR | NR | NR | NR | NR | NR | NR
Griffith, 1988^27^ | NR | NR | NR | NR | NR | NR | NR | NR
Williams, 1984^28^ | NR | NR | NR^*^ | NR^*^ | All patients had UTI at start of the study | All patients had UTI at start of the study | NR | NR

* Two patients in placebo group and none in the AHA group were stated to have undergone surgery for obstruction or infection.

Abbreviations: NR = not reported; UTI = urinary tract infection

Appendix E. Table 5c Health outcomes for the acetohydroxamic acid trials

Study | Emergency Room Treatment Related to Stone Recurrence (e.g., renal colic) % (n/N) | | Hospitalizations Related to Stone Recurrence (e.g., renal colic) % (n/N) | | Quality of Life | | Other? % (n/N)
Study | AHA | Control | AHA | Control | AHA | Control | AHA | Control
Griffith, 1991^26^ | NR | NR | NR | NR | NR | NR | NR | NR
Griffith, 1988^27^ | NR | NR | NR | NR | NR | NR | NR | NR
Williams, 1984^28^ | NR | NR | NR | NR | NR | NR | NR | NR

Abbreviation: NR = not reported

Appendix E. Table 6a Secondary stone recurrence outcomes for the magnesium trials

Study | Definition of Stone Recurrence | Stone Recurrence Rate | | Change in Stone Size | | Stone Fragment Clearance
Study | Definition of Stone Recurrence | Magnesium | Control(s) | Magnesium | Control(s) | Magnesium | Control(s)
Ettinger, 1988^12^ | [underlined: Composite]: Passage of previously unrecognized stone >3 months after baseline; or radiologically detected new stone or enlargement in residual fragment (annual x-ray) | NR | NR | NR | NR | NR | NR

Abbreviation: NR = not reported

Appendix E. Table 6b Health outcomes for the magnesium trials

Study | Pain % (n/N) | | Urinary Tract Obstruction with Acute Renal Failure % (n/N) | | Infection % (n/N) | | Procedure-related Morbidity% (n/N)
Study | Magnesium | Control(s) | Magnesium | Control(s) | Magnesium | Control(s) | Magnesium | Control(s)
Ettinger, 1988^12^ | NR | NR | NR | NR | NR | NR | NR | NR

Abbreviation: NR = not reported

Appendix E. Table 6c Health outcomes for the magnesium trials

Study | Emergency Room Treatment Related to Stone Recurrence (e.g., renal colic) % (n/N) | | Hospitalizations Related to Stone Recurrence (e.g., renal colic) % (n/N) | | Quality of Life | | Other? % (n/N)
Study | Magnesium | Control(s) | Magnesium | Control(s) | Magnesium | Control(s) | Magnesium | Control(s)
Ettinger, 1988^12^ | NR | NR | NR | NR | NR | NR | NR | NR

Abbreviation: NR = not reported