# Baseline Characteristics Summary Tables

Appendix F. Table 1 Summary of study baseline characteristics for diet studies

Characteristic | Mean (range) Unless Otherwise Noted | Number of Trials Reporting
Total number of patients evaluated | 2270 (45 to 1009) | 8
Study withdrawals, % of patients | 12 (0 to 58) | 8
Age of subjects, years | 42 (32 to 45) | 7 a,b,c,d,f,g,h
Gender, male, % of patients | 80 (46 to 100) | 8
Race/ethnicity, white, % of patients | 77 | 1 g
Weight, pounds | 157.3 (152 to 171) | 3 a,c,f
Body mass index, kg/m2 | 24.5 (24 to 25.5) | 2 a,g
Creatinine, mg/dL | 1.0 (1.0 to 1.1) | 2 a,c
Creatinine clearance | 88 ml/min/1.73m^2^ to 126 ml/min | 2 a,c
Stone type, calcium oxalate stones, % of patients (n/N) | 20 (460/2270) | 4 b,c,f,g,*
Stone type, “mixed calcium or other stones,” % of patients (n/N) | 80 (1810/2270) | 4 a,d,e,h
Multiple past stones, % of patients (n/N) | 54 (1140/2095) | 3 c,d,h,**
Single past stone, % of patients (n/N) | 46 (955/2095) | 5 b,e,f,g,h,†
Residual stones at baseline, % of patients | 21 e, 4 trials with 0 c,d,f,g
Hypercalciuria at baseline, % of patients | 18 g, 38 a, 100 c, 1 trial with 0 b, 1 trial with 67 reported only for intervention group e
Hypocitraturia at baseline, % of patients | 1 trial with 19 reported only for intervention group e
Hyperuricosuria at baseline, % of patients | 1 trial with 27 reported only for intervention group e, 1 trial with 0 b
Hyperoxaluria at baseline, % of patients | 18 c, 1 trial with 18 reported only for intervention group e, 2 trials with 0 a,b
Hypomagnesuria at baseline, % of patients | 9 | 1 trial reported only intervention group e
Mixed at baseline, % of patients | 2 trials with 0 c,d
No metabolic disorder at baseline (% of patients) | 100 b, 4 trials with 0 a,c,e,g
Randomized to low animal protein diet, % of patients (n/N) | 2 (55/2235^††^) | 1 a
Randomized to high fiber diet, % of patients (n/N) | 3 (60/2235) | 1 a
Randomized to low animal protein/high fiber diet, % of patients (n/N) | 2 (50/2235) | 1^g^
Randomized to low protein/low sodium diet, % of patients (n/N) | 3 (60/2235) | 1 c
Randomized to low calcium diet, % of patients (n/N) | 3 (60/2235) | 1 c
Randomized to “tailored” diet, % of patients (n/N) | 5 (113/2235) | 1 e
Randomized to increased fluid or urine output, % of patients (n/N) | 23 (506/2235) | 3 b,d,f
Randomized to decreased soft drink consumption, % of patients (n/N) | 22 (504/2235) | 1 h
Randomized to no treatment/usual care, % of patients (n/N) | 37 (827/2235) | 6 a,b,e,f,g,h
Studies conducted in the US, % of patients (n/N) | 49 (1108/2270) | 2 g,h
Studies conducted in Europe, % of patients (n/N) | 51 (1162/2270) | 6 a,b,c,d,e,f
Mean study duration (months) | 39 (19 to 60) | 7 a,c,d,e,f,g,h

* All trials 100%;

** 2 trials 100% (Borghi 2002,3 Di Silverio 2000^4^);

† 4 trials 100% (Sarica 2006,2 Kocvara 1999,5 Borghi 1996,6 Hiatt 1996^7^).

†† The denominator for diet allocation includes completers only from Kocvara 1999,^5^ number randomized to each arm at baseline not reported. Therefore, there are 207 subjects versus 242 randomized.

a Dussol 2008;^1^

b Sarica 2006;^2^

c Borghi 2002;^3^

d Di Silverio 2000;^4^

e Kocvara 1999;^5^

f Borghi 1996;^6^

g Hiatt 1996;^7^

h Shuster 1992^8^

Appendix F. Table 2 Summary of baseline characteristics for thiazide studies

Characteristic | Mean (range)^‡^ Unless Otherwise Noted | Trials Reporting
Total number of patients evaluated | 564 (41 to 150) | 7
Study withdrawals, % of patients | 12^*^ (0 to 46) | 7
Study withdrawals due to adverse events, % of patients | 2^**^ (0 to 12) | 7
Age of subjects, years | 45 (35 to 48) | 6 b,c,d,e,f,g
Gender, male, % of patients | 80 (61 to 88) | 6 b,c,d,e,f,g
Race/ethnicity, white, % of patients | 94 | 1 d
Stone type, calcium oxalate stones, % of patients (n/N) | 69^†^ (390/564) | 4 a,b,c,d,
Stone type, “calcium stones,” % of patients (n/N) | 31 (174/564) | 3 e,f,g
Multiple past stones, % of patients (n/N) | 100 (564/564) | 6
Single past stone, % of patients (n/N) | 0 (0/564) | -
Residual stones at baseline, % of patients | 0% c, 47% d | 2
Hypercalciuria at baseline, % of patients | 47 (12 to 100) | 7
Hypocitraturia at baseline, % of patients | 7 (0 to 15) | 4^a,b,c,e^
Hyperuricosuria at baseline, % of patients | 12 (0 to 37) | 6 a,b,c,d,e,f
Hyperoxaluria at baseline, % of patients | 11 (0 to 100) | 6 a,b,c,d,e,g
Hypomagnesuria at baseline, % of patients | 10 | 1 b
Mixed at baseline, % of patients | 11 (0 to 23) | 5^a,b,c,d,e^
No metabolic disorder at baseline (% of patients) | 29 (0 to 56) | 6 a,b,c,d,e,g
Studies evaluating HCTZ, % of patients (n/N) | 65 (365/564) | 5 a,b,e,f,g
Studies evaluating chlorthalidone, % of patients (n/N) | 22 (124/564) | 1 d
Studies evaluating indapamide, % of patients (n/N) | 13 (75/564) | 1 c
Studies conducted in the US, % of patients (n/N) | 22 (124/564) | 1 d
Studies conducted in Europe, % of patients (n/N) | 78 (440/564) | 6 a,b,c,e,f,g
Mean study duration (months) | 34 (12 to 48) | 7

* Unclear in the Ettinger 1988^12^ trial, possibly 26% overall.

** overall due to adverse events for all study groups unclear in the Ettinger 1988^12^ trial, the range was 3.2% for placebo up to 22.6% for chlorthalidone 25 mg. None reported for magnesium hydroxide 650 mg.

† Two trials (Barcelo21) reported either calcium oxalate or a mixture of calcium oxalate and calcium phosphate stones.

‡ Data reported in this table is from trials comparing thiazide vs. placebo/control as well as trials comparing thiazide + second active therapy vs. control.

HCTZ = hydrochlorthiazide

a Fernandez-Rodriguez 2006;^9^

b Ahlstrand 1995;^10^

c Borghi 1993;^11^

d Ettinger 1988;^12^

e Ala-Opas 1987;^13^

f Laerum 1984;^14^

g Scholz 1982^15^

Appendix F. Table 3 Summary of baseline characteristics for citrate studies

Characteristic | Mean (range) Unless Otherwise Noted^**^ | Trials Reporting
Total number of patients evaluated | 559 (48 to 150) | 7
Study withdrawals, % of patients | 15 (0 to 36) | 7
Study withdrawals due to adverse events, % of patients | 4 (0 to 10) | 7
Age of subjects, years | 47 (42 to 55) | 5^b,d,e,f,g^
Gender, male, % of patients | 63 (44 to 78) | 6^b,c,d,e,f,g^
Race/ethnicity, white, % of patients | NR | -
Stone type, calcium oxalate stones, % of patients (n/N) | 100^*^ (431/431) | 5 a,b,d,e,f of 5 report stone type
Multiple past stones, % of patients (n/N) | 74 (321/431) | 4^a,d,e,f^ of 5 report stone history
Single past stone, % of patients (n/N) | 26 (110/431) | 1^b^ of 5 report stone history
Residual stones at baseline, % of patients | 61 (38 to 100) | 3^b,c,d^
Hypercalciuria at baseline, % of patients | 24 (0 to 44) | 5^a,b,e,f,g^
Hypocitraturia at baseline, % of patients | 22 (0 to 69) | 5^a,b,e,f,g^
Hyperuricosuria at baseline, % of patients | 7 (0 to 18) | 4^a,b,f,g^
Hyperoxaluria at baseline, % of patients | 6 (0 to 18) | 3^a,f,g^
Mixed at baseline, % of patients | 12 (0 to 16) | 2^a,f^
No metabolic disorder at baseline, % of patients | 49 (29 to 100) | 2^a,f^
Studies evaluating potassium (K) citrate, % of patients (n/N) | 57 (317/559) | 3^a,b,f^
Studies evaluating sodium/K citrate, % of patients (n/N) | 32 (178/559) | 2^c,e^
Studies evaluating magnesium/K citrate, % of patients (n/N) | 11 (64/559) | 1^d^
Studies conducted in the US, % of patients (n/N) | 11 (64/559) | 1^d^
Studies conducted in Europe, % of patients (n/N) | 66 (367/559) | 4 a,b,e,f
Studies conducted in Other, % of patients (n/N) | 23 (128/559) | 2^c,g^
Mean study duration (months) | 26 (12 to 37) | 7

* One trial (Barcelo21) reported either calcium oxalate or a mixture of calcium oxalate and calcium phosphate stones

** Data reported in this table is from trials comparing citrate vs. placebo/control as well as trials comparing citrate + second active therapy vs. control.

Abbreviation: NR = not reported

a Fernandez-Rodriguez 2006;^9^

b Soygur 2002;^17^

c Premgamone 2001;^18^

d Ettinger 1997;^19^

e Hofbauer 1994;^20^

f Barcelo 1993^21^;

g Lojanapiwat, 2011^16^

Appendix F. Table 4 Summary of baseline characteristics for allopurinol studies

Characteristic | Mean (range) Unless Otherwise Noted^**^ | Trials Reporting
Total number of patients evaluated | 339^*^ (15 to 132) | 5
Study withdrawals, % of patients | *23 (15 to 30) | 3 a,b,e
Study withdrawals due to adverse events, % of patients | 0^*^ | 3 a,b,e
Age of subjects, years | 46 (45 to 48) | 2^a,b^
Gender, male, % of patients | 87 (79 to 100) | 2^a,d^
Race/ethnicity, white, % of patients | NR | -
Stone type, calcium oxalate stones, % of patients | 100% in 3 studies | 3^c,d,e^
Stone type, mixed calcium oxalate stones and calcium phosphate or other, % of patients | 2 studies with ≥80% calcium oxalate only | 2^a,b^
Multiple past stones, % of patients (n/N) | 100% in all studies | 5
Single past stone, % of patients (n/N) | 0% in all studies | 5
Residual stones at baseline, % of patients (n/N) | (0 to 47) | 2^a,b^
Hypercalciuria at baseline, % of patients | 100 | 1^a^
Hypocitraturia at baseline, % of patients | NR
Hyperuricosuria at baseline, % of patients | 100 | 1^b^
Hypeoxaluria at baseline, % of patients | NR
Hyperuricemia at baseline, % of patients | 100 | 1^e^
Mixed at baseline, % of patients | NR
No metabolic disorder at baseline, % of patients | 0 | 3 a,b,e
Studies conducted in the US, % of patients (n/N) | 60 (204/339) | 2 b,e
Studies conducted in Europe, % of patients (n/N) | 40 (135/339) | 4 a,c,d
Mean study duration (months) | 46 (24 to 60) | 5

* Two trials, Miano 1985^23^ and Robertson 1985^24^, reported only preliminary data on 15 patients (of 30 randomized) and 45 (of 120 randomized), respectively. No further data on either of these two studies were identified.

** Data reported in this table is from trials comparing allopurinol vs. placebo/control as well as trials comparing allopurinol + second active therapy vs. control.

Abbreviation: NR = not reported

a Borghi 1996;^6^

b Ettinger 1986;^22^

c Miano 1985;^23^

d Robertson1985;^24^

e Smith 1977^25^

Appendix F. Table 5 Summary of study baseline characteristics for acetohydroxamic acid trials

Characteristic | Mean (range) Unless Otherwise Noted | Trials Reporting
Total number of patients evaluated | 343 (39 to 210) | 3
Study withdrawals, % of patients | 49 (15 to 69) | 3
Study withdrawals due to adverse events, % of patients | 13 (5 to 16) | 3
Age of subjects, years | 49 (48 to 49) | 2 b,c
Gender, male, % of patients | 77 (18 to 100) | 3
Race/ethnicity, white, % of patients | NR
Stone type, struvite stones, % of patients | 100% for all trials
Multiple past stones, % of patients (n/N) | 100% for 2 trials | 2 a,c
Single past stone, % of patients (n/N) | 0% for 2 studies | 2 a,c
Residual stones at baseline, % of patients (n/N) | 88^*^ (269/304) | 2 a,b
Hypercalciuria at baseline, % of patients | NR
Hypocitraturia at baseline, % of patients | NR
Hyperuricosuria at baseline, % of patients | NR
Hyperoxaluria at baseline, % of patients | NR
Mixed at baseline, % of patients | NR
No metabolic disorder at baseline, % of patients | NR
Spinal cord injury, % of patients (n/N) | 85^**^ (257/304) | 2 a,b
Studies conducted in the US | All trials
Mean study duration (months) | 18 months for Williams1984. Only range for follow-up period reported for Griffith 1991 (6–32 mos) and Griffith 1988 reported up to 24 months.

* For Williams1984,^28^ residual stones at baseline were not reported for all subjects except for 7 placebo patients who had stones that doubled in area versus 0 for AHA patients (determined by X-ray).

** 10% of subjects in Williams1984^28^ study had neurogenic bladders.

Abbreviation: NR = not reported

a Griffith 1991;^26^

b Griffith 1988;^27^

c Williams1984^28^