# Primary Stone Recurrence Outcomes Tables

Appendix D. Table 1 Primary stone recurrence outcomes for the diet trials

Study | Definition of Stone Recurrence | Symptomatic Stone Recurrence % (n/N) | | Radiographically Detected Stone Recurrence % (n/N) | | Composite Stone Recurrence % (n/N)
Study | Definition of Stone Recurrence
Study | Definition of Stone Recurrence | Diet | Control or Diet B | Diet | Control or Diet B | Diet | Control or Diet B
Dussol 2008^1^ | [underlined: Composite]: a) symptomatic-passage of stone or stone confirmed radio-logically based on colic or hematuria or b) silent-appearance of a new stone or a >50% increase in size of a previously present stone on radiological or ultrasound exams. | NR | NR | NR | NR | Month 24 Low animal protein diet 34.2% (12/35) High fiber diet 40.5% (17/42) P=NS^*^ (all groups) | Month 24 Usual diet 34.2% (12/35)
Dussol 2008^1^ | | NR | NR | NR | NR | Month 48^**^ Low animal protein diet 47.8% (11/23) High fiber diet 63.0% (17/27) P=NS (all groups) | Month 48 47.8% (11/23)
Sarica 2006^2^ | [underlined: Radiographic]: Plain abdominal X-ray (including renal tomography), kidney sonography or excretory urogram at regular intervals (3, 6, and 12 months after stone disintegration) | NR | NR | Forced fluid 8.3% (1/12)^†^ P<0.05 | No intervention 55.6% (5/9)^†^ | NR | NR
Borghi 2002^3^ | [underlined: Composite]: Passage of stone or stone identified by annual ultrasound and abdominal flat-plate examinations | NR | NR | NR | NR | Low calcium diet 38.3% (23/60) P=0.03 | Low protein/low sodium diet 20.0% (12/60)
Di Silverio 2000^4^ | [underlined: Radiographic]: X-ray and abdominal echographic studies upon recruitment and thereafter every 6 months until the onset of recurrence. | NR | NR | Oligomineral water, calcium 15 mg/I 16.7% (32/192) P=0.13 | Tap water, calcium 55–130 mg/l 22.9% (44/192) | NR | NR
Kocvara 1999^5^ | [underlined: Composite]: radiography and ultrasonography (but over half of the stones were “asymptomatic”) so symptomatic passage also | NR | NR | NR | NR | Tailored diet with evaluation 6.2% (7/113) P<0.01 | General diet recommendations 19.1% (18/94)
Borghi 1996^6^ | [underlined: Composite]: Passage of stone, renal colic, annual x-ray and ultrasound screening | NR | NR | NR | NR | Achieve daily urine volume >2 liters 12.1% (12/99) P=0.008 | No intervention 27.0% (27/100)
Hiatt 1996^7^ | [underlined: Composite]: Passage of stone, surgical removal or annual radiological detection of previously unrecognized stone | NR | NR | NR | NR | Low animal protein and high fiber diet 24.0% (12/50) P=0.004 | Standard advice 4.1% (2/49)
Shuster 1992^8^ | [underlined: Symptomatic]: Self reported stone episode, possibly confirmed by physician | Decrease soft drink consumption 33.7% (170/504) “failed” P=0.023 | No intervention 40.6% (205/505) “failed” | NR | NR | NR | NR

* P values versus control unless noted;

** of the 39 patients with stone recurrence, 5 patients had silent recurrence;

† These results are limited to the subset of subjects who were stone free after SWL.

NS = not statistically significant

Abbreviation: NR = not reported

Appendix D. Table 2 Primary stone recurrence outcomes for thiazide trials

Study | Definition of Stone Recurrence | Symptomatic Stone Recurrence % (n/N) | | Radiographically Detected Stone Recurrence % (n/N) | | Composite Stone Recurrence % (n/N)
Study | Definition of Stone Recurrence | Thiazide | Control(s) | Thiazide | Control(s) | Thiazide | Control(s)
Fernández-Rodriguez, 2006^9^ | [underlined: Composite]: Passage or removal of any stone; radiologically detected new stone (plain x-ray every 6 months for 3 years). | NR | NR | NR | NR | HCTZ monotherapy 32% (16/50) P=0.02 vs. no treatment^*,**^; HCTZ + citrate 30% (15/50) P=0.83 vs. HCTZ monotherapy^**^ | no treatment 56% (28/50)
Ahlstrand, 1995^10^ | [underlined: Composite]: x-ray examinations annually and “at clinical events” | NR | NR | NR | NR | 53% (9/17) P=0.04; | 86% (19/22)
Borghi, 1993^11^ | [underlined: Composite]: Passage or removal of any stone; radiologically detected new stone (x-ray abdominal flat plate with renal tomograms at 6 & 12 months, then annually through 3 years). | NR | NR | NR | NR | Indapamide monotherapy 15.8% (3/19)^*^ P=0.09 vs. control Indapamide+ allopurinol 12.5% (3/24)^*^ P=0.04 vs. control P=0.01 for combined Indapamide groups | 42.8% (9/21)^*^
Ettinger, 1988^12^ | [underlined: Composite]: Passage of previously unrecognized stone >3 months after baseline; or radiologically detected new stone or enlargement in residual fragment (annual x-ray | NR | NR | NR | NR | chlorthalidone 25 mg/d 15.8% (3/19) P=0.06 vs. placebo P=0.39 vs. MgOH_2_ 650 mg P=0.22 vs. MgOH_2_ 1300 mg chlorthalidone 50 mg/d 13.0% (3/23); P=0.03 mg vs. placebo P=0.25 vs. MgOH_2_ 650 mg P=0.13 vs. MgOH_2_ 1300 mg P=0.007 for combined chlorthalidone groups vs. placebo | 1. placebo 45.2% (14/31); 2. MgOH_2_; 650 mg/d; 26.7% (8/30); 3. MgOH_2_; 1300 mg/d; 33.3% (7/21)
Ala-Opas, 1987^13^ | [underlined: Composite]: Passage or removal of stone; or radiologically detected new stone (x-ray every 6 months). | NR | NR | NR | NR | HCTZ normocalciuric patients 28.6% (4/14) P=0.71^†^; hypercalciuric patients 14.3% (2/14) P=0.41^†^ all patients 21.4% (6/28) P=0.62^†^ | Control normocalciuric patients 22.2% (6/27) hypercalciuric patients 33.3% (6/18) all patients 26.7% (12/45)
Laerum, 1984^14^ | [underlined: Composite]: Passage of new stone; or radiologically detected new stone (annual plain abdominal x-ray plus pyelography and tomography in ambiguous cases). | NR | NR | NR | NR | HCTZ + KCl 21.7% (5/23)^**^ P=0.05 | Placebo 48.0% (12/25)
Scholz, 1982^15^ | [underlined: Symptomatic]: Passage of new stone. | HCTZ 24.0% (6/25) P=1.0^†^ | Placebo 23.1% (6/26) | NR | NR | NR | NR

* n and/or N were calculated from data presented in the manuscript;

** P values versus control unless noted;

† P-value calculated from data presented in the manuscript

Abbreviations: HCTZ = hydrochlorothiazide; HCL = hydrochloride; K = potassium; MgOH_2_ = magnesium hydroxide; Na phos = sodium phosphate; NR = not reported; NS = not significant

Appendix D. Table 3 Primary stone recurrence outcomes for citrate trials

Study | Definition of Stone Recurrence | Symptomatic Stone Recurrence % (n/N) | | Radiographically Detected Stone Recurrence % (n/N) | | Composite Stone Recurrence % (n/N)
Study | Definition of Stone Recurrence | Citrate | Control(s) | Citrate | Control(s) | Citrate | Control(s)
Lojanapiwat, 2011^16^ | [underlined: Composite]: Spontaneous stone passage and/or radiologically detected new stone (KUB x-ray at 12 months). | NR | NR | NR | NR | stone free group 8% (1/13); P=0.08 | stone free group 42% (11/26)
Fernández-Rodriguez, 2006^9^ | [underlined: Composite]: Passage or removal of any stone; radiologically detected new stone (x-ray every 6 months for 3 years). | NR | NR | NR | NR | Citrate + HCTZ 30% (15/50) P= 0.01 vs. no treatment^*^; P= 0.83 vs. HCTZ^**^ | 1. no treatment; 56% (28/50); 2. HCTZ; 32% (16/50)
Soygur, 2002^17^ | [underlined: Composite]: Passage of previously unrecognized stone; or any radiologically detected new stone or >2mm increase in residual fragment (ultrasound + plain abdominal x-ray at 1 year post-baseline). | NR | NR | NR | NR | stone free group 0% (0/28); P=0.004 | stone free group 28.6% (8/28)
Premgamone, 2001^18^ | [underlined: Radiologic]: Percentage reduction in stone diameter per year (ultrasound every 5–7 weeks). | NR | NR | NR | NR | NR | NR
Ettinger, 1997^19^ | [underlined: Composite]: Passage of previously unrecognized stone >1m after baseline; or radio-logically detected new stone or enlargement in residual fragment (annual x-ray). | NR | NR | NR | NR | 12.9% (4/31)^††^ P=0.001 | 63.6% (21/33)^††^
Hofbauer, 1994^20^ | [underlined: Radiologic]: Detection by ultrasound + x-ray every 6 months for 3 years. | NR | NR | 68.8% (11/16) | 72.7% (16/22) | NR | NR
Barcelo, 1993^21^ | [underlined: Composite]: Passage of previously unrecognized stone; new stone requiring SWL or surgery; or radiologically detected new stone (every 6 months, x-ray for 3 years). | NR | NR | NR | NR | 27.8% (5/18) P=0.003 | 80% (16/20)

* P values versus control unless noted;

** P-value calculated from data presented in the manuscript;

† Recurrence for subjects with residual stones was 55.6% (10/18) and 87.5% (14/16) for the citrate and control groups, respectively (P=0.06);

†† n and/or N were calculated from data presented in the manuscript

Abbreviations: HCTZ = hydrochlorothiazide; K = potassium; Na = sodium; NR = not reported

Appendix D. Table 4 Primary stone recurrence outcomes for allopurinol trials

Study | Definition of Stone Recurrence | Symptomatic Stone Recurrence% (n/N) | | Radiographically Detected Stone Recurrence % (n/N) | | Composite Stone Recurrence % (n/N)
Study | Definition of Stone Recurrence | Allopurinol | Control(s) | Allopurinol | Control(s) | Allopurinol | Control(s)
Borghi, 1993^11^ | [underlined: Composite]: Passage or removal of any stone; radiologically detected new stone (x-ray at 6 & 12 months, then annually through 3 years). | NR | NR | NR | NR | + indapamide 12.5% (3/24)^*^ P<0.02 vs. control^**^; P=0.76 vs. indapamide | 1. control; 42.8% (9/21)^*^; 2. indapamide; 15.8% (3/19)^*^
Ettinger, 1986^22^ | [underlined: Composite] (Beginning 6 months post-baseline): Passage of new stone; or radiologically detected new stone or enlargement of pre-existing stone (annual x-ray). | 10.3% (3/29) | 29.0% (9/31) | 6.9% (2/29) | 6.5% (2/31) | 17.2% (5/29)^†^ | 35.5% (11/31)^†^
Miano, 1985^23^ | [underlined: Symptomatic]: Passage of new stone. | NR | NR | NR | NR | NR | NR
Robertson, 1985^24^ | [underlined: Symptomatic]: Passage or removal of any stone. | NR | NR | NR | NR | NR | NR
Smith, 1977^25^ | [underlined: Composite]: Passage of new stone; or radiologically detected new stone (study did not report type or frequency of imaging modality utilized). | NR | NR | NR | NR | 42.9% (21/49) P=0.01^†^ | 69.8% (30/43)

* n and/or N were calculated from data presented in the manuscript;

** P values versus control unless noted;

† Results indicated here for composite of new symptomatic stones or radiographically detected stones, excluding events reported in the manuscript for stone growth.

Abbreviations: HCTZ = hydrochlorothiazide; K = potassium; Mg = magnesium; Na phos. = sodium phosphate; NR = not reported; NS = not significant

Appendix D. Table 5 Primary stone recurrence outcomes for the acetohydroxamic acid (AHA) trials

Study | Definition of Stone Recurrence | Symptomatic Stone Recurrence % (n/N) | | Radiographically Detected Stone Recurrence % (n/N) | | Composite Stone Recurrence % (n/N)
Study | Definition of Stone Recurrence | AHA | Control(s) | AHA | Control(s) | AHA | Control(s)
Griffith, 1991^26^ | [underlined: Radiologic]: X-ray. Stone growth (>25% increase in area) or new stone formation detected by x-ray at 3 and 12m, then annually) | NR | NR | 0 (0/3) who were stone free at baseline p= NS^*^ | 28 (2/7) who were stone free at baseline | NR | NR
Griffith, 1988^27^ | [underlined: Radiologic]: X-ray. Definite (>50% increase in area) or possible (10–50% increase in area) stone growth or new stone formation detected by x-ray every 3 months | NR | NR | 16.6 (2/12) who were stone free at baseline p= NS^*^ | 15.3 (2/13) who were stone free at baseline | NR | NR
Williams, 1984^28^ | [underlined: Composite]: Radiologically detected new stone or stone growth (>100% increase in area) on x-ray every 3 months or surgical intervention for stone obstruction or infection | NR | NR | 0.0 (0/18) among all patients; no separate results reported by baseline residual stone status | NR | NR | NR

* NS = not significant

Appendix D. Table 6 Primary stone recurrence outcomes for magnesium trials

Study | Definition of Stone Recurrence | Symptomatic Stone Recurrence % (n/N) | | Radiographically Detected Stone Recurrence % (n/N) | | Composite Stone Recurrence % (n/N)
Study | Definition of Stone Recurrence | Magnesium | Control(s) | Magnesium | Control(s) | Magnesium | Control(s)
Ettinger, 1988^12^ | [underlined: Composite]: Passage of previously unrecognized stone >3 months after baseline; or radiologically detected new stone or enlargement in residual fragment (annual x-ray) | NR | NR | NR | NR | 650 mg/d 26.7% (8/30) P=0.15 vs. placebo; P=0.39 vs. chlorthalidone 25 mg; P=0.25 vs. chlorthalidone 50 mg 1300 mg/d 33.3% (7/21) P=0.41 vs. placebo; P=0.22 chlorthalidone 25 mg; P=0.13 vs. chlorthalidone 50 mg P=0.14 for combined groups vs. placebo | 1. placebo 45.2% (14/31); 2. chlorthalidone 25 mg; 15.8% (3/19); 3. chlorthalidone 50 mg; 13.0% (3/23);

Abbreviation: NR = not reported