# Quality Assessment

Table F1 Quality assessment of systematic reviews of acetaminophen

Study, Year | (1) ‘A priori’ design provided? | (2) Duplicate study selection and data extraction?; a. Study selection; b. Data extraction | (3) Comprehensive literature search performed? | (4) Status of publication used as an inclusion criteria? | (5) List of studies (included and excluded) provided? | (6) Characteristics of the included studies provided? | (7) Scientific quality of included studies assessed and documented? | (8) Scientific quality of the included studies used appropriately in formulating conclusions? | (9) Methods used to synthesize the findings of studies appropriate? | (10) Likelihood of publication bias assessed? | (11) Conflict of interest stated?; a. Systematic Review; b. Individual Studies | Quality Rating
Roelofs, 2008 | Yes | a. Yes; b. Yes | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | a. Yes; b. No | Good

Please see Appendix C. Included Studies for full study references.

Table F2 Quality assessment of randomized controlled trials of acetaminophen

Author, Year | Randomization | Concealed Treatment Allocation | Baseline Group Similarity | Patient Blinded | Care Provider Blinded | Outcome Assessor / Data Analyst Blinded | Cointerventions Avoided or Similar | Compliance Acceptable in All Groups | Attrition Reported | Attrition Acceptable | Timing of Outcome Assessment in all Groups Similar | Intention-to-Treat Analysis | Is There a Registered or Published Protocol | Avoidance of Selective Outcomes Reporting | Quality Rating
Williams, 2014 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good

Please see Appendix C. Included Studies for full study references.

Table F3 Quality assessment of systematic reviews of NSAIDs

Study, Year | (1) ‘A priori’ design provided? | (2) Duplicate study selection and data extraction?; a. Study selection; b. Data extraction | (3) Comprehensive literature search performed? | (4) Status of publication used as an inclusion criteria? | (5) List of studies (included and excluded) provided? | (6) Characteristics of the included studies provided? | (7) Scientific quality of included studies assessed and documented? | (8) Scientific quality of the included studies used appropriately in formulating conclusions? | (9) Methods used to synthesize the findings of studies appropriate? | (10) Likelihood of publication bias assessed? | (11) Conflict of interest stated?; a. Systematic Review; b. Individual Studies | Quality Rating
Roelofs, 2008 | Yes | a. Yes; b. Yes | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | a. Yes; b. No | Good

Please see Appendix C. Included Studies for full study references.

Table F4 Quality assessment of randomized controlled trials of NSAIDs

Author, Year | Randomization | Concealed Treatment Allocation | Baseline Group Similarity | Patient Blinded | Care Provider Blinded | Outcome Assessor / Data Analyst Blinded | Cointerventions Avoided or Similar | Compliance Acceptable in All Groups | Attrition Reported | Attrition Acceptable | Timing of Outcome Assessment in all Groups Similar | Intention-to-Treat Analysis | Is There a Registered or Published Protocol | Avoidance of Selective Outcomes Reporting | Quality Rating
Herrmann, 2009 | Yes | Yes | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Fair
Majchrzycki, 2014 | Yes | No | Yes | No | No | Unclear | Unclear | Yes | Yes | Yes | Yes | Yes | No | Yes | Fair
Shirado, 2010 | Yes | No | Yes | No | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Good

Please see Appendix C. Included Studies for full study references.

Table F5 Quality assessment of systematic reviews of opioids

Author, Year | “A priori” design provided? | Duplicate study selection and data abstraction?; a. Study selection; b. Data abstraction | Comprehensive literature search performed? | Non-English language studies considered for inclusion? | Conducted searches for unpublished (gray) literature? | List of included studies provided? | List of excluded studies provided with reasons? | Characteristics of the included studies provided? | Scientific quality of included studies:; a. Assessed?; b. Documented? | Sensitivity analyses or stratified analyses conducted according to study quality? | Study conclusions supported by the evidence? (Was study quality considered in the synthesis?) | Conflict of interest stated?; a. Systematic Review; b. Individual Studies | Multidisciplinary systematic review team? | Quality Rating
Carson, 2011 | Yes | a. Unclear; b. Yes | Yes | No | No | Yes | No- only 4 of 38 excluded full text articles were listed in Appendix D | Yes | a. Yes | Qualitatively, yes | Yes | a. Systematic review: Yes | Unclear | Good
Chaparro, 2013 | Yes | Yes to both | Yes | Yes | No | Yes | Yes- but only for 36 of 76 excluded articles | Yes | Yes to both | No, except for analysis 4.1, examining results of studies with “enhanced enrollment”, meaning patients were enrolled only if they benefitted from opioids and tolerated side effects, then were randomized to opioid withdrawal. | Yes | a. Systematic review: Yes; b. Individual studies: only for strong opioids | Yes | Good

Please see Appendix C. Included Studies for full study references.

Table F6 Quality assessment of randomized controlled trials of opioids

Author, Year | Randomization | Concealed Treatment Allocation | Baseline Group Similarity | Patient Blinded | Care Provider Blinded | Outcome Assessor / Data Analyst Blinded | Cointerventions Avoided or Similar | Compliance Acceptable in all Groups | Attrition Reported | Attrition Acceptable | Timing of Outcome Assessment in All Groups Similar | Intention-to-Treat Analysis | Is There A Registered or Published Protocol | Avoidance of Selective Outcomes Reporting | Quality Rating
Cloutier, 2013 | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear | Yes | No; <20% | Yes | Yes | Unclear | Unclear | Good
Hyup Lee, 2013 | Yes | Yes | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | No; 21% | Yes | Yes | Yes | Yes | Good
Rauck, 2014 | Unclear | Unclear | No; not sex | Yes | Yes | Unclear | Yes | Yes | Yes | No; 39% | Yes | Yes | No | Yes | Poor
Schiphorst Preuper, 2014 | Unclear | Yes | Yes | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Fair

Please see Appendix C. Included Studies for full study references.

Table F7 Quality assessment of randomized controlled trials of SMRs

Author, Year | Randomization | Concealed Treatment Allocation | Baseline Group Similarity | Patient Blinded | Care Provider Blinded | Outcome Assessor / Data Analyst Blinded | Cointerventions Avoided or Similar | Compliance Acceptable in all Groups | Attrition Reported | Attrition Acceptable | Timing of Outcome Assessment In All Groups Similar | Intention-to-Treat Analysis | Is There a Registered or Published Protocol | Avoidance of Selective Outcomes Reporting | Quality Rating
Pareek, 2009 | Unclear | Unclear | Yes | Yes | Unclear | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear | Fair
Ralph, 2008 | Unclear | Unclear | Yes | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear | Fair

Please see Appendix C. Included Studies for full study references.

Table F8 Quality assessment of randomized controlled trials of benzodiazepines

Author, Year | Randomization | Concealed Treatment Allocation | Baseline Group Similarity | Patient Blinded | Care Provider Blinded | Outcome Assessor / Data Analyst Blinded | Cointerventions Avoided or Similar | Compliance Acceptable in All Groups | Attrition Reported | Attrition Acceptable | Timing of Outcome Assessment in all Groups Similar | Intention-to-Treat Analysis | Is There a Registered or Published Protocol | Avoidance of Selective Outcomes Reporting | Quality Rating
Brotz, 2010 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good

Please see Appendix C. Included Studies for full study references.

Table F9 Quality assessment of systematic reviews of antidepressants

Study, Year | (1) ‘A priori’ design provided? | (2) Duplicate study selection and data extraction?; a. Study selection; b. Data extraction | (3) Comprehensive literature search performed? | (4) Status of publication used as an inclusion criteria? | (5) List of studies (included and excluded) provided? | (6) Characteristics of the included studies provided? | (7) Scientific quality of included studies assessed and documented? | (8) Scientific quality of the included studies used appropriately in formulating conclusions? | (9) Methods used to synthesize the findings of studies appropriate? | (10) Likelihood of publication bias assessed? | (11) Conflict of interest stated?; a. Systematic Review; b. Individual Studies | Quality Rating
Urquhart, 2010 | Yes | a. Yes; b. No | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | a. Yes; b. No | Good

Please see Appendix C. Included Studies for full study references.

Table F10 Quality assessment of randomized controlled trials of antidepressants

Author, Year | Randomization | Concealed Treatment Allocation | Baseline Group Similarity | Patient Blinded | Care Provider Blinded | Outcome Assessor / Data Analyst Blinded | Cointerventions Avoided or Similar | Compliance Acceptable in All Groups | Attrition Reported | Attrition Acceptable | Timing of Outcome Assessment in all Groups Similar | Intention-to-Treat Analysis | Is There a Registered or Published Protocol | Avoidance of Selective Outcomes Reporting | Quality Rating
Farajirad, 2013 | Unclear | Unclear | Yes | Unclear | No | No | Unclear | Unclear | No | Unclear | Unclear | Unclear | Unclear | Unclear | Poor
Mazza, 2010 | Unclear | Unclear | Yes | Unclear | Unclear | Unclear | Yes | Unclear | Yes | Yes | Yes | Yes | Unclear | Unclear | Fair
Skljarevski, 2009 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Unclear | Unclear | Good
Skljarevski, 2010 (Journal of Pain) | Unclear | Unclear | Unclear | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | No | Unclear | Unclear | Fair
Skljarevski, 2010 (Spine) | Unclear | Unclear | Unclear | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | No | Unclear | Unclear | Fair

Please see Appendix C. Included Studies for full study references.

Table F11 Quality assessment of randomized controlled trials of antiseizure medications

Author, Year | Randomization | Concealed Treatment Allocation | Baseline Group Similarity | Patient Blinded | Care Provider Blinded | Outcome Assessor / Data Analyst Blinded | Cointerventions Avoided or Similar | Compliance Acceptable in All Groups | Attrition Reported | Attrition Acceptable | Timing of Outcome Assessment in all Groups Similar | Intention-to-Treat Analysis | Is There a Registered or Published Protocol | Avoidance of Selective Outcomes Reporting | Quality Rating
Baron, 2010 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | Yes | Fair
Baron, 2014 | Unclear | Unclear | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | Yes | Fair
Kalita, 2014 | Yes | Unclear | Yes | No | No | No | Yes | Unclear | Yes | No | Yes | Yes | Yes | Yes | Poor
Markman, 2014 | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Fair
Pota, 2012 | Unclear | No | Yes | Yes | Unclear | Unclear | Unclear | Unclear | Yes | Yes | Yes | Yes | No | Yes | Fair
Romano, 2009 | Unclear | Unclear | Unclear | Yes | Yes | Unclear | Yes | Unclear | Yes | Yes | Yes | No | Unclear | Yes | Fair
Yaksi, 2007 | Unclear | Unclear | Yes | Unclear | Unclear | Unclear | Yes | Unclear | No | Unclear | Yes | Unclear | Unclear | Yes | Poor

Please see Appendix C. Included Studies for full study references.

Table F12 Quality assessment of randomized controlled trials of corticosteroids

Author, Year | Randomization | Concealed Treatment Allocation | Baseline Group Similarity | Patient Blinded | Care Provider Blinded | Outcome Assessor / Data Analyst Blinded | Cointerventions Avoided or Similar | Compliance Acceptable in All Groups | Attrition Reported | Attrition Acceptable | Timing of Outcome Assessment in all Groups Similar | Intention-to-Treat Analysis | Is There a Registered or Published Protocol | Avoidance of Selective Outcomes Reporting | Quality Rating
Eskin, 2014 | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Unclear | Yes | Fair
Friedman, 2008 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | Yes | Good
Hedeboe, 1982 | Unclear | Unclear | Unclear | Yes | Yes | Unclear | Yes | Unclear | No | Unclear | Yes | Yes | Unclear | Unclear | Fair
Holve, 2008 | No (sequential allocation) | No | Unclear | Yes | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | Yes | Unclear | Yes | Poor
Rodrigues, 2014 | Yes | Yes | Yes | Yes | Unclear | Yes | Yes | Unclear | Yes | Yes | Yes | Yes | Unclear | Yes | Fair

Please see Appendix C. Included Studies for full study references.

Table F13 Quality assessment of systematic reviews of exercise

Author, Year | “A priori” design provided? | Duplicate study selection and data abstraction?; a. Study selection; b. Data abstraction | Comprehensive literature search performed? | Non-English language studies considered for inclusion? | Conducted searches for unpublished (gray) literature? | List of included studies provided? | List of excluded studies provided with reasons? | Characteristics of the included studies provided? | Scientific quality of included studies:; a. Assessed?; b. Documented? | Sensitivity analyses or stratified analyses conducted according to study quality? | Study conclusions supported by the evidence? (Was study quality considered in the synthesis?) | Conflict of interest stated?; a. Systematic Review; b. Individual Studies | Multidisciplinary systematic review team? | Quality Rating
Bystrom, 2013 | Yes | a. Yes; b. no | >2 databases through October 2011; no mention of “plus” sources | No | Not stated | Yes | No | Yes | a. 10-point PEDro scale; b. marginally - score out of 10 provided; areas of methodological concern for studies not described | No; no information on heterogeneity provided | Yes | a. Systematic review: Yes, however 1 author is also author of one of the included trials; b. Individual studies: No | Unclear | Fair
Oesch, 2010 | Yes | a. Yes; b. No | Yes, >2 databases through Aug 2008; checked refs | No | Not stated | Yes | No | Yes | a. According to Juni; b. Not by study | Metaregresion-NS Effect of specific exercise characteristics; sensitivity by study quality; funnel plot | Yes | a. Funding source stated; b. No | Yes | Fair
van Middelkoop, 2010 | Yes | a. Yes; b. Yes | Data bases through 2008 for CLBP only; unclear if additional sources | Cite Cochrane Back group strategy used - assume no restriction? | Cite Cochrane Back group strategy used - assume so? | Not explicitly; references provided | No | No | a. Yes; b. Yes | No | Yes | a. No; b. No | Unclear | Fair

Please see Appendix C. Included Studies for full study references.

Table F14 Quality assessment of randomized controlled trials of exercise

Author, Year | Randomization | Concealed Treatment Allocation | Baseline Group Similarity | Patient Blinded | Care Provider Blinded | Outcome Assessor / Data Analyst Blinded | Cointerventions Avoided or Similar | Compliance Acceptable in All Groups | Attrition Reported | Attrition Acceptable | Timing of Outcome Assessment in All Groups Similar | Intention-to-Treat Analysis | Is There a Registered or Published Protocol | Avoidance of Selective Outcomes Reporting | Quality Rating
Albaladejo, 2010 | Yes | Yes | Yes | No | No | Yes | Unclear | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Fair (but results reporting poor)
Albert, 2012 | Yes | No | Yes | No | No | Yes | Unclear | Unclear | Yes | Yes | Yes | Yes | Yes | Unclear | Fair
Bronfort, 2011 | Yes | Yes | Yes | No | No | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Garcia, 2013 | Yes | Yes | Yes | No | No | Yes | Unclear | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Good
George, 2008 | Yes | No | No | No | No | Yes | Unclear | Unclear | Yes | No | Yes | Yes | Yes | Unclear | Poor
Hagen, 2010 | Yes | No | Yes | No | No | Yes | Unclear | Unclear | Yes | Yes | Yes | Yes | No | Unclear | Fair
Hartvigsen, 2010 | Unclear | Yes | Yes | No | No | Unclear | Unclear | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Fair
Helmhout, 2008 | Yes | Unclear | No | No | No | Unclear | Unclear | Unclear | Yes | Yes | Yes | Yes | Yes | Unclear | Poor
Henchoz, 2010 | Unclear | Unclear | Yes | No | No | No | Unclear | No | Yes | Yes | Yes | Yes | No | Yes | Poor
Hofstee, 2002 | Yes | No | No | No | No | No | No | Unclear | Yes | Yes | Yes | Yes | No | Unclear | Poor
Hurley, 2015 | Yes | Yes | Yes | No | No | Yes | Unclear | No | Yes | No | Yes | Yes | Yes | Yes | Fair
Jensen, 2012 | Yes | Yes | Yes | No | No | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Kell, 2011 | Unclear | Unclear | Yes | No | No | Unclear | Unclear | Unclear | No | Unclear | Yes | Unclear | No | Yes | Poor
Little, 2008 | Yes | Yes | Yes | No | No | Yes | Unclear | Yes | Yes | Yes | Yes | Unclear | Yes | Yes | Good
Macedo, 2012 | Yes | Yes | Yes | No | No | Yes | Unclear | Unclear | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear/fair
Machado, 2010 | Yes | Yes | Yes | No | No | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | Fair
Pengel, 2007 | Yes | Yes | Yes | Unclear/ sham | No | Yes | No | Unclear | Yes | Yes | Yes | Yes | Yes | Unclear | Fair

Please see Appendix C. Included Studies for full study references.

Table F15 Quality assessment of systematic reviews of Pilates

Author, Year | “A priori” design provided? | Duplicate study selection and data abstraction?; a. Study selection; b. Data abstraction | Comprehensive literature search performed? | Non-English language studies considered for inclusion? | Conducted searches for unpublished (gray) literature? | List of included studies provided? | List of excluded studies provided with reasons? | Characteristics of the included studies provided? | Scientific quality of included studies:; a. Assessed?; b. Documented? | Sensitivity analyses or stratified analyses conducted according to study quality? | Study conclusions supported by the evidence? (Was study quality considered in the synthesis?) | Conflict of interest stated?; a. Systematic Review; b. Individual Studies | Multidisciplinary systematic review team? | Quality Rating
Wells, 2014 | Yes | a. Yes; b. No | Yes, >2 databases including CINAHL, Cochrane Library, Scopus | No | Yes (Proquest - dissertations and theses; Nursing and Allied Health Source; hand search of bibliographies | Yes | No | Yes | Yes: Modified Guidelines for use of the McMasters Critical Appraisal Form for Quantitative Studies | No; no metaanalysis done; quality rating | No ; Study quality (high vs. low quality) described w/results; conclusions regarding pain short term - may be over stated; | a. Yes; b. No | Unclear | Fair

Please see Appendix C. Included Studies for full study references.

Table F16 Quality assessment of randomized controlled trials of tai chi

Author, Year | Randomization | Concealed Treatment Allocation | Baseline Group Similarity | Patient Blinded | Care Provider Blinded | Outcome Assessor / Data Analyst Blinded | Cointerventions Avoided or Similar | Compliance Acceptable in All Groups | Attrition Reported | Attrition Acceptable | Timing of Outcome Assessment in All Groups Similar | Intention-to-Treat Analysis | Is There a Registered or Published Protocol | Avoidance of Selective Outcomes Reporting | Quality Rating
Hall, 2011 | Yes | Yes | Yes | No | No | No | Unclear | Yes | Yes | Yes | Yes | Yes | No | Yes | Fair
Weifen, 2013 | Unclear | Unclear | Yes | No | No | Yes | Unclear | Yes | No | Unclear | Yes | Unclear | No | Yes | Fair

Please see Appendix C. Included Studies for full study references.

Table F17 Quality assessment of systematic reviews of yoga

Author, Year | “A priori” design provided? | Duplicate study selection and data abstraction?; a. Study selection; b. Data abstraction | Comprehensive literature search performed? | Non-English language studies considered for inclusion? | Conducted searches for unpublished (gray) literature? | List of included studies provided? | List of excluded studies provided with reasons? | Characteristics of the included studies provided? | Scientific quality of included studies:; a. Assessed?; b. Documented? | Sensitivity analyses or stratified analyses conducted according to study quality? | Study conclusions supported by the evidence? (Was study quality considered in the synthesis?) | Conflict of interest stated?; a. Systematic Review; b. Individual Studies | Multidisciplinary systematic review team? | Quality Rating
Cramer, 2013 | Yes | a. Not stated explicitly; Stated used PRISMA and Cochrane methods; b. Yes | January 2012: Medline, EMBASE, the Cochrane Library, PsycINFO, and CAMBASE | Yes | No | Yes | Yes - full text; reason with citation | Yes | a. 2009 Updated Method Guidelines for Systematic Reviews in the Cochrane Back Review Group; b. Yes | Yes; high vs. low ROB; if heterogeneity | Study quality considered; Conclusions regarding pain, disability are supported; HRQOL conclusions - seem to be downgraded more (short term) than rating scheme might suggest? Limited info on adverse events available, but conclude that Yoga not associated with serious adverse events | a. Systematic review: Yes; b. Individual studies: No | Unclear | Good

Please see Appendix C. Included Studies for full study references.

Table F18 Quality assessment of randomized controlled trials of yoga

Author, Year | Randomization | Concealed Treatment Allocation | Baseline Group Similarity | Patient Blinded | Care Provider Blinded | Outcome Assessor / Data Analyst Blinded | Cointerventions Avoided or Similar | Compliance Acceptable in All Groups | Attrition Reported | Attrition Acceptable | Timing of Outcome Assessment in All Groups Similar | Intention-to-Treat Analysis | Is There a Registered or Published Protocol | Avoidance of Selective Outcomes Reporting | Quality Rating
Nambi, 2014 | Yes | Unclear | Yes | No | Unclear | Unclear | Unclear | Unclear | Yes | Yes | Yes | Yes | No | unclear | Poor
Saper, 2013 | Yes | Unclear | No (But adjusted estimates for baseline differences were essentially the same as crude estimates) | No | Unclear | Yes | Yes use of other treatments overall: 53% (26/47) vs.. 61% (28/44); similar % for massage, PH, acupuncture, chiropractic, epidural injections | No; attendance: 65% for once weekly class, 44% for twice weekly classes | Yes | Yes | Yes | Yes | Yes | Yes | Fair

Please see Appendix C. Included Studies for full study references.

Table F19 Quality assessment of systematic reviews of psychological therapies

Author, Year | “A priori” design provided? | Duplicate study selection and data abstraction?; a. Study selection; b. Data abstraction | Comprehensive literature search performed? | Non-English language studies considered for inclusion? | Conducted searches for unpublished (gray) literature? | List of included studies provided? | List of excluded studies provided with reasons? | Characteristics of the included studies provided? | Scientific quality of included studies:; a. Assessed?; b. Documented? | Sensitivity analyses or stratified analyses conducted according to study quality? | Study conclusions supported by the evidence? (Was study quality considered in the synthesis?) | Conflict of interest stated?; a. Systematic Review; b. Individual Studies | Multidisciplinary systematic review team? | Quality Rating
Henschke, 2010 | Yes | a. Yes; b. Yes | Yes | Yes | Unclear | Yes | Yes | Yes | a. Yes; b. Yes | No | Yes (yes) | a. Yes; b. No | Yes | Good

Please see Appendix C. Included Studies for full study references.

Table F20 Quality assessment of randomized controlled trials of psychological therapy

Author, Year | Randomization | Concealed Treatment Allocation | Baseline Group Similarity | Patient Blinded | Care Provider Blinded | Outcome Assessor / Data Analyst Blinded | Cointerventions Avoided or Similar | Compliance Acceptable in All Groups | Attrition Reported | Attrition Acceptable | Timing of Outcome Assessment in All Groups Similar | Intention-to-Treat Analysis | Is There a Registered or Published Protocol | Avoidance of Selective Outcomes Reporting | Quality Rating
Kahn, 2014 | Yes | Unclear | Unclear (age, sex, duration of pain NR, slight differences in pain and function at baseline) | Yes (statement that patients were blind to the study) | No (but blinding not possible for these interventions) | Yes (outcomes patient reported) | Unclear | Unclear | Yes | Yes (100%) | Yes | Unclear | No | Yes | Fair
Lamb 2010/2012 | Yes | Yes | Yes | No | No (but blinding not possible for these interventions) | Yes | No (control group free to seek any additional care on their own; additional treatments received not reported) | No Intervention group: 63% (294/468) Control group: 100% (233/233) | Yes | Yes (85% in both groups) | Yes | No | Yes | Yes | Fair
Siemonsma, 2013 | Yes | Yes | Yes | No | No (but blinding not possible for these interventions) | Yes | Yes | No Intervention group: 81.7% Control group (waiting list, no interventions permitted): Unclear | Yes | Yes (89% was lowest f/u reported (for activity-specific pain, 139/156) | Yes | No (Their fig 1 makes it look like all pts randomized were included in the primary analysis but the paragraph under “Primary Outcome” contradicts this.) | Yes | Yes | Fair
Vong, 2011 | Yes | Unclear | Yes | Yes (patients told they would receive one of two types of conventional patient treatment but did not know anything about motivational enhancement therapy) | No (but blinding not possible for these interventions) | Yes (outcomes patient reported) | Yes | No Intervention group: 62% Control group: 63% (% of patients who participated fully) | Yes | yes (86%) | Yes | No (they said they used ITT but 12 patients who were randomized did not receive treatment and were excluded from all analyses) | No | Yes | Fair

Table F21 Quality assessment of systematic reviews of multidisciplinary rehabilitation

Author, Year | “A priori” design provided? | Duplicate study selection and data abstraction?; a. Study selection; b. Data abstraction | Comprehensive literature search performed? | Non-English language studies considered for inclusion? | Conducted searches for unpublished (gray) literature? | List of included studies provided? | List of excluded studies provided with reasons? | Characteristics of the included studies provided? | Scientific quality of included studies:; a. Assessed?; b. Documented? | Sensitivity analyses or stratified analyses conducted according to study quality? | Study conclusions supported by the evidence? (Was study quality considered in the synthesis?) | Conflict of interest stated?; a. Systematic review; b. Individual studies | Multidisciplinary systematic review team? | Quality Rating
Kamper, 2014 | Yes | a. Yes; b. Yes | Yes | Yes | No | Yes | No | Yes | a. Yes; b. Yes | Yes | Yes | a. Yes; b. No | Yes | Good

Please see Appendix C. Included Studies for full study references.

Table F22 Quality assessment of randomized controlled trials of multidisciplinary rehabilitation

Author, Year | Randomization | Concealed Treatment Allocation | Baseline Group Similarity | Patient Blinded | Care Provider Blinded | Outcome Assessor / Data Analyst Blinded | Cointerventions Avoided or Similar | Compliance Acceptable in All Groups | Attrition Reported | Attrition Acceptable | Timing of Outcome Assessment in All Groups Similar | Intention-to-Treat Analysis | Is There a Registered or Published Protocol | Avoidance of Selective Outcomes Reporting | Quality Rating
Eisenberg, 2012 | Yes | Unclear | Yes | No | No | Unclear | NA | Yes | Yes | Yes | Yes | Yes | No | Unclear | Good
Gatchel, 2003 | Yes | Unclear | Unclear | No | No | Unclear | NA | Yes | No | NA | Yes | Unclear | Yes | Unclear | Fair
Monticone, 2014 | Yes | Unclear | Yes | Yes | No | Unclear | NA | Yes | Yes | Yes | Yes | Yes | No | Unclear | Good

Please see Appendix C. Included Studies for full study references.

Table F23 Quality assessment of systematic reviews of acupuncture

Author, Year | “A priori” design provided? | Duplicate study selection and data abstraction?; a. Study selection; b. Data abstraction | Comprehensive literature search performed? | Non-English language studies considered for inclusion? | Conducted searches for unpublished (gray) literature? | List of included studies provided? | List of excluded studies provided with reasons? | Characteristics of the included studies provided? | Scientific quality of included studies:; a. Assessed?; b. Documented? | Sensitivity analyses or stratified analyses conducted according to study quality? | Study conclusions supported by the evidence? (Was study quality considered in the synthesis?) | Conflict of interest stated?; a. Systematic Review; b. Individual Studies | Multidisciplinary systematic review team? | Quality Rating
Lam, 2013 | Unclear | a. Yes; b. Yes | Yes | Yes | No | Yes | No | Yes | a. Yes; b. Yes | No | Unclear | a. Yes; b. No | No | Fair
Lee, 2013 | Unclear | a. Yes; b. Yes | Yes | Yes | Yes | Yes | No | Yes | a. Yes; b. Yes | Yes | Yes | a. Yes; b. No | No | Fair

Please see Appendix C. Included Studies for full study references.

Table F24 Quality assessment of randomized controlled trials of acupuncture

Author, Year | Randomization adequate? | Allocation concealment adequate? | Groups similar at baseline? | Eligibility criteria specified? | Patients masked? | Care provider masked? | Outcomes assessors masked? | Attrition and withdrawals reported? | Attrition acceptable and comparable? | Analyze people in the groups in which they were randomized | Primary outcome specified and reported? | Other issues | Quality Rating
Cho, 2013 | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | None | Good
Hasagawa, 2014 | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | None | Good
Vas, 2012 | Yes | Yes | Yes | Yes | Yes (for acupuncture and sham groups only) | No | Yes | Yes | Yes | Yes | Yes | None | Good
Yun, 2012 (back points) | Yes | Unclear, but likely ok - just says “central randomization with random block sizes” | Yes | Yes | Yes (only for acupuncture groups, not for usual care group) | No | Yes | Yes | Yes | Yes | Yes | None | Fair
Weiss, 2013 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Yes | Yes | Unclear | Exploratory only | Poor

Please see Appendix C. Included Studies for full study references.

Table F25 Quality assessment of systematic reviews of massage

Author, Year | “A priori” design provided? | Duplicate study selection and data abstraction?; a. Study selection; b. Data abstraction | Comprehensive literature search performed? | Non-English language studies considered for inclusion? | Conducted searches for unpublished (gray) literature? | List of included studies provided? | List of excluded studies provided with reasons? | Characteristics of the included studies provided? | Scientific quality of included studies:; a. Assessed?; b. Documented? | Sensitivity analyses or stratified analyses conducted according to study quality? | Study conclusions supported by the evidence? (Was study quality considered in the synthesis?) | Conflict of interest stated?; a. Systematic Review; b. Individual Studies | Multidisciplinary systematic review team? | Quality Rating
Furlan, 2010 | Yes | a. Yes; b. Yes | Yes | Yes | Yes | Yes | Yes | Yes | a. Yes; b. Yes | Yes | Yes | a. Yes; b. No | Yes | Good

Please see Appendix C. Included Studies for full study references.

Table F26 Quality assessment of randomized controlled trials of massage

Author, Year | Randomization adequate? | Allocation concealment adequate? | Groups similar at baseline? | Eligibility criteria specified? | Outcome assessors masked? | Care provider masked? | Patient masked? | Attrition and withdrawals reported? | Attrition acceptable and comparable? | Analyze people in the groups in which they were randomized | Primary outcome specified and reported? | Other issues? | Quality Rating
Ajimsha, 2014 | Unclear | No | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | None | Fair
Borges, 2014 | Yes | Unclear | Yes | Yes | Unclear | No | Unclear | Yes | Yes | Yes | Yes | None | Fair
Cherkin, 2011 | Yes | Yes | Yes | Yes | Yes - for the two massage groups only | No | Yes | Yes | Yes | Yes | Yes | None | Good
Kong, 2012 | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | None | Good
Romanowski, 2012 | Unclear | Unclear | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | None | Poor
Sritooma, 2014 | Yes | Unclear | Yes | Yes | No | No | No - not described | Yes | Yes | Yes | Yes | None | Fair
Zhang, 2015 | No | No | Yes | Yes | Yes | No | Unclear | Yes | Yes | Yes | Yes | None | Fair
Zheng, 2012 | Yes | Unknown | Yes | Yes | Unclear | Unclear | Unclear | Yes | Yes | Yes | Yes | None | Fair

Please see Appendix C. Included Studies for full study references.

Table F27 Quality assessment of systematic reviews of spinal manipulation

Author, Year | “A priori” design provided? | Duplicate study selection and data abstraction?; a. Study selection; b. Data abstraction | Comprehensive literature search performed? | Non-English language studies considered for inclusion? | Conducted searches for unpublished (gray) literature? | List of included studies provided? | List of excluded studies provided with reasons? | Characteristics of the included studies provided? | Scientific quality of included studies:; a. Assessed?; b. Documented? | Sensitivity analyses or stratified analyses conducted according to study quality? | Study conclusions supported by the evidence? (Was study quality considered in the synthesis?) | Conflict of interest stated?; a. Systematic Review; b. Individual Studies | Multidisciplinary systematic review team? | Quality Rating
Rubinstein, 2011 | Yes | a. Yes; b. Yes | Yes | Yes | Yes | Yes | Yes | Yes | a. Yes; b. Yes | Yes | Yes | a. Yes; b. Yes | Yes | Good
Rubinstein, 2012 | Yes | a. Yes; b. Yes | Yes | Unclear | Yes, but excluded from analysis | Yes | Yes | Yes | a. Yes; b. Yes | Yes | Yes | a. Yes; b. Yes | Yes | Good

Please see Appendix C. Included Studies for full study references.

Table F28 Quality assessment of randomized controlled trials of SMT

Author, Year | Randomization adequate? | Allocation concealment adequate? | Groups similar at baseline? | Eligibility criteria specified? | Patient masked? | Care provider masked? | Outcomes assessor masked? | Attrition and withdrawals reported? | Attrition acceptable and comparable? | Analyze people in the groups in which they were randomized | Primary outcome specified and reported? | Other issues | Quality Rating
Balthazard, 2012 | Yes | Unclear | Yes - although pain slightly higher in sham group (53 vs. 62) but not statistically significant | Yes | No | No | Unclear | Yes | Yes | Yes | Yes | None | Fair
Bicahlo, 2010 | Yes | Unclear | Yes | Yes | No | No | Unclear | Yes | Yes | Yes | Yes | Incomplete reporting of outcomes (function) | Fair
Bronfort, 2004 | Yes | No | Yes | Yes | No | No | No | No | Unclear | Yes | No | Primary outcome not specified | Poor
Bronfort, 2011 | Yes | Yes | Yes | No | No | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Good
Bronfort, 2014 | Yes - minimization used, not randomization | Yes | Yes | Yes | No | No | No | Yes | Yes | Yes | Yes | None | Fair - not blinded
Burton, 2000 | Yes | Yes | Yes | Yes | No | No | No | Yes | Unclear | Yes | Yes | None | Poor
Cecchi, 2010 | Yes | Unclear | No - sick leave higher in back school group compared to other groups | Yes | No | No | Unclear | Yes | Yes | Yes | Yes | None | Fair
De Oliviera, 2013 | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | None | Good
Goertz, 2013 | Yes | Yes | Yes | Yes | No | No | Yes | Yes | No - low followup rate in the SMC group | Yes | Yes | None | Fair
Haas, 2014 | Yes | Yes | Yes | Yes | No | No | Yes | Yes | Yes | Yes | Yes | None | Good
Paatelma, 2008 | Yes | Yes | Yes | Yes | No | No | Yes | Yes | No - high drop out rate | Yes | Yes | None | Fair
Petersen, 2011 | Yes | Yes | Yes | Yes | No | No | Yes | Yes | Yes | Yes | Yes | None | Good
Santilli, 2006 | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | Yes | None | Good
Schneider, 2015 | Yes | Yes | Yes | Yes | No | No | Yes | Yes | Yes | Yes | Yes | None | Good
Senna, 2011 | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | No - low followup rate in sham SMT group | Yes | Yes | None | Fair
Von Heymann, 2013 | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | No - low followup rate | Yes | Yes | Unclear intervention (Single treatment?), small sample size with high drop out rate | Fair

Please see Appendix C. Included Studies for full study references.

Table F29 Quality assessment of systematic reviews of ultrasound

Author, Year | “A priori” design provided? | Duplicate study selection and data abstraction?; a. Study selection; b. Data abstraction | Comprehensive literature search performed? | Non-English language studies considered for inclusion? | Conducted searches for unpublished (gray) literature? | List of included studies provided? | List of excluded studies provided with reasons? | Characteristics of the included studies provided? | Scientific quality of included studies:; a. Assessed?; b. Documented? | Sensitivity analyses or stratified analyses conducted according to study quality? | Study conclusions supported by the evidence? (Was study quality considered in the synthesis?) | Conflict of interest stated?; a. Systematic Review; b. Individual Studies | Multidisciplinary systematic review team? | Quality Rating
Ebadi, 2014 | Yes | Yes/Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes (considered in SOE analyses) | Yes | Yes/No | Yes | Good

Please see Appendix C. Included Studies for full study references.

Table F30 Quality assessment of randomized controlled trials of ultrasound

Author, Year | Randomization | Concealed Treatment Allocation | Baseline Group Similarity | Patient Blinded | Care Provider Blinded | Outcome Assessor / Data Analyst Blinded | Cointerventions Avoided or Similar | Compliance Acceptable in all Groups | Attrition Reported | Attrition Acceptable | Timing of Outcome Assessment in all Groups Similar | Intention-to-Treat Analysis | Is There a Registered or Published Protocol | Avoidance of Selective Outcomes Reporting | Quality (Cochrane Back Group)
Bronfort, 2011 | Yes | Yes | Yes | No | No | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Fiore, 2011 | Yes | Yes | Unclear | No | No | Yes | Unclear | Unclear | Yes | Yes | Yes | Yes | Unclear | Unclear | Fair
Goren, 2010 | Yes | Yes | Yes | Yes | Unclear | Yes | Yes | Unclear | Yes | Yes | Yes | Yes | Unclear | Unclear | Fair
Licciardone, 2013 | Yes | Yes | Yes | Yes | Unclear | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Unlu, 2008 | Unclear | Unclear | Yes | No | No | Unclear | Unclear | Unclear | No | Unclear | Yes | Unclear | Unclear | Unclear | Poor

Please see Appendix C. Included Studies for full study references.

Table F31 Quality assessment of systematic reviews of TENS

Author, Year | “A priori” design provided? | Duplicate study selection and data abstraction?; a. Study selection; b. Data abstraction | Comprehensive literature search performed? | Non-English language studies considered for inclusion? | Conducted searches for unpublished (gray) literature? | List of included studies provided? | List of excluded studies provided with reasons? | Characteristics of the included studies provided? | Scientific quality of included studies:; a. Assessed?; b. Documented? | Sensitivity analyses or stratified analyses conducted according to study quality? | Study conclusions supported by the evidence? (Was study quality considered in the synthesis?) | Conflict of interest stated?; a. Systematic Review; b. Individual Studies | Multidisciplinary systematic review team? | Quality Rating
van Middelkoop, 2011 | Yes | a. Yes; b. Yes | Yes | Yes | Unclear | Yes | No | Yes | a. Yes; b. Yes | Unclear | Yes | a. Yes; b. Yes | Unclear | Good

Please see Appendix C. Included Studies for full study references.

Table F32 Quality assessment of randomized controlled trials of TENS

Author, Year | Randomization | Concealed Treatment Allocation | Baseline Group Similarity | Patient Blinded | Care Provider Blinded | Outcome Assessor / Data Analyst Blinded | Cointerventions Avoided or Similar | Compliance Acceptable in All Groups | Attrition Reported | Attrition Acceptable | Timing of Outcome Assessment in all Groups Similar | Intention-to-Treat Analysis | Is There a Registered or Published Protocol | Avoidance of Selective Outcomes Reporting | Quality Rating
Buchmuller, 2012 | Yes | Yes | Yes | Yes | No | No | Yes | Yes | Yes | No | Yes | Unclear | Unclear | Unclear | Fair
Facci, 2011 | Yes | Yes | No; significant difference between TENS and control in pain intensity at baseline (p=0.009) | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear | Good
Shimoji, 2007 | Unclear | Unclear | Yes | Yes | Unclear | Yes | Yes | Yes | No | Unclear | Yes | Unclear | Unclear | Unclear | Fair
Tsukayama, 2002 | Yes | Unclear | Yes | No | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear | Fair

Please see Appendix C. Included Studies for full study references.

Table F33 Quality assessment of randomized controlled trials of electrical stimulation

Author, Year | Randomization | Concealed Treatment Allocation | Baseline Group Similarity | Patient Blinded | Care Provider Blinded | Outcome Assessor / Data Analyst Blinded | Cointerventions Avoided or Similar | Compliance Acceptable in all Groups | Attrition Reported | Attrition Acceptable | Timing of Outcome Assessment in all Groups Similar | Intention-to-Treat Analysis | Is There a Registered or Published Protocol | Avoidance of Selective Outcomes Reporting | Quality (Cochrane Back Group) | Comments
Durmus, 2009 | Unclear | Unclear | Yes | No | No | Unclear | Unclear | Unclear | No | Unclear | Yes | Unclear | Unclear | Yes | Poor | Some outcomes assessed as means and others as medians, no explanation provided
Durmus, 2010 | Unclear | Unclear | Yes | No | No | Unclear | Unclear | Unclear | Yes | Yes | Yes | No | Unclear | Yes | Poor | Some outcomes assessed as means and others as medians, no explanation provided
Glaser, 2001 | Yes | Unclear | Yes | Yes | Yes | Unclear | Unclear | Unclear | Yes | No | Yes | No | Unclear | Yes | Poor | Very high loss to followup
Moore, 1997 | Unclear | Unclear | Unclear | Yes | Unclear | Unclear | Unclear | Unclear | Yes | Yes | Yes | No | Unclear | Yes | Poor | Crossover design, results of first intervention not reported and carryover effects not assessed
Pope, 1994 | Yes | Unclear | Unclear | No | No | Yes | Unclear | No | Yes | Yes | Yes | Unclear | Yes | Yes | Fair

Please see Appendix C. Included Studies for full study references.

Table F34 Quality assessment of randomized controlled trials of PENS

Author, Year | Randomization | Concealed Treatment Allocation | Baseline Group Similarity | Patient Blinded | Care Provider Blinded | Outcome Assessor / Data Analyst Blinded | Cointerventions Avoided or Similar | Compliance Acceptable in all Groups | Attrition Reported | Attrition Acceptable | Timing of Outcome Assessment in all Groups Similar | Intention-to-Treat Analysis | Is There a Registered or Published Protocol | Avoidance of Selective Outcomes Reporting | Quality Rating
Hamza, 1999 | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Yes | No | Yes | Unclear | Unclear | Unclear | Poor
Pérez-Palomares, 2010 | Yes | Unclear | Unclear | No | No | Yes | Unclear | Unclear | Yes | Yes | Yes | Unclear | Unclear | Unclear | Poor
Weiner, 2008 | Yes | Unclear | Yes | Yes | No | Yes | Unclear | Unclear | Yes | Yes | Yes | Yes | Unclear | Yes | Fair

Please see Appendix C. Included Studies for full study references.

Table F35 Quality assessment of randomized controlled trials of interferential therapy

Author, Year | Randomization | Concealed Treatment Allocation | Baseline Group Similarity | Patient Blinded | Care Provider Blinded | Outcome Assessor / Data Analyst Blinded | Cointerventions Avoided or Similar | Compliance Acceptable in all Groups | Attrition Reported | Attrition Acceptable | Timing of Outcome Assessment in all Groups Similar | Intention-to-Treat Analysis | Is There a Registered or Published Protocol | Avoidance of Selective Outcomes Reporting | Quality Rating
Lara-Palomo, 2013 | Yes | Yes | Yes | No | No | Unclear | Unclear | Unclear | Yes | Yes | Yes | Yes | Unclear | Yes | Fair

Please see Appendix C. Included Studies for full study references.

Table F36 Quality assessment of systematic reviews of heat-cold

Author, Year | “A priori” design provided? | Duplicate study selection and data abstraction?; a. Study selection; b. Data abstraction | Comprehensive literature search performed? | Non-English language studies considered for inclusion? | Conducted searches for unpublished (gray) literature? | List of included studies provided? | List of excluded studies provided with reasons? | Characteristics of the included studies provided? | Scientific quality of included studies:; a. Assessed?; b. Documented? | Sensitivity analyses or stratified analyses conducted according to study quality? | Study conclusions supported by the evidence? (Was study quality considered in the synthesis?) | Conflict of interest stated?; a. Systematic Review; b. Individual Studies | Multidisciplinary systematic review team? | Quality Rating
French, 2006 Updated in French, 2011 | Yes | a. Yes; b. Yes | Yes | Unclear | Unclear | Yes | Yes (no reasons for exclusion provided) | Yes | a. Yes; b. Yes | No | Yes | a. Yes; b. No | Yes | Good

Please see Appendix C. Included Studies for full study references.

Table F37 Quality assessment of randomized controlled trials of heat-cold

Author, Year | Randomization | Concealed Treatment Allocation | Baseline Group Similarity | Patient Blinded | Care Provider Blinded | Outcome Assessor / Data Analyst Blinded | Cointerventions Avoided or Similar | Compliance Acceptable in All Groups | Attrition Reported | Attrition Acceptable | Timing of Outcome Assessment in all Groups Similar | Intention-to-Treat Analysis | Is There a Registered or Published Protocol | Avoidance of Selective Outcomes Reporting | Quality
Dehgan, 2014 | Unclear | Unclear | Unclear | No | Unclear | Unclear | Unclear | Unclear | Yes | Yes | Yes | Yes | Unclear | Unclear | Fair
Kettenmann, 2007 | Unclear | Unclear | Yes | No | Unclear | Unclear | Yes | Unclear | Yes | No | Yes | No | Unclear | Unclear | Fair
Stark, 2014 | Unclear | Unclear | Yes | No | Unclear | Unclear | Yes | Unclear | No | Unclear | Yes | Yes | Yes | Unclear | Fair
Tao, 2005 | Unclear | Unclear | Yes | No | Unclear | Unclear | Unclear | Unclear | No | Unclear | Yes | Unclear | Unclear | Unclear | Poor

Please see Appendix C. Included Studies for full study references.

Table F38 Quality assessment of randomized controlled trials of LLLT

Author, Year | Randomization | Concealed Treatment Allocation | Baseline Group Similarity | Patient Blinded | Care Provider Blinded | Outcome Assessor / Data Analyst Blinded | Cointerventions Avoided or Similar | Compliance Acceptable in All Groups | Attrition Reported | Attrition Acceptable | Timing of Outcome Assessment in all Groups Similar | Intention-to-Treat Analysis | Is There a Registered or Published Protocol | Avoidance of Selective Outcomes Reporting | Quality Rating
Ay, 2010 | Yes | Unclear | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear | Good
Djavid, 2007 | Unclear | Yes | Yes | Unclear | Yes | Yes | Unclear | Yes | Yes | Yes | Yes | No | Unclear | Unclear | Fair
Hsieh, 2014 | Yes | Yes | Yes | Yes | No | Unclear | Unclear | Unclear | Yes | Yes | Yes | Yes | Unclear | Unclear | Fair
Jovicic, 2012 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear | Fair
Konstantinovic, 2010 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear | Good
Vallone, 2014 | Yes | Yes | Unclear | Yes | Unclear | Unclear | Yes | Unclear | No | Unclear | Yes | Unclear | Unclear | Unclear | Fair

Please see Appendix C. Included Studies for full study references.

Table F39 Quality assessment of randomized controlled trials of diathermy

Author, Year | Randomization | Concealed Treatment Allocation | Baseline Group Similarity | Patient Blinded | Care Provider Blinded | Outcome Assessor / Data Analyst Blinded | Cointerventions Avoided or Similar | Compliance Acceptable in all Groups | Attrition Reported | Attrition Acceptable | Timing of Outcome Assessment in all Groups Similar | Intention-to-Treat Analysis | Is There a Registered or Published Protocol | Avoidance of Selective Outcomes Reporting | Quality Rating
Ahmed, 2009 | Unclear | Unclear | Unclear | Yes | Unclear | Unclear | Unclear | Unclear | No | Unclear | Yes | No | Unclear | Unclear | Poor
Shakoor, 2008 | Unclear | Unclear | Unclear | Yes | Unclear | Unclear | Yes | Unclear | No | Unclear | Yes | No | Unclear | Unclear | Poor

Please see Appendix C. Included Studies for full study references.

Table F40 Quality assessment of systematic reviews of lumbar supports

Author, Year | “A priori” design provided? | Duplicate study selection and data abstraction?; a. Study selection; b. Data abstraction | Comprehensive literature search performed? | Non-English language studies considered for inclusion? | Conducted searches for unpublished (gray) literature? | List of included studies provided? | List of excluded studies provided with reasons? | Characteristics of the included studies provided? | Scientific quality of included studies:; a. Assessed?; b. Documented? | Sensitivity analyses or stratified analyses conducted according to study quality? | Study conclusions supported by the evidence? (Was study quality considered in the synthesis?) | Conflict of interest stated?; a. Systematic Review; b. Individual Studies | Multidisciplinary systematic review team? | Quality Rating
van Duijvenbode, 2011 | Yes | a. Yes; b. Yes | Yes | Yes | Unclear | Yes | Yes | Yes | a. Yes; b. Yes | Yes | Yes | a. Yes; b. No | Yes | Good

Please see Appendix C. Included Studies for full study references.

Table F41 Quality assessment of randomized controlled trials of lumbar support

Author, Year | Randomization | Concealed Treatment Allocation | Baseline Group Similarity | Patient Blinded | Care Provider Blinded | Outcome Assessor / Data Analyst Blinded | Cointerventions Avoided or Similar | Compliance Acceptable in all Groups | Attrition Reported | Attrition Acceptable | Timing of Outcome Assessment In All Groups Similar | Intention-to-Treat Analysis | Is There a Registered or Published Protocol | Avoidance of Selective Outcomes Reporting | Quality Rating
Calmels, 2009 | Yes | Unclear | Yes (reported in text; data not shown for some characteristics) | No | No | Unclear | Yes | Unclear | Yes | Yes | Yes | No | Unclear | Unclear | Fair
Morrisette, 2014 | Yes | Yes | Yes | No | No | Unclear | Unclear | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear | Fair
Oleske, 2007 | Yes | Yes | Yes | No | No | Yes | Yes | Unclear | Yes | Yes | Yes | Yes | Unclear | Unclear | Fair
Sato, 2012 | Yes | Unclear | Yes (reported in text; data not shown) | No | No | Unclear | Yes | Unclear | Yes | Yes | Yes | No | Unclear | Unclear | Fair

Please see Appendix C. Included Studies for full study references.

Table F42 Quality assessment of systematic reviews of traction

Author, Year | “A priori” design provided? | Duplicate study selection and data abstraction?; a. Study selection; b. Data abstraction | Comprehensive literature search performed? | Non-English language studies considered for inclusion? | Conducted searches for unpublished (gray) literature? | List of included studies provided? | List of excluded studies provided with reasons? | Characteristics of the included studies provided? | Scientific quality of included studies:; a. Assessed?; b. Documented? | Sensitivity analyses or stratified analyses conducted according to study quality? | Study conclusions supported by the evidence? (Was study quality considered in the synthesis?) | Conflict of interest stated?; a. Systematic Review; b. Individual Studies | Multidisciplinary systematic review team? | Quality Rating
Wegner, 2013 | Yes | a. Yes; b. Yes | Yes | Yes | Yes | Yes | Yes | Yes | a. Yes; b. Yes | Yes | Yes | a. Yes; b. No | Yes | Good

Please see Appendix C. Included Studies for full study references.

Table F43 Quality assessment of randomized controlled trials of traction

Author, year | Randomization | Concealed treatment allocation | Baseline group similarity | Patient blinded | Care provider blinded | Outcome assessor / Data analyst blinded | Cointerventions avoided or similar | Compliance acceptable in all groups | Attrition reported | Attrition acceptable | Timing of outcome assessment in all groups similia | Intention-to-treat analysis | Is there a registered or published protocol | Avoidance of selective outcomes reporting | Quality Rating
Diab, 2012 and Diab, 2013 | Yes | Yes | Yes | No | No | No | Yes | Yes | Yes | Yes | Yes | Unclear | Yes | Yes | Fair
Moustafa, 2013 | Yes | Yes | Yes | No | Unclear | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear | Fair
Prasad, 2013 | Unclear | Unclear | Yes | No | Yes | Unclear | Yes | Unclear | Yes | No | Yes | No | Unclear | Unclear | Poor

Please see Appendix C. Included Studies for full study references.

Table F44 Quality assessment of randomized controlled trials of taping

Author, Year | Randomization | Concealed Treatment Allocation | Baseline Group Similarity | Patient Blinded | Care Provider Blinded | Outcome Assessor / Data Analyst Blinded | Cointerventions Avoided or Similar | Compliance Acceptable in All Groups | Attrition Reported | Attrition Acceptable | Timing of Outcome Assessment in all Groups Similar | Intention-to-Treat Analysis | Is There a Registered or Published Protocol | Avoidance of Selective Outcomes Reporting | Quality Rating
Bae, 2013 | Unclear | Unclear | Yes | No | No | Unclear | Yes | Unclear | No | Unclear | Yes | Yes | Unclear | Yes | Fair
Castro-Sanchez, 2012 | Yes | Yes | P | Yes | No | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Unclear | Yes | Good
Chen, 2012 | Unclear | Unclear | Yes | No | No | Yes | Unclear | Unclear | Yes | Yes | Yes | Yes | Unclear | Yes | Fair
Kachanathu, 2014 | Unclear | Unclear | Unclear | No | No | Unclear | Unclear | Unclear | No | Unclear | Yes | Unclear | Unclear | Yes | Poor
Paolini, 2011 | Yes | Unclear | Yes | No | No | Unclear | Unclear | Unclear | No | Unclear | Yes | Unclear | Unclear | Yes | Fair
Silva Parreira, 2014 | Yes | Yes | Yes | Yes | No | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good

Please see Appendix C. Included Studies for full study references