# Data Abstraction

Table E1 Data abstraction of systematic reviews of acetaminophen

Table E2 Data abstraction of randomized controlled trials of acetaminophen

Table E3 Data abstraction of systematic reviews of NSAIDs

Table E4 Data abstraction of randomized controlled trials of NSAIDs

Table E5 Study characteristics of systematic reviews of opioids

Table E6 Data abstraction of randomized controlled trials of opioids

Table E7 Data abstraction of randomized controlled trials of SMRs

Table E8 Data abstraction of randomized controlled trials of benzodiazepines

Table E9 Dat abstraction of systematic reviews of antidepressants for low back pain

Table E10 Data abstraction of randomized controlled trials of antidepressants

Table E11 Data abstraction of randomized controlled trials of antiseizure medications

Table E12 Data abstraction of randomized controlled trials of corticosteroids

Table E13 Study characteristics of systematic reviews of exercise

Table E14 Data abstraction of randomized controlled trials of exercise

Table E15 Data abstraction of systematic reviews of Pilates

Table E16 Data abstraction of randomized controlled trials of tai chi

Appendix 17 Data abstraction of systematic reviews of yoga

Table E18 Data abstraction of randomized controlled trials of yoga

Table E19 Data abstraction of systematic reviews of psychological therapies

Table E20 Data abstraction of randomized controlled trials of psychological therapies

Table E21 Data abstraction of systematic reviews of multidisciplinary rehabilitation

Table E22 Data abstraction of randomized controlled trials of multidisciplinary rehabilitation

Table E23 Data abstraction of systematic reviews of acupuncture

Table E24 Data abstraction of randomized controlled trials of acupuncture

Table E25 Data abstraction of systematic reviews of massage

Table E26 Data abstraction of randomized controlled trials of massage

Table E27 Data abstraction of systematic reviews of spinal manipulation

Table E28 Data abstraction of randomized controlled trials of spinal manipulation

Table E29 Data abstraction of systematic reviews of ultrasound

Table E30 Data abstraction of randomized controlled trials of ultrasound

Table E31 Data abstraction of systematic reviews of TENS

Table E32 Data abstraction of randomized controlled trials of TENS

Table E33 Data abstraction of randomized controlled trials of electrical stimulation

Table E34 Data abstraction of randomized controlled trials of PENS

Table E35 Data abstraction of randomized controlled trials of interferential therapy

Table E36 Data abstraction of systematic reviews of heat-cold

Table E37 Data abstraction of randomized controlled trials of heat-cold

Table E38 Data abstraction of randomized controlled trials of LLLT

Table E39 Data abstraction of randomized controlled trials of diathermy

Table E40 Data abstraction of systematic reviews of lumbar supports

Table E41 Data abstraction of randomized controlled trials of lumbar support

Table E42 Data abstraction of systematic reviews of traction

Table E43 Data abstraction of randomized controlled trials of traction

Table E44 Data abstraction of randomized controlled trials of taping