# Outcome Measures

Table G1 Outcome measures

Outcome Measure | Measure Description | Score Range and Direction | Section of Current Report
SF-12® Health Survey | - Short form survey with 12 questions from the SF-36 Health Survey; - Two scales: mental and physical functioning and overall health-related-quality of life; - 4-week recall of symptoms | - Scores range from 0 to 100 (zero score indicates the lowest level of health and 100 indicates the highest level of health) | Antiseizure Medications; Opioids; Psychological Therapies
Athens Insomnia Scale (AIS) | - Assesses the severity of insomnia; evaluates sleep onset, night and early-morning waking, sleep time, sleep quality, frequency and duration of complaints, distress caused by the experience of insomnia, and interference with daily functioning. | - Likert-type scales to show how severely certain sleep difficulties have affected them during the past month.; - Scores range from 0 (meaning that the item in question has not been a problem) to 3 (indicating more acute sleep difficulties) | Antidepressants
Beck Depression Inventory (BDI) | The BDI is a 21-item measure of depressive symptomatology, including items assessing both cognitive and somatic complaints associated with depression. Survey is completed by patient | Scored on 0 to 3 scale Minimal: 0 Severe: 3 Each item represents a symptom or belief that is rated from 0 to 3 in terms of intensity. The BDI consists of 21 groups of statements, and after reading each group of statements, participants mark the statement in each group that best describes the way they have been feeling over the previous week. | Electrical Stimulation
BPI- Short Form (BPI-SF) | A 9 item self-administered questionnaire used to evaluate the severity of a patient's pain and the impact of this pain on the patient's daily functioning | Rating of: worst, least, average, and current pain intensity, list current treatments and their perceived effectiveness, and rate the degree that pain interferes with general activity, mood, walking ability, normal work, relations with other persons, sleep, and enjoyment of life on a 10 point scale. (Higher score indicates higher level of pain) | Antiseizure Medications
Brief Pain Inventory (BPI) | To assess the severity of pain and the impact of pain on daily functions | The BPI assesses pain at its “worst,” “least,” “average,” and “now” (current pain). In clinical trials, the items “worst” and “average” have each been used singly to represent pain severity. A composite of the four pain items (a mean severity score) is sometimes presented as supplemental information. | Antidepressants; Opioids
Center for Disease Control and Prevention health-related quality of life Questionnaire (CDC HRQOL– 4) | 4 item questionnaire to measure General health and the number of recent days when a person was physically unhealthy, mentally unhealthy, or limited in usual activities. | Responses to questions 2 and 3 are combined to calculate a summary index of overall unhealthy days, with a logical maximum of 30 unhealthy days. Healthy days are the positive complementary form of unhealthy days. | Yoga
Chronic Pain Acceptance Questionnaire (CPAQ) | A 20-item inventory measuring acceptance of pain | Two subscales: activity engagement (AE) and pain willingness (PW). Participants rate items on a scale from 0 (never true) to 6 (always true). Higher scores denote greater activity engagement and pain willingness (pain willingness items are reverse scored | Psychological Therapies
Chronic Pain Self Efficacy Scale (PSEQ) | A 10-item questionnaire to assess the confidence people with ongoing pain have in performing activities while in pain. | A 7-point Likert scale (0-6) 0= not at all confident 6= completely confident A total score ranging from 0 to 60 is calculated by adding the scores for each item. Higher score reflect stronger self-efficacy beliefs | Psychological Therapies
Clinical Global Impressions of Severity Scale (CGI-S) | Provides an overall clinician-determined summary measure that takes into account all available information, including a knowledge of the patient's history, psychosocial circumstances, symptoms, behavior, and the impact of the symptoms on the patient's ability to function | Scale: 1-7 Ranging from 1 (normal) to 7 (extremely ill) | Antidepressants
Dallas Pain Questionnaire (DPQ) | Assess the amount of chronic spinal pain that affects four aspects of the patients' lives: Daily activities, work-leisure activities, anxiety-depression, and social interest/ | A 16-item visual analog scale, with each item broken down into 5 to 8 small segments; each item contains its own visual analog scale. Each segment is marked with an ‘x’ by the subject – this indicates where their pain impact falls on that continuum. The scales range from “no pain” or 0%, to “some” pain, to “all the time” and 100% impact of pain. Each item in assigned a value, then individual rating are summed and multiplies bay a constant for a percentage of pain impact for each of the four aspects of the patients' lives. | TENS
EuroQoL (EQ-5D) | Designed for the collection of health state values using a VAS rating scale. It's only distributed in instances where researchers specifically wish to elicit valuations of health. | A vertical 20 cm visual analogue scale with the end points labelled best imaginable health state at the top and worst imaginable health state at the bottom having numeric values of 100 and 0 respectively. | Antidepressants; Antiseizure Medications; Interferential therapy; Opioids; Psychological Therapies
Fear Avoidance Beliefs Questionnaire (FABQ) | Measures patients' fear of pain and consequent avoidance of physical activity because of their fear | This questionnaire consists of 16 items, with 2 subscales, the Work Subscale and the Physical Activity Subscale; each item is scored from 0-6. Higher scores on the FABQ are indicative of greater fear and avoidance beliefs. | Psychological Therapies
Functional Rating Index (FRI) | An instrument specifically designed to quantitatively measure the subjective perception of function and pain of the spinal musculoskeletal system in a clinical environment | A 10-item assessment with a 5 point scale ranked by the patient; 0 = no pain or full ability to function; 4 = worst possible pain and/or unable to perform this function at all. The index score is achieved by simply summing up the equally weighted scores, dividing by the total number of possible points, and multiplying by one hundred percent. The range of scores is zero percent (no disability) to 100% (severe disability). {(total score/40) × 3 100%} | Ultrasound
Geriatric Depression Scale (GDS) | Developed as a basic screening measure for depression in older adults | normal-0-9; mild depressives-10-19; severe depressives-20-30 | PENS
The Hospital Anxiety and Depression Scale (HADS) | Instrument for detecting states of depression and anxiety in the setting of an hospital medical outpatient clinic | There are 14 items; 7 regarding depression and 7 regarding anxiety. Score for each subscale (anxiety and depression) can range from 0-21 with scores categorized as follows: normal (0-7), mild (8-10), moderate (11-14), severe (15-21). Scores for the entire scale (emotional distress) range from 0-42, with higher scores indicating more distress | Antiseizure Medications
Illness Perceptions Questionnaire-Revised (IPQ-R) | An 84-item self-completed instrument developed to provide a quantitative measurement of the components of illness representations, as described by Leventhal's Common-Sense Model (CSM) of self regulation. | Divided into three sections: identity subscale (14 symptoms), causal subscale (18 causes), and a third section which contains 7 subscales, including consequences, timeline acute/chronic and cyclical, personal and treatment control/cure, illness coherence, and emotional representations. For the identity subscale, patients respond by circling ‘yes’ or ‘no’ to each question. For the causal subscale, patients respond to each of the listed causes using a 5-point Likert style scale, ranging from strongly disagree to strongly agree. The third section (7 subscales) is scored by summing responses to each item is on a 5-point Likert style scale, ranging from strongly disagree to strongly agree. All items for each of the subscales are summed to give an overall score. | Psychological Therapies
Isotechnologies B-200 | A computerized isodynamic system providing information about the functional characteristics of the low back | Parameters measured included: Range of motion, isometric torque, and isodynamic velocities in all three major axes. | LLLT
Japanese Orthopedic Association (JOA) | An objective assessment scale quantitating the severity of the spondylotic myelopathy. | Results are scored on a 23 point scale. Total is based on the sum 2 sub scales: ‘Subjective systems’ (0-9); (ADL) Activities of daily living, (0-14). Higher point scores indicate improved symptoms. | Lumbar Supports
Leeds Assessment of Neuropathic Symptoms and Signs (LANSS) | Tool used in identifying patients in whom neuropathic mechanisms dominate their pain experience. | If score < 12, neuropathic mechanisms are unlikely to be contributing to the patient's pain. If score ≥ 12, neuropathic mechanisms are likely to be contributing to the patient's pain | Antiseizure Medications
Low Back Pain Outcome Instrument (LBPOI) | A comprehensive back pain Questionnaire designed to be applicable to a varied population of patients with back pain | 6 summative subscales based on 34 items: back pain, neurogenic symptoms, job exertion, job stress/satisfaction, expectations for treatment, and additionally the Short Form 36 (SF36) mental health subscale Discrete, linear values are calculated for each Subscale. The numeric range of response is 1 through 6. | Electrical Stimulation
McGill Pain Questionnaire Pain Rating Index (MPQ) | consists primarily of 3 major classes of word descriptors--sensory, affective and evaluative--that are used by patients to specify subjective pain experience | (0 to 78) minimum pain score: 0 (would not be seen in a person with true pain) maximum pain score: 78 The higher the pain score the greater the pain | Interferential therapy; PENS; TENS
McGill Pain Questionnaire Pain Rating Index- Short-Form (SF-MPQ) | A self-report measure of pain quality consisting of 15 descriptors of pain, representing both the sensory (e.g., ‘throbbing’, ‘aching’) and affective (e.g., ‘sickening’, ‘fearful’) components of pain quality. Participants are asked to indicate the extent to which each descriptor describes the severity of their pain experience. | Responses are made on a four-point Likert scale, ranging from 0 (none) to 3 (severe). Three subscale scores are calculated: sensory, affective and total pain responses | Antiseizure Medications; Psychological Therapies
Medical Outcome Study Sleep Scale (MOS Sleep Scale) | Measures six dimensions of sleep, including initiation, maintenance, quantity, adequacy, somnolence, and respiratory impairments | Ten of the scale's 12 items are scored using a six-point response scale, one item uses a five-point Likert scale, and sleep quantity is an open-ended question recording the actual number of hours slept. Sleep quantity are recalibrated on a 0–100 scale that represents the percentage of a particular sleep domain; sleep quantity is recorded as 0–24 h. Higher scores for the domains of sleep disturbance, somnolence and the sleep indices indicate worse sleep problems, whereas lower scores for sleep quantity and sleep adequacy indicate worse sleep problems | Antiseizure Medications
Multidimensional Pain Inventory (Pain Severity Scale) | A self-report instrument that measures the impact of pain on an individual's life. Pain Severity Scale, a sub-scale of the Multidimensional Pain Inventory focuses on the average pain the subject has had in the past week and the corresponding Amount of suffering experienced. | Rated on a 7-point scale (0-6). Scale scores are computed by summing over all items and then the mean is composed based on the number of scale items. | PENS
Oswestry disability index (ODI) | A self-administered outcome-measure questionnaire for low back pain in a hospital setting; divided into ten sections designed to assess limitations of various activities of daily living | For each section of six statements the total score is 5; if the first statement is marked the score = 0; if the last statement is marked it = 5. Intervening statements are scored according to rank. If more than one box is marked in each section, take the highest score. If all 10 sections are completed the score is calculated as follows: total scored/ 50 (total possible score) × 100= % | Antiseizure Medications; Electrical Stimulation; Interferential therapy; Opioids; PENS; Taping; Traction; Ultrasound
Pain Disability Index (PDI) | A seven-item self-report measure that assesses disability in seven areas: family, occupation, sexual relations, social activities, recreation, self-care and life support. Participants are asked to indicate their disability in each of the seven areas. | Each of the seven subscales is graded from zero to 10; zero (no disability) to 10 (total disability). A total disability score is determined by summing the numerical ratings of the seven disability scales (range zero to 70). | Acetaminophen; Electrical Stimulation
Pain Self Efficacy Scale (PSEQ) | A 10-item questionnaire to assess the confidence people with ongoing pain have in performing activities while in pain. | A 7-point Likert scale (0-6) 0= not at all confident 6= completely confident A total score ranging from 0 to 60 is calculated by adding the scores for each item. Higher score reflect stronger self-efficacy beliefs | Psychological Therapies
Patient Specific Functional Scale (PSFS) | Patients rate their ability to complete an activity on a 11-point scale at a level experienced prior to injury or change in functional status | mean, 0-10 (0” represents “unable to perform” “10” represents “able to perform at prior level”) | Acetaminophen
Patients' Global Impression (PGIC) | A self-reported measure which reflects a patient's belief about the efficacy of treatment | A 7 point scale depicting a patient's rating of overall improvement. (Patients rate their change as “very much improved,” “much improved,” “minimally improved,” “no change,” “minimally worse,” “much worse,” or “very much worse.”) | Antidepressants
Pittsburgh Sleep Quality Index (PSQI) | An instrument used to measure the quality and patterns of sleep in the older adults. | Based on a 0 to 3 scale, whereby 3 reflects the negative extreme on the Likert Scale. A global sum of “5”or greater indicates a “poor” sleeper | PENS
Profile of Mood States (POMS) | To assess affective mood state fluctuation | Measures six identifiable mood or affective states: 1) Tension-Anxiety 2) Vigor-Activity 3) Depression-Dejection 4) Fatigue-Inertia 5) Anger-Hostility 6) Confusion-Bewilderment; Requires respondents to indicate how well each item describes their mood over the past week using a five-point scale (0-4) ranging from “not at all” to “extremely.” | Antidepressants
Quebec Back Pain disability scale (QBPDS) | A condition-specific questionnaire developed to measure the level of functional disability for patients with low back pain | There are 6 answer categories, measured by using a Likert scale from 0-5 (0 = no effort, 5 = not able to) | Opioids; Psychological Therapies
Roland Morris Back Pain disability questionnaire (RMDQ) | A self-administered disability questionnaire designed for back pain. | A 24 item questionnaire, with and individual's score ranging from 0 (no disability) to 24 (maximum disability). | Acetaminophen; Antidepressants; Antiseizure Medications; Benzodiazepine; Corticosteroids; Interferential therapy; LLLT; Opioids; PENS; Psychological Therapies; Taping; TENS; Traction; Ultrasound;
Schober test | Assesses the amount of lumbar flexion. | A mark is made at the level of the posterior iliac spine on the vertebral column, i.e. approximately at the level of L5. The examiner then places one finger 5cm below this mark and another finger at about 10cm above this mark. The patient is then instructed to touch his toes. If the increase in distance between the two fingers on the patients spine is less than 5cm then this is indicative of a limitation of lumbar flexion. | LLLT
SF12 Mental score (MCS-12) | The SF-12 is a multipurpose short form survey with 12 questions, all selected from the SF-36 Health Survey The questions are combined, scored, and weighted to create two scales that provide glimpses into mental functioning and overall health-related-quality of life | mean, 0-100 (zero score indicates the lowest level of health measured by the scales and 100 indicates the highest level of health) | Acetaminophen
SF12 Physical score (PCS-12) | The SF-12 is a multipurpose short form survey with 12 questions, all selected from the SF-36 Health Survey The questions are combined, scored, and weighted to create two scales that provide glimpses into physical functioning and overall health-related-quality of life | mean, 0-100 (zero score indicates the lowest level of health measured by the scales and 100 indicates the highest level of health) | Acetaminophen
Short Form-36 (SF-36) | 36 item questionnaire which measures Quality of Life (QoL) across eight domains, which are both physically and emotionally based | 0–100 (higher score indicates worse disability) | Antidepressants; Electrical Stimulation; Antidepressants; Electrical Stimulation; Interferential therapy; Opioids; PENS; Psychological Therapies; TENS; Traction; Ultrasound; Yoga
Short Opioid Withdrawal Scale (SOWS) | A 10 item scale as a measure of the opiate withdrawal response. | Four point scale: (0) none to (3) severe. | Opioids
State-trait Anxiety Inventory (STAI) | Measure of trait and state anxiety It can be used to diagnose anxiety and to distinguish it from depressive syndromes. | 20 items for assessing trait anxiety and 20 for state anxiety 4-point scale. Higher score indicates greater anxiety. | Yoga
Swiss Spinal Stenosis Questionnaire (SSS) | A disease-specific self-report outcome instrument designed to complement generic measures of lumbar spine disability and health status in patients with lumbar spinal stenosis. | Symptom severity scale: the range of the scales: 1 to 5 (higher score indicates higher severity) Physical function scale: the range of the scale is 1 to 4 (higher score indicates lower function) Patient's satisfaction with treatment scale: the range of the scale is 1 to 4 (higher score indicates greater dissatisfaction) | Antiseizure Medications
Symptom Checklist-90 | Helps evaluate a broad range of psychological problems and symptoms of psychopathology. The instrument is also useful in measuring patient progress or treatment outcomes | The 90 items in the questionnaire are scored on a five-point Likert scale, indicating the rate of occurrence of the symptom during the time reference. It is intended to measure symptom intensity on nine different subscales | Opioids
Visual Analogue Scale (VAS) | A unidimensional measure of pain intensity. It's a continuous scale comprised of a horizontal (HVAS) or vertical (VVAS) line, usually 10 centimeters (100 mm) in length, anchored by 2 verbal descriptors, one for each symptom extreme. | For pain intensity, the scale is most commonly anchored by “no pain” (score of 0) and “pain as bad as it could be” or “worst imaginable pain” (score of 100 [100-mm scale]) | Antidepressants
Von Korff pain scale | A system for grading chronic pain and chronic disability resulting from different causes | scale 0–100%; lower scores indicate less severe pain or disability | Psychological Therapies