# Detailed Search Strategies

July 9th, 2012

Pubmed search string=14239

((“pulmonary embolism”[mh] OR PE[tiab] OR “Pulmonary embolism”[tiab] OR thromboembolism[mh] OR thromboembolism[tiab] OR thromboembolisms[tiab] OR Thrombosis[mh] OR thrombosis[tiab] OR DVT[tiab] OR VTE[tiab] OR clot[tiab]) AND (Anticoagulants[mh] OR Anticoagulants[tiab] OR Anticoagulant[tiab] OR “thrombin inhibitors”[tiab] OR Aspirin[mh] or aspirin[tiab] OR aspirins[tiab] or clopidogrel[nm] OR clopidogrel[tiab] OR Plavix[tiab] or ticlopidine[mh] or ticlopidine[tiab]OR ticlid[tiab] OR prasugrel[nm]Or prasugrel[tiab]OR effient[tiab]OR ticagrelor[NM] OR ticagrelor[tiab]OR Brilinta[tiab] OR cilostazol[NM] OR cilostazol[tiab]OR pletal[tiab] OR warfarin[mh]OR warfarin[tiab]OR coumadin[tiab] OR coumadine[tiab] OR Dipyridamole[mh]OR dipyridamole[tiab]OR persantine[tiab] OR dicoumarol[MH] OR dicoumarol[tiab] OR dicumarol[tiab] OR Dextran sulfate[mh] OR dextran sulfate[tiab] OR“thrombin inhibitors”[tiab] OR “thrombin inhibitor”[tiab] OR heparin[mh] OR Heparin[tiab] OR Heparins[tiab] OR LMWH[tiab] OR LDUH[tiab] OR Enoxaparin[mh] OR Enoxaparin[tiab] OR Lovenox[tiab] OR Dalteparin[tiab] OR Fragmin[tiab] OR Tinzaparin[tiab] OR innohep[tiab] OR Nadroparin[tiab] OR Fondaparinux[nm] OR Fondaparinux[tiab] OR Arixtra[tiab] OR Idraparinux[nm] OR Idraparinux[tiab] OR Rivaroxaban[nm] OR Rivaroxaban[tiab] OR novastan[tiab] OR Desirudin[nm] OR Desirudin[tiab] OR Iprivask[tiab]OR “direct thrombin inhibitor”[tiab] OR Argatroban[nm] OR Argatroban[tiab] OR Acova[tiab] OR Bivalirudin[nm] OR Bivalirudin[tiab] OR Angiomax[tiab] OR Lepirudin[nm] OR Lepirudin[tiab] OR Refludan[tiab] OR Dabigatran[nm] OR Dabigatran[tiab] OR Pradaxa[tiab] OR “factor xa”[mh] OR “factor Xa”[tiab] OR vena cava filters[mh] OR filters[tiab] OR filter[tiab] OR compression stockings[mh] OR intermittent pneumatic compression devices[mh] OR compression [tiab] OR “Venous foot pump”[tiab])) AND(prevent*[tiab] OR prophyla*[tiab] OR prevention and control[subheading]) NOT (animals[mh] NOT humans[mh]) NOT (editorial[pt] OR comment[pt]) NOT ((infant[mh] OR infant[tiab] OR child[mh] OR child[tiab] OR children[tiab] OR adolescent[mh] OR adolescent[tiab] OR “teen-age”[tiab] OR pediatric[tiab] OR perinatal[tiab]) NOT (adult[tiab] OR adults[tiab] OR adult[mh])) NOT (“mechanical valve”[tiab] OR “heart valve”[tiab] OR “atrial fibrillation”[mh] OR “atrial fibrillation”[tiab] OR thrombophilia[mh] OR thrombophilia[tiab] OR pregnancy[mh])

CINAHL = 2856

International pharmaceutical abstracts = 13337

TX “Pulmonary embolism” OR TX thromboembolism OR TX thromboembolisms OR TX Thrombosis OR TX DVT OR TX VTE OR TX clot

AND

TX Anticoagulants OR TX Anticoagulant OR TX “thrombin inhibitors” OR TX “thrombin inhibitor” OR TX aspirin OR TX aspirins OR TXclopidogrel OR TX Plavix OR TX ticlopidine OR TX ticlid OR TX prasugrel OR TX effient OR TX ticagrelor OR TX Brilinta OR TX cilostazolOR TX pletal OR TX warfarinOR TX coumadin OR TX coumadine OR TX dipyridamoleOR Tx persantine OR TX dicoumarol OR TX dicumarol OR TX dextran sulfate OR TX Heparin OR TX Heparins OR TX LMWH OR TX LDUH OR TX Enoxaparin OR TX Lovenox OR TX Dalteparin OR TX Fragmin OR TX Tinzaparin OR TX innohep OR TX Nadroparin OR TX Fondaparinux OR TX Arixtra OR TX Idraparinux OR TX Rivaroxaban OR TX novastan OR TX Desirudin OR TX Iprivask OR TX “direct thrombin inhibitor” OR TX Argatroban OR TX Acova OR TX Bivalirudin OR TX Angiomax OR TX Lepirudin OR TX Refludan OR TX Dabigatran OR TX Pradaxa OR TX “factor Xa” OR TX vena cava filters OR TX filters OR TX filter OR TX compression stockings OR TX intermittent pneumatic compression devices OR TX compression OR TX “Venous foot pump”TX Anticoagulants OR TX Anticoagulant OR TX “thrombin inhibitors” OR TX “thrombin inhibitor” OR TX Heparin OR TX Heparins OR TX LMWH OR TX LDUH OR TX Enoxaparin OR TX Lovenox OR TX Dalteparin OR TX Fragmin OR TX Tinzaparin OR TX innohep OR TX Nadroparin OR TX Fondaparinux OR TX Arixtra OR TX Idraparinux OR TX Rivaroxaban OR TX novastan OR TX Desirudin OR TX Iprivask OR TX “direct thrombin inhibitor” OR TX Argatroban OR TX Acova OR TX Bivalirudin OR TX Angiomax OR TX Lepirudin OR TX Refludan OR

AND

TX prevent* OR TX prophyla*

EMBASE : 9473

‘thromboembolism’/exp OR ‘pulmonary embolism’:ab,ti OR thromboembolism:ab,ti OR thromboembolisms:ab,ti OR thrombosis:ab,ti OR dvt:ab,ti OR vte:ab,ti OR clot:ab,ti AND (‘thrombin inhibitor’/exp OR aspirin:ab,ti OR aspirins:ab,ti OR clopidogrel:ab,ti OR warfarin:ab,ti OR coumadin:ab,ti OR coumadine:ab,ti OROR heparins:ab,ti OR ‘lmwh’:ab,ti OR lduh:ab,ti OR enoxaparin:ab,ti OR lovenox:ab,ti OR dalteparin:ab,ti OR fragmin:ab,ti OR tinzaparin:ab,ti OR innohep:ab,ti OR nadroparin:ab,ti OR fondaparinux:ab,ti OR arixtra:ab,ti OR idraparinux:ab,ti OR rivaroxaban:ab,ti OR novastan:ab,ti OR desirudin:ab,ti OR iprivask:ab,ti OR ‘direct thrombin inhibitor’:ab,ti OR argatroban:ab,ti OR acova:ab,ti OR bivalirudin:ab,ti OR angiomax:ab,ti OR lepirudin:ab,ti OR refludan:ab,ti OR dabigatran:ab,ti OR pradaxa:ab,ti OR ‘factor xa’:ab,ti OR ‘vena cava filters’:ab,ti OR ‘compression stockings’:ab,ti OR ‘intermittent pneumatic compression devices’:ab,ti OR compression:ab,ti OR ‘venous foot pump’:ab,ti) AND (prevent*:ab,ti OR prophyla*:ab,ti) NOT (‘infant’/exp OR infant:ab,ti OR ‘child’/exp OR child:ab,ti OR children:ab,ti OR ‘adolescent’/exp OR adolescent:ab,ti OR ‘teen-age’:ab,ti OR pediatric:ab,ti OR perinatal:ab,ti NOT (adult:ab,ti OR adults:ab,ti) NOT (‘animal’/exp OR animal:ab,ti NOT (‘human’/exp OR human:ab,ti)) NOT (‘mechanical valve’:ab,ti OR ‘heart valve’:ab,ti OR ‘atrial fibrillation’:ab,ti OR ‘elective knee replacement’:ab,ti OR ‘elective hip replacement’:ab,ti OR thrombophilia:ab,ti OR pregnancy:ab,ti))

Cochrane: 3252

D | Search | Hits | Edit | Delete
#1 | “pulmonary embolism”:ti,ab,kw OR thromboembolism:ti,ab,kw OR thromboembolisms:ti,ab,kw | 3187 | edit | delete
#2 | MeSH descriptor Thromboembolism explode all trees | 1328 | edit | delete
#3 | “pulmonary embolism”:ti,ab,kw OR thromboembolism:ti,ab,kw OR thromboembolisms:ti,ab,kw OR Thrombosis:ti,ab,kw | 7800 | edit | delete
#4 | “pulmonary embolism”:ti,ab,kw OR thromboembolism:ti,ab,kw OR thromboembolisms:ti,ab,kw OR Thrombosis:ti,ab,kw OR DVT:ti,ab,kw | 7863 | edit | delete
#5 | “pulmonary embolism”:ti,ab,kw OR thromboembolism:ti,ab,kw OR thromboembolisms:ti,ab,kw OR Thrombosis:ti,ab,kw OR DVT:ti,ab,kw OR VTE:ti,ab,kw | 7882 | edit | delete
#6 | “pulmonary embolism”:ti,ab,kw OR thromboembolism:ti,ab,kw OR thromboembolisms:ti,ab,kw OR Thrombosis:ti,ab,kw OR DVT:ti,ab,kw OR VTE:ti,ab,kw OR clot:ti,ab,kw | 9505 | edit | delete
#7 | (#2 OR #6) | 9598 | edit | delete
#8 | MeSH descriptor Anticoagulants explode all trees | 7437 | edit | delete
#9 | Anticoagulants:ti,ab,kw | 4323 | edit | delete
#10 | Anticoagulants:ti,ab,kw OR Anticoagulant:ti,ab,kw | 4323 | edit | delete
#11 | Anticoagulants:ti,ab,kw OR Anticoagulant:ti,ab,kw OR “thrombin inhibitors”:ti,ab,kw | 4334 | edit | delete
#12 | Anticoagulants:ti,ab,kw OR Anticoagulant:ti,ab,kw OR “thrombin inhibitors”:ti,ab,kw OR “thrombin inhibitor”:ti,ab,kw | 4441 | edit | delete
#13 | Anticoagulants:ti,ab,kw OR Anticoagulant:ti,ab,kw OR “thrombin inhibitors”:ti,ab,kw OR “thrombin inhibitor”:ti,ab,kw OR heparin:ti,ab,kw | 9205 | edit | delete
#14 | Anticoagulants:ti,ab,kw OR Anticoagulant:ti,ab,kw OR “thrombin inhibitors”:ti,ab,kw OR “thrombin inhibitor”:ti,ab,kw OR heparin:ti,ab,kw OR Heparins:ti,ab,kw | 9267 | edit | delete
#15 | Anticoagulants:ti,ab,kw OR Anticoagulant:ti,ab,kw OR “thrombin inhibitors”:ti,ab,kw OR “thrombin inhibitor”:ti,ab,kw OR heparin:ti,ab,kw OR Heparins:ti,ab,kw OR LMWH:ti,ab,kw | 9293 | edit | delete
#16 | Anticoagulants:ti,ab,kw OR Anticoagulant:ti,ab,kw OR “thrombin inhibitors”:ti,ab,kw OR “thrombin inhibitor”:ti,ab,kw OR heparin:ti,ab,kw OR Heparins:ti,ab,kw OR LMWH:ti,ab,kw OR LDUH:ti,ab,kw | 9293 | edit | delete
#17 | Anticoagulants:ti,ab,kw OR Anticoagulant:ti,ab,kw OR “thrombin inhibitors”:ti,ab,kw OR “thrombin inhibitor”:ti,ab,kw OR heparin:ti,ab,kw OR Heparins:ti,ab,kw OR LMWH:ti,ab,kw OR LDUH:ti,ab,kw OR Enoxaparin:ti,ab,kw | 9484 | edit | delete
#18 | Anticoagulants:ti,ab,kw OR Anticoagulant:ti,ab,kw OR “thrombin inhibitors”:ti,ab,kw OR “thrombin inhibitor”:ti,ab,kw OR heparin:ti,ab,kw OR Heparins:ti,ab,kw OR LMWH:ti,ab,kw OR LDUH:ti,ab,kw OR Enoxaparin:ti,ab,kw OR Lovenox:ti,ab,kw | 9488 | edit | delete
#19 | Anticoagulants:ti,ab,kw OR Anticoagulant:ti,ab,kw OR “thrombin inhibitors”:ti,ab,kw OR “thrombin inhibitor”:ti,ab,kw OR heparin:ti,ab,kw OR Heparins:ti,ab,kw OR LMWH:ti,ab,kw OR LDUH:ti,ab,kw OR Enoxaparin:ti,ab,kw OR Lovenox:ti,ab,kw OR Dalteparin:ti,ab,kw | 9537 | edit | delete
#20 | Anticoagulants:ti,ab,kw OR Anticoagulant:ti,ab,kw OR “thrombin inhibitors”:ti,ab,kw OR “thrombin inhibitor”:ti,ab,kw OR heparin:ti,ab,kw OR Heparins:ti,ab,kw OR LMWH:ti,ab,kw OR LDUH:ti,ab,kw OR Enoxaparin:ti,ab,kw OR Lovenox:ti,ab,kw OR Dalteparin:ti,ab,kw OR Fragmin:ti,ab,kw | 9551 | edit | delete
#21 | Anticoagulants:ti,ab,kw OR Anticoagulant:ti,ab,kw OR “thrombin inhibitors”:ti,ab,kw OR “thrombin inhibitor”:ti,ab,kw OR heparin:ti,ab,kw OR Heparins:ti,ab,kw OR LMWH:ti,ab,kw OR LDUH:ti,ab,kw OR Enoxaparin:ti,ab,kw OR Lovenox:ti,ab,kw OR Dalteparin:ti,ab,kw OR Fragmin:ti,ab,kw OR Tinzaparin:ti,ab,kw | 9582 | edit | delete
#22 | Anticoagulants:ti,ab,kw OR Anticoagulant:ti,ab,kw OR “thrombin inhibitors”:ti,ab,kw OR “thrombin inhibitor”:ti,ab,kw OR heparin:ti,ab,kw OR Heparins:ti,ab,kw OR LMWH:ti,ab,kw OR LDUH:ti,ab,kw OR Enoxaparin:ti,ab,kw OR Lovenox:ti,ab,kw OR Dalteparin:ti,ab,kw OR Fragmin:ti,ab,kw OR Tinzaparin:ti,ab,kw OR innohep:ti,ab,kw | 9582 | edit | delete
#23 | Anticoagulants:ti,ab,kw OR Anticoagulant:ti,ab,kw OR “thrombin inhibitors”:ti,ab,kw OR “thrombin inhibitor”:ti,ab,kw OR heparin:ti,ab,kw OR Heparins:ti,ab,kw OR LMWH:ti,ab,kw OR LDUH:ti,ab,kw OR Enoxaparin:ti,ab,kw OR Lovenox:ti,ab,kw OR Dalteparin:ti,ab,kw OR Fragmin:ti,ab,kw OR Tinzaparin:ti,ab,kw OR innohep:ti,ab,kw OR Nadroparin:ti,ab,kw | 9615 | edit | delete
#24 | Anticoagulants:ti,ab,kw OR Anticoagulant:ti,ab,kw OR “thrombin inhibitors”:ti,ab,kw OR “thrombin inhibitor”:ti,ab,kw OR heparin:ti,ab,kw OR Heparins:ti,ab,kw OR LMWH:ti,ab,kw OR LDUH:ti,ab,kw OR Enoxaparin:ti,ab,kw OR Lovenox:ti,ab,kw OR Dalteparin:ti,ab,kw OR Fragmin:ti,ab,kw OR Tinzaparin:ti,ab,kw OR innohep:ti,ab,kw OR Nadroparin:ti,ab,kw OR Fondaparinux:ti,ab,kw | 9670 | edit | delete
#25 | Anticoagulants:ti,ab,kw OR Anticoagulant:ti,ab,kw OR “thrombin inhibitors”:ti,ab,kw OR “thrombin inhibitor”:ti,ab,kw OR heparin:ti,ab,kw OR Heparins:ti,ab,kw OR LMWH:ti,ab,kw OR LDUH:ti,ab,kw OR Enoxaparin:ti,ab,kw OR Lovenox:ti,ab,kw OR Dalteparin:ti,ab,kw OR Fragmin:ti,ab,kw OR Tinzaparin:ti,ab,kw OR innohep:ti,ab,kw OR Nadroparin:ti,ab,kw OR Fondaparinux:ti,ab,kw OR Arixtra:ti,ab,kw | 9671 | edit | delete
#26 | Anticoagulants:ti,ab,kw OR Anticoagulant:ti,ab,kw OR “thrombin inhibitors”:ti,ab,kw OR “thrombin inhibitor”:ti,ab,kw OR heparin:ti,ab,kw OR Heparins:ti,ab,kw OR LMWH:ti,ab,kw OR LDUH:ti,ab,kw OR Enoxaparin:ti,ab,kw OR Lovenox:ti,ab,kw OR Dalteparin:ti,ab,kw OR Fragmin:ti,ab,kw OR Tinzaparin:ti,ab,kw OR innohep:ti,ab,kw OR Nadroparin:ti,ab,kw OR Fondaparinux:ti,ab,kw OR Arixtra:ti,ab,kw OR Idraparinux:ti,ab,kw | 9679 | edit | delete
#27 | Anticoagulants:ti,ab,kw OR Anticoagulant:ti,ab,kw OR “thrombin inhibitors”:ti,ab,kw OR “thrombin inhibitor”:ti,ab,kw OR heparin:ti,ab,kw OR Heparins:ti,ab,kw OR LMWH:ti,ab,kw OR LDUH:ti,ab,kw OR Enoxaparin:ti,ab,kw OR Lovenox:ti,ab,kw OR Dalteparin:ti,ab,kw OR Fragmin:ti,ab,kw OR Tinzaparin:ti,ab,kw OR innohep:ti,ab,kw OR Nadroparin:ti,ab,kw OR Fondaparinux:ti,ab,kw OR Arixtra:ti,ab,kw OR Idraparinux:ti,ab,kw OR Rivaroxaban:ti,ab,kw | 9708 | edit | delete
#28 | Anticoagulants:ti,ab,kw OR Anticoagulant:ti,ab,kw OR “thrombin inhibitors”:ti,ab,kw OR “thrombin inhibitor”:ti,ab,kw OR heparin:ti,ab,kw OR Heparins:ti,ab,kw OR LMWH:ti,ab,kw OR LDUH:ti,ab,kw OR Enoxaparin:ti,ab,kw OR Lovenox:ti,ab,kw OR Dalteparin:ti,ab,kw OR Fragmin:ti,ab,kw OR Tinzaparin:ti,ab,kw OR innohep:ti,ab,kw OR Nadroparin:ti,ab,kw OR Fondaparinux:ti,ab,kw OR Arixtra:ti,ab,kw OR Idraparinux:ti,ab,kw OR Rivaroxaban:ti,ab,kw OR novastan:ti,ab,kw | 9708 | edit | delete
#29 | Anticoagulants:ti,ab,kw OR Anticoagulant:ti,ab,kw OR “thrombin inhibitors”:ti,ab,kw OR “thrombin inhibitor”:ti,ab,kw OR heparin:ti,ab,kw OR Heparins:ti,ab,kw OR LMWH:ti,ab,kw OR LDUH:ti,ab,kw OR Enoxaparin:ti,ab,kw OR Lovenox:ti,ab,kw OR Dalteparin:ti,ab,kw OR Fragmin:ti,ab,kw OR Tinzaparin:ti,ab,kw OR innohep:ti,ab,kw OR Nadroparin:ti,ab,kw OR Fondaparinux:ti,ab,kw OR Arixtra:ti,ab,kw OR Idraparinux:ti,ab,kw OR Rivaroxaban:ti,ab,kw OR novastan:ti,ab,kw OR Desirudin:ti,ab,kw | 9711 | edit | delete
#30 | Anticoagulants:ti,ab,kw OR Anticoagulant:ti,ab,kw OR “thrombin inhibitors”:ti,ab,kw OR “thrombin inhibitor”:ti,ab,kw OR heparin:ti,ab,kw OR Heparins:ti,ab,kw OR LMWH:ti,ab,kw OR LDUH:ti,ab,kw OR Enoxaparin:ti,ab,kw OR Lovenox:ti,ab,kw OR Dalteparin:ti,ab,kw OR Fragmin:ti,ab,kw OR Tinzaparin:ti,ab,kw OR innohep:ti,ab,kw OR Nadroparin:ti,ab,kw OR Fondaparinux:ti,ab,kw OR Arixtra:ti,ab,kw OR Idraparinux:ti,ab,kw OR Rivaroxaban:ti,ab,kw OR novastan:ti,ab,kw OR Desirudin:ti,ab,kw OR Iprivask:ti,ab,kw | 9711 | edit | delete
#31 | Anticoagulants:ti,ab,kw OR Anticoagulant:ti,ab,kw OR “thrombin inhibitors”:ti,ab,kw OR “thrombin inhibitor”:ti,ab,kw OR heparin:ti,ab,kw OR Heparins:ti,ab,kw OR LMWH:ti,ab,kw OR LDUH:ti,ab,kw OR Enoxaparin:ti,ab,kw OR Lovenox:ti,ab,kw OR Dalteparin:ti,ab,kw OR Fragmin:ti,ab,kw OR Tinzaparin:ti,ab,kw OR innohep:ti,ab,kw OR Nadroparin:ti,ab,kw OR Fondaparinux:ti,ab,kw OR Arixtra:ti,ab,kw OR Idraparinux:ti,ab,kw OR Rivaroxaban:ti,ab,kw OR novastan:ti,ab,kw OR Desirudin:ti,ab,kw OR Iprivask:ti,ab,kw OR “direct thrombin inhibitor”:ti,ab,kw | 9711 | edit | delete
#32 | Anticoagulants:ti,ab,kw OR Anticoagulant:ti,ab,kw OR “thrombin inhibitors”:ti,ab,kw OR “thrombin inhibitor”:ti,ab,kw OR heparin:ti,ab,kw OR Heparins:ti,ab,kw OR LMWH:ti,ab,kw OR LDUH:ti,ab,kw OR Enoxaparin:ti,ab,kw OR Lovenox:ti,ab,kw OR Dalteparin:ti,ab,kw OR Fragmin:ti,ab,kw OR Tinzaparin:ti,ab,kw OR innohep:ti,ab,kw OR Nadroparin:ti,ab,kw OR Fondaparinux:ti,ab,kw OR Arixtra:ti,ab,kw OR Idraparinux:ti,ab,kw OR Rivaroxaban:ti,ab,kw OR novastan:ti,ab,kw OR Desirudin:ti,ab,kw OR Iprivask:ti,ab,kw OR “direct thrombin inhibitor”:ti,ab,kw OR Argatroban:ti,ab,kw | 9732 | edit | delete
#33 | Anticoagulants:ti,ab,kw OR Anticoagulant:ti,ab,kw OR “thrombin inhibitors”:ti,ab,kw OR “thrombin inhibitor”:ti,ab,kw OR heparin:ti,ab,kw OR Heparins:ti,ab,kw OR LMWH:ti,ab,kw OR LDUH:ti,ab,kw OR Enoxaparin:ti,ab,kw OR Lovenox:ti,ab,kw OR Dalteparin:ti,ab,kw OR Fragmin:ti,ab,kw OR Tinzaparin:ti,ab,kw OR innohep:ti,ab,kw OR Nadroparin:ti,ab,kw OR Fondaparinux:ti,ab,kw OR Arixtra:ti,ab,kw OR Idraparinux:ti,ab,kw OR Rivaroxaban:ti,ab,kw OR novastan:ti,ab,kw OR Desirudin:ti,ab,kw OR Iprivask:ti,ab,kw OR “direct thrombin inhibitor”:ti,ab,kw OR Argatroban:ti,ab,kw OR Acova:ti,ab,kw | 9733 | edit | delete
#34 | Anticoagulants:ti,ab,kw OR Anticoagulant:ti,ab,kw OR “thrombin inhibitors”:ti,ab,kw OR “thrombin inhibitor”:ti,ab,kw OR heparin:ti,ab,kw OR Heparins:ti,ab,kw OR LMWH:ti,ab,kw OR LDUH:ti,ab,kw OR Enoxaparin:ti,ab,kw OR Lovenox:ti,ab,kw OR Dalteparin:ti,ab,kw OR Fragmin:ti,ab,kw OR Tinzaparin:ti,ab,kw OR innohep:ti,ab,kw OR Nadroparin:ti,ab,kw OR Fondaparinux:ti,ab,kw OR Arixtra:ti,ab,kw OR Idraparinux:ti,ab,kw OR Rivaroxaban:ti,ab,kw OR novastan:ti,ab,kw OR Desirudin:ti,ab,kw OR Iprivask:ti,ab,kw OR “direct thrombin inhibitor”:ti,ab,kw OR Argatroban:ti,ab,kw OR Acova:ti,ab,kw OR Bivalirudin:ti,ab,kw | 9740 | edit | delete
#35 | Anticoagulants:ti,ab,kw OR Anticoagulant:ti,ab,kw OR “thrombin inhibitors”:ti,ab,kw OR “thrombin inhibitor”:ti,ab,kw OR heparin:ti,ab,kw OR Heparins:ti,ab,kw OR LMWH:ti,ab,kw OR LDUH:ti,ab,kw OR Enoxaparin:ti,ab,kw OR Lovenox:ti,ab,kw OR Dalteparin:ti,ab,kw OR Fragmin:ti,ab,kw OR Tinzaparin:ti,ab,kw OR innohep:ti,ab,kw OR Nadroparin:ti,ab,kw OR Fondaparinux:ti,ab,kw OR Arixtra:ti,ab,kw OR Idraparinux:ti,ab,kw OR Rivaroxaban:ti,ab,kw OR novastan:ti,ab,kw OR Desirudin:ti,ab,kw OR Iprivask:ti,ab,kw OR “direct thrombin inhibitor”:ti,ab,kw OR Argatroban:ti,ab,kw OR Acova:ti,ab,kw OR Bivalirudin:ti,ab,kw OR Angiomax:ti,ab,kw | 9743 | edit | delete
#36 | Anticoagulants:ti,ab,kw OR Anticoagulant:ti,ab,kw OR “thrombin inhibitors”:ti,ab,kw OR “thrombin inhibitor”:ti,ab,kw OR heparin:ti,ab,kw OR Heparins:ti,ab,kw OR LMWH:ti,ab,kw OR LDUH:ti,ab,kw OR Enoxaparin:ti,ab,kw OR Lovenox:ti,ab,kw OR Dalteparin:ti,ab,kw OR Fragmin:ti,ab,kw OR Tinzaparin:ti,ab,kw OR innohep:ti,ab,kw OR Nadroparin:ti,ab,kw OR Fondaparinux:ti,ab,kw OR Arixtra:ti,ab,kw OR Idraparinux:ti,ab,kw OR Rivaroxaban:ti,ab,kw OR novastan:ti,ab,kw OR Desirudin:ti,ab,kw OR Iprivask:ti,ab,kw OR “direct thrombin inhibitor”:ti,ab,kw OR Argatroban:ti,ab,kw OR Acova:ti,ab,kw OR Bivalirudin:ti,ab,kw OR Angiomax:ti,ab,kw OR Lepirudin:ti,ab,kw | 9745 | edit | delete
#37 | Anticoagulants:ti,ab,kw OR Anticoagulant:ti,ab,kw OR “thrombin inhibitors”:ti,ab,kw OR “thrombin inhibitor”:ti,ab,kw OR heparin:ti,ab,kw OR Heparins:ti,ab,kw OR LMWH:ti,ab,kw OR LDUH:ti,ab,kw OR Enoxaparin:ti,ab,kw OR Lovenox:ti,ab,kw OR Dalteparin:ti,ab,kw OR Fragmin:ti,ab,kw OR Tinzaparin:ti,ab,kw OR innohep:ti,ab,kw OR Nadroparin:ti,ab,kw OR Fondaparinux:ti,ab,kw OR Arixtra:ti,ab,kw OR Idraparinux:ti,ab,kw OR Rivaroxaban:ti,ab,kw OR novastan:ti,ab,kw OR Desirudin:ti,ab,kw OR Iprivask:ti,ab,kw OR “direct thrombin inhibitor”:ti,ab,kw OR Argatroban:ti,ab,kw OR Acova:ti,ab,kw OR Bivalirudin:ti,ab,kw OR Angiomax:ti,ab,kw OR Lepirudin:ti,ab,kw OR Refludan:ti,ab,kw | 9745 | edit | delete
#38 | Anticoagulants:ti,ab,kw OR Anticoagulant:ti,ab,kw OR “thrombin inhibitors”:ti,ab,kw OR “thrombin inhibitor”:ti,ab,kw OR heparin:ti,ab,kw OR Heparins:ti,ab,kw OR LMWH:ti,ab,kw OR LDUH:ti,ab,kw OR Enoxaparin:ti,ab,kw OR Lovenox:ti,ab,kw OR Dalteparin:ti,ab,kw OR Fragmin:ti,ab,kw OR Tinzaparin:ti,ab,kw OR innohep:ti,ab,kw OR Nadroparin:ti,ab,kw OR Fondaparinux:ti,ab,kw OR Arixtra:ti,ab,kw OR Idraparinux:ti,ab,kw OR Rivaroxaban:ti,ab,kw OR novastan:ti,ab,kw OR Desirudin:ti,ab,kw OR Iprivask:ti,ab,kw OR “direct thrombin inhibitor”:ti,ab,kw OR Argatroban:ti,ab,kw OR Acova:ti,ab,kw OR Bivalirudin:ti,ab,kw OR Angiomax:ti,ab,kw OR Lepirudin:ti,ab,kw OR Refludan:ti,ab,kw OR Dabigatran:ti,ab,kw | 9762 | edit | delete
#39 | Anticoagulants:ti,ab,kw OR Anticoagulant:ti,ab,kw OR “thrombin inhibitors”:ti,ab,kw OR “thrombin inhibitor”:ti,ab,kw OR heparin:ti,ab,kw OR Heparins:ti,ab,kw OR LMWH:ti,ab,kw OR LDUH:ti,ab,kw OR Enoxaparin:ti,ab,kw OR Lovenox:ti,ab,kw OR Dalteparin:ti,ab,kw OR Fragmin:ti,ab,kw OR Tinzaparin:ti,ab,kw OR innohep:ti,ab,kw OR Nadroparin:ti,ab,kw OR Fondaparinux:ti,ab,kw OR Arixtra:ti,ab,kw OR Idraparinux:ti,ab,kw OR Rivaroxaban:ti,ab,kw OR novastan:ti,ab,kw OR Desirudin:ti,ab,kw OR Iprivask:ti,ab,kw OR “direct thrombin inhibitor”:ti,ab,kw OR Argatroban:ti,ab,kw OR Acova:ti,ab,kw OR Bivalirudin:ti,ab,kw OR Angiomax:ti,ab,kw OR Lepirudin:ti,ab,kw OR Refludan:ti,ab,kw OR Dabigatran:ti,ab,kw OR Pradaxa:ti,ab,kw | 9762 | edit | delete
#40 | Anticoagulants:ti,ab,kw OR Anticoagulant:ti,ab,kw OR “thrombin inhibitors”:ti,ab,kw OR “thrombin inhibitor”:ti,ab,kw OR heparin:ti,ab,kw OR Heparins:ti,ab,kw OR LMWH:ti,ab,kw OR LDUH:ti,ab,kw OR Enoxaparin:ti,ab,kw OR Lovenox:ti,ab,kw OR Dalteparin:ti,ab,kw OR Fragmin:ti,ab,kw OR Tinzaparin:ti,ab,kw OR innohep:ti,ab,kw OR Nadroparin:ti,ab,kw OR Fondaparinux:ti,ab,kw OR Arixtra:ti,ab,kw OR Idraparinux:ti,ab,kw OR Rivaroxaban:ti,ab,kw OR novastan:ti,ab,kw OR Desirudin:ti,ab,kw OR Iprivask:ti,ab,kw OR “direct thrombin inhibitor”:ti,ab,kw OR Argatroban:ti,ab,kw OR Acova:ti,ab,kw OR Bivalirudin:ti,ab,kw OR Angiomax:ti,ab,kw OR Lepirudin:ti,ab,kw OR Refludan:ti,ab,kw OR Dabigatran:ti,ab,kw OR Pradaxa:ti,ab,kw OR “factor xa”:ti,ab,kw | 9808 | edit | delete
#41 | Anticoagulants:ti,ab,kw OR Anticoagulant:ti,ab,kw OR “thrombin inhibitors”:ti,ab,kw OR “thrombin inhibitor”:ti,ab,kw OR heparin:ti,ab,kw OR Heparins:ti,ab,kw OR LMWH:ti,ab,kw OR LDUH:ti,ab,kw OR Enoxaparin:ti,ab,kw OR Lovenox:ti,ab,kw OR Dalteparin:ti,ab,kw OR Fragmin:ti,ab,kw OR Tinzaparin:ti,ab,kw OR innohep:ti,ab,kw OR Nadroparin:ti,ab,kw OR Fondaparinux:ti,ab,kw OR Arixtra:ti,ab,kw OR Idraparinux:ti,ab,kw OR Rivaroxaban:ti,ab,kw OR novastan:ti,ab,kw OR Desirudin:ti,ab,kw OR Iprivask:ti,ab,kw OR “direct thrombin inhibitor”:ti,ab,kw OR Argatroban:ti,ab,kw OR Acova:ti,ab,kw OR Bivalirudin:ti,ab,kw OR Angiomax:ti,ab,kw OR Lepirudin:ti,ab,kw OR Refludan:ti,ab,kw OR Dabigatran:ti,ab,kw OR Pradaxa:ti,ab,kw OR “factor xa”:ti,ab,kw OR “vena cava filters”:ti,ab,kw | 9822 | edit | delete
#42 | Anticoagulants:ti,ab,kw OR Anticoagulant:ti,ab,kw OR “thrombin inhibitors”:ti,ab,kw OR “thrombin inhibitor”:ti,ab,kw OR heparin:ti,ab,kw OR Heparins:ti,ab,kw OR LMWH:ti,ab,kw OR LDUH:ti,ab,kw OR Enoxaparin:ti,ab,kw OR Lovenox:ti,ab,kw OR Dalteparin:ti,ab,kw OR Fragmin:ti,ab,kw OR Tinzaparin:ti,ab,kw OR innohep:ti,ab,kw OR Nadroparin:ti,ab,kw OR Fondaparinux:ti,ab,kw OR Arixtra:ti,ab,kw OR Idraparinux:ti,ab,kw OR Rivaroxaban:ti,ab,kw OR novastan:ti,ab,kw OR Desirudin:ti,ab,kw OR Iprivask:ti,ab,kw OR “direct thrombin inhibitor”:ti,ab,kw OR Argatroban:ti,ab,kw OR Acova:ti,ab,kw OR Bivalirudin:ti,ab,kw OR Angiomax:ti,ab,kw OR Lepirudin:ti,ab,kw OR Refludan:ti,ab,kw OR Dabigatran:ti,ab,kw OR Pradaxa:ti,ab,kw OR “factor xa”:ti,ab,kw OR “vena cava filters”:ti,ab,kw OR filters:ti,ab,kw | 11706 | edit | delete
#43 | Anticoagulants:ti,ab,kw OR Anticoagulant:ti,ab,kw OR “thrombin inhibitors”:ti,ab,kw OR “thrombin inhibitor”:ti,ab,kw OR heparin:ti,ab,kw OR Heparins:ti,ab,kw OR LMWH:ti,ab,kw OR LDUH:ti,ab,kw OR Enoxaparin:ti,ab,kw OR Lovenox:ti,ab,kw OR Dalteparin:ti,ab,kw OR Fragmin:ti,ab,kw OR Tinzaparin:ti,ab,kw OR innohep:ti,ab,kw OR Nadroparin:ti,ab,kw OR Fondaparinux:ti,ab,kw OR Arixtra:ti,ab,kw OR Idraparinux:ti,ab,kw OR Rivaroxaban:ti,ab,kw OR novastan:ti,ab,kw OR Desirudin:ti,ab,kw OR Iprivask:ti,ab,kw OR “direct thrombin inhibitor”:ti,ab,kw OR Argatroban:ti,ab,kw OR Acova:ti,ab,kw OR Bivalirudin:ti,ab,kw OR Angiomax:ti,ab,kw OR Lepirudin:ti,ab,kw OR Refludan:ti,ab,kw OR Dabigatran:ti,ab,kw OR Pradaxa:ti,ab,kw OR “factor xa”:ti,ab,kw OR “vena cava filters”:ti,ab,kw OR filters:ti,ab,kw OR “compression stockings”:ti,ab,kw | 11914 | edit | delete
#44 | Anticoagulants:ti,ab,kw OR Anticoagulant:ti,ab,kw OR “thrombin inhibitors”:ti,ab,kw OR “thrombin inhibitor”:ti,ab,kw OR heparin:ti,ab,kw OR Heparins:ti,ab,kw OR LMWH:ti,ab,kw OR LDUH:ti,ab,kw OR Enoxaparin:ti,ab,kw OR Lovenox:ti,ab,kw OR Dalteparin:ti,ab,kw OR Fragmin:ti,ab,kw OR Tinzaparin:ti,ab,kw OR innohep:ti,ab,kw OR Nadroparin:ti,ab,kw OR Fondaparinux:ti,ab,kw OR Arixtra:ti,ab,kw OR Idraparinux:ti,ab,kw OR Rivaroxaban:ti,ab,kw OR novastan:ti,ab,kw OR Desirudin:ti,ab,kw OR Iprivask:ti,ab,kw OR “direct thrombin inhibitor”:ti,ab,kw OR Argatroban:ti,ab,kw OR Acova:ti,ab,kw OR Bivalirudin:ti,ab,kw OR Angiomax:ti,ab,kw OR Lepirudin:ti,ab,kw OR Refludan:ti,ab,kw OR Dabigatran:ti,ab,kw OR Pradaxa:ti,ab,kw OR “factor xa”:ti,ab,kw OR “vena cava filters”:ti,ab,kw OR filters:ti,ab,kw OR “compression stockings”:ti,ab,kw OR “intermittent pneumatic compression devices”:ti,ab,kw | 11970 | edit | delete
#45 | Anticoagulants:ti,ab,kw OR Anticoagulant:ti,ab,kw OR “thrombin inhibitors”:ti,ab,kw OR Aspirin:ti, ab, kw OR aspirins:ti, ab, kw OR clopidogreal:ti, ab, kw OR warfarin: ti, ab, kw OR coumadin: ti, ab, kw OR coumadina:ti, ab, kw OR “thrombin inhibitor”:ti,ab,kw OR heparin:ti,ab,kw OR Heparins:ti,ab,kw OR LMWH:ti,ab,kw OR LDUH:ti,ab,kw OR Enoxaparin:ti,ab,kw OR Lovenox:ti,ab,kw OR Dalteparin:ti,ab,kw OR Fragmin:ti,ab,kw OR Tinzaparin:ti,ab,kw OR innohep:ti,ab,kw OR Nadroparin:ti,ab,kw OR Fondaparinux:ti,ab,kw OR Arixtra:ti,ab,kw OR Idraparinux:ti,ab,kw OR Rivaroxaban:ti,ab,kw OR novastan:ti,ab,kw OR Desirudin:ti,ab,kw OR Iprivask:ti,ab,kw OR “direct thrombin inhibitor”:ti,ab,kw OR Argatroban:ti,ab,kw OR Acova:ti,ab,kw OR Bivalirudin:ti,ab,kw OR Angiomax:ti,ab,kw OR Lepirudin:ti,ab,kw OR Refludan:ti,ab,kw OR Dabigatran:ti,ab,kw OR Pradaxa:ti,ab,kw OR “factor xa”:ti,ab,kw OR “vena cava filters”:ti,ab,kw OR filters:ti,ab,kw OR “compression stockings”:ti,ab,kw OR “intermittent pneumatic compression devices”:ti,ab,kw OR compression:ti,ab,kw OR “Venous foot pump”:ti,ab,kw | 14236 | edit | delete
#46 | (#8 OR #45) | 16191 | edit | delete
#47 | prevent*:ti,ab,kw OR prophyla*:ti,ab,kw | 103114 | edit | delete
#48 | (#7 AND #46 AND #47) | 3120 | edit | delete

Scopus 5513

(TITLE-ABS-KEY(“pulmonary embolism”) OR TITLE-ABS-KEY(thromboembolism) OR TITLE-ABS-KEY(thromboembolisms) OR TITLE-ABS-KEY(thrombosis) OR TITLE-ABS-KEY(dvt) OR TITLE-ABS-KEY(“VTE”) OR TITLE-ABS-KEY(clot)) AND (TITLE-ABS-KEY(anticoagulants) OR TITLE-ABS-KEY(anticoagulant) OR TITLE-ABS-KEY(“thrombin inhibitors”) OR TITLE-ABS-KEY(“thrombin inhibitor”) OR TITLE-ABS-KEY(Aspirin) OR TITLE-ABS-KEY(clopidogrel) OR TITLE-ABS-KEY(ticlopidine) OR TITLE-ABS-KEY(prasugrel) TITLE-ABS-KEY(warfarin) OR TITLE-ABS-KEY(coumadin) TITLE-ABS-KEY(coumadine) OR TITLE-ABS-KEY(heparin) OR TITLE-ABS-KEY(heparins) OR TITLE-ABS-KEY(“LMWH”) OR TITLE-ABS-KEY(“LDUH”) OR TITLE-ABS-KEY(enoxaparin) OR TITLE-ABS-KEY(lovenox) OR TITLE-ABS-KEY(dalteparin) OR TITLE-ABS-KEY(fragmin) OR TITLE-ABS-KEY(tinzaparin) OR TITLE-ABS-KEY(innohep) OR TITLE-ABS-KEY(nadroparin) OR TITLE-ABS-KEY(fondaparinux) OR TITLE-ABS-KEY(arixtra) OR TITLE-ABS-KEY(idraparinux) OR TITLE-ABS-KEY(rivaroxaban) OR TITLE-ABS-KEY(novastan) OR TITLE-ABS-KEY(desirudin) OR TITLE-ABS-KEY(iprivask) OR TITLE-ABS-KEY(“direct thrombin inhibitor ”)OR TITLE-ABS-KEY(Argatroban)OR TITLE-ABS-KEY(Acova)OR TITLE-ABS-KEY(Bivalirudin)OR TITLE-ABS-KEY(Angiomax)OR TITLE-ABS-KEY(Lepirudin)OR TITLE-ABS-KEY(Refludan)OR TITLE-ABS-KEY(Dabigatran)OR TITLE-ABS-KEY(Pradaxa)OR TITLE-ABS-KEY(“factor xa”)OR TITLE-ABS-KEY(“ vena cava filters ”)OR TITLE-ABS-KEY(filters)OR TITLE-ABS-KEY(filter)OR TITLE-ABS-KEY(“ compression stockings ”)OR TITLE-ABS-KEY(“ intermittent pneumatic compression devices ”) OR TITLE-ABS-KEY(compression)OR TITLE-ABS-KEY(“Venous foot pump”)) AND (TITLE-ABS-KEY(prevent*) OR TITLE-ABS-KEY(prophyla*))