# Screening and Data Abstraction Forms

This is the title review form, one of the standardized forms for data abstraction. It asks whether an article title potentially applies to any of the Key Questions. This is the abstract review form for articles not selected. It is one of the standardized forms for data abstraction. It asks reviewers to select yes, no, or unclear for whether an article abstract potentially applies to any of the Key Questions. If not, the reviewer is asked to pick from seven reasons. The form also asks if the article is written in a language other than English. This is the abstract review form for articles selected. It is one of the standardized forms for data abstraction. It asks reviewers to select yes, no, or unclear for whether an article abstract potentially applies to any of the Key Questions. The form also asks if the article is written in a language other than English. This is the article review form for articles not selected. It asks reviewers to select yes, no, or unclear for whether an article abstract applies to any of the Key Questions. If not, the reviewer is asked to pick from nine reasons. For excluded articles, the reviewer is asked to check a box, “flag article for report writing.” This is the article review form for articles selected. It asks reviewers to select yes, no, or unclear for whether an article abstract applies to any of the Key Questions. If yes, the reviewer is asked to identify which Key Questions the article applies to. This is the intervention characteristics form for articles not selected. It asks reviewers to pick from 11 study interventions and to check yes or no for concurrent standard therapies/interventions. The form also lists the five arms. This is the intervention characteristics form for articles selected. It asks reviewers to pick from 11 study interventions and to check yes or no for concurrent standard therapies/interventions. The form also lists the five arms. This is the study characteristics form. It asks 11 questions about the study and asks for inclusion and exclusion criteria for 24 populations. This is the participant characteristic form. It asks 106 questions. This is the primary outcomes form. This is the secondary outcomes form. It asks 103 questions. This is the adverse outcomes form. This is the risk of bias form. It contains several checklists.