# Acronyms and Abbreviations

AIS: Abbreviated Injury Scale
BMI: Body Mass Index
CAT: Computed Axial Tomography
CT: Computed Tomography
CTA: Computed Tomography Angiography
CUS: Compression Ultrasonography
DVT: Deep Vein Thrombosis
GCS: Glasgow Coma Scale
Hr(s): Hour(s)
ICU: Intensive Care Unit
INR: International Normalized Ratio
IPG: Impedance Phlebography
ISS: Injury Severity Score
IVC: Inferior Vena Cava
IVCF: Inferior Vena Cava Filter
LE: Lower Extremity
LMWH: Low Molecular Weight Heparin
Mg: Milligram
NIH: National Institutes of Health
NR: Not Reported
PE: Pulmonary Embolism
P-IVCF: Prophylactic Inferior Vena Cava Filter
RCT: Randomized Controlled Trial
R-IVCF: Retrievable Inferior Vena Cava Filter
RYGB: Roux-en-Y gastric bypass
SCD: Sequential Compression Device
SCI: Spinal Cord Injury
SQ: Subcutaneous
TBI: Traumatic Brain Injury
UFH: Unfractionated Heparin
USS: Ultrasound Scan
U: Units
VCF: Vena Cava Filter
V/Q Scan: Ventilation Perfusion Scan
VTE: Venous Thromboembolism