# An Implementation Guide for Behavioral Health Program Administrators

1 Part 2, Chapter 1

2 Part 2, Chapter 2