# Part 2, Chapter 2

## Introduction

A variety of materials can be found online to assist behavioral health service providers who use technology in their practice and to help clients use technology to support their recovery. This chapter includes selected resources for providers and administrators who are implementing technology-assisted care (TAC). The materials included in this chapter are intended for modification based on the unique context, service design, and staffing configurations of a given program or organization; they are only a small sampling of the wide array of resources available.

In exploring TAC implementation opportunities, understanding the various TAC-specific terms you may encounter is key; the glossary in Exhibit 2.2-1 is by no means exhaustive, but it does cover most common terms.

Exhibit 2.2-1 Glossary of Common Technology Terms

Application (app) | A software program that runs on a computer, tablet, or mobile phone.
Asynchronous communication | Communication that, once sent, can be responded to later. For example, email allows recipients to respond whenever they wish, whereas synchronous communication requires sender and recipient to communicate at the same time, often back and forth, as in a phone conversation. Email can be considerably slower than text messaging, but some consumers may be more comfortable with a slower form of communication. Younger clients are often more experienced with texting and prefer the more rapid communication exchange that is possible via this medium, as do many others of any age who are familiar with texting.
Authentication | Some form of verifying the user of a given technology, such as through a password, key code, thumbprint, retinal scan, or photo likeness.
Avatar | An icon, picture, character, or graphic that represents a person's online identity. Avatars allow people to portray online identities without revealing their real images.
Bandwidth | The capacity of the transmission connection. Large bandwidth allows more information to be sent in less time.
Blog | Written thoughts, links, opinions, and commentaries posted on a Web site.
Broadband | Bandwidth adequate to transmit high-quality audiovisual data.
Chat | Online communication that occurs in real time; includes chat rooms, where people (usually several individuals) exchange dialog, as well as instant messaging (usually involving just two people).
Desktop | The first display you see on a computer after the startup is completed. It is often a background or wallpaper where icons of files and programs are saved.
Desktop computer | A personal computer (PC) to be used in one location, as compared with a laptop or portable computer, which is meant to be carried around and used in many locations.
Domain | The last two parts of an email or Web address that show the organization's name, such as “gmail.com” or “SAMHSA.gov.”
Encryption | Encoding data on an email or Web page so it has to be decoded by the person or system that is authorized to see it.
Firewall | Hardware or software that prevents unauthorized access to a computer network.
Frame relay | The streamlined process of sending and receiving data.
Malware | A program loaded on a computer system to compromise the confidentiality or integrity of the data, applications, or operating system of the computer.
Network | A set of locations, points, or computers connected for information exchanges.
POTS | Plain Old Telephone System or landline (versus a mobile, or cellular, phone system).
Real time | A form of sharing data or communicating where there is no perceivable delay between the time something is sent and the time it is received.
Redundant | A backup approach to data processing or communications to ensure that even when one critical element of the system fails, the system continues to operate.
Smartphone | A mobile telephone that can do more than make phone calls or send text messages. Smartphones often can send and receive email, access the Internet, display photos, and play videos.
Social media or networking | Web sites (e.g., Facebook, Google+, LinkedIn) that allow people to create Web pages with personal information and exchange messages with others.
Store-and-forward | Transmission of images or audio clips to a storage device where a behavioral health service provider can view them, thus reducing the bandwidth required.
Synchronous communication | Communication where there is no lapse between the time the sender communicates something and the receiver gets the message, allowing the participants to communicate in real time.
Tablet | A small, lightweight computer that often uses a touchscreen instead of a keyboard.
Teleconferencing | Interactive communication among multiple users at different sites; can include voice, video, and data.
Telehealth | Use of electronic information and telecommunications to support long-distance clinical healthcare, health-related client and professional education, public health, and health administration.
Telemedicine | The exchange of medical information from one site to another through electronic communications to improve clients' clinical health status; can sometimes be used as a synonym for telehealth.
Text message (SMS) | Brief message typed in a phone or other handheld device that is sent by wireless telephone to another user.
Tweet | Brief online posting distributed to a group of users that are registered as followers of a particular person's tweets.
Twitter | An online service that manages subscribers' tweets.
Uniform resource locator (URL) | An Internet address.
Video conferencing | Real-time, two-way transmission of video images across multiple locations.
Videophone | These types of phones include an imaging device that lets the caller and receiver view each other, as on a television.

## Tools for Clinicians

### Written Statements To Communicate or Elicit Emotional Responses

Relying on written words to express emotion is quite different from having in-person exchanges, but written exchanges can be particularly useful for specific types of people or circumstances (Anthony, Nagel, & Goss, 2010). In particular, people who have previously experienced discrimination, who have service access barriers, or who are concerned about preserving the anonymity of their participation in treatment can benefit from counseling and support that relies on the written word rather than in-person exchanges. Nonetheless, providing clinical services via the written word presents challenges for counselors and clients. Exhibit 2.2-2 shows how a counselor might phrase questions to elicit particular responses or communicate a collaborative and accepting attitude to a client. For additional discussion of research (Simon et al., 2011) related to online text messages in a trial of depression treatment follow-up, see Part 1, Chapter 2, as well as the online-only literature review in Part 3 of this Treatment Improvement Protocol.

Exhibit 2.2-2 Statements To Elicit Responses From Online Clients

Expressing empathy | Obtaining permission | Normalizing
- How sad.; - That is terrible.; - What an incredible ordeal. | - Is it okay if I ask you some questions about…?; - Are you up to some questions now? | - Often it is hard to…; - Often it is hard not to…; - It is okay if you…
Restating | Nurturing collaboration | Eliciting commitment
- Correct me if I'm wrong…; - I get the impression that…; - I sense that you… | - Do you think it would be advisable to…?; - As we have both said… | - What are one or two things that you should do first?; - How would you know if the effort was worth it?; - So are you saying that you are willing to try doing ______?
Promoting credit for change | Emphasizing strengths and nurturing hope | - What are one or two things that you should do first?; - How would you know if the effort was worth it?; - So are you saying that you are willing to try doing ______?
- How were things different this time than they were last time?; - What do you think accounts for the change?; - What, if anything, did you do differently this time? | - Somehow you got past the obstacle of… Is that correct?; - What allowed you to…in spite of…?; - How did you do that? | - What are one or two things that you should do first?; - How would you know if the effort was worth it?; - So are you saying that you are willing to try doing ______?
- How were things different this time than they were last time?; - What do you think accounts for the change?; - What, if anything, did you do differently this time? | - Somehow you got past the obstacle of… Is that correct?; - What allowed you to…in spite of…?; - How did you do that? | Assisting with goals
- How were things different this time than they were last time?; - What do you think accounts for the change?; - What, if anything, did you do differently this time? | - Somehow you got past the obstacle of… Is that correct?; - What allowed you to…in spite of…?; - How did you do that? | - Does your goal seem realistic? Should you establish subgoals?; - Of your goals, which one should you begin with? How should you choose?; - How can you go about achieving these goals?; - Do you have a plan? Do you need help?
- How were things different this time than they were last time?; - What do you think accounts for the change?; - What, if anything, did you do differently this time? | Gathering more information
Enhancing motivation | - In order to understand your situation, I would like to ask you some questions.; - Can you describe the situation you are in now?; - How often does this behavior occur?; - What else should I know about you and your situation to help you with this problem?
- What is different when the problem is manageable?; - How would you like things to be different?; - Of the things we have discussed, which are the most important reasons to change?

### Text-Based Communication Shortcuts

The use of emoticons and acronyms is not recommended for behavioral health service providers because of the risk of misinterpretation and the blurring of professional and personal relationship boundaries. However, providers engaged in text-based client communication should understand some common emoticons and acronyms that their clients may use. Exhibit 2.2-3 lists some of the more common emoticons and acronyms used in text-based communication. Providers should verify the meaning of communications from clients using emoticons; they often carry multiple, ambiguous meanings.

Exhibit 2.2-3 Common Emoticons and Acronyms in Text-Based Communications

Common Emoticons | | Common Acronyms
:) or :-) | Happiness, joke, sarcasm | AAMOF | As a matter of fact
:( | Unhappiness | BBFN | Bye bye for now
:-/ or :-// or :-S | Undecided, confused | BFN | Bye for now
:@ | Shock or screaming | BTW | By the way
\|-O | Yawn | BYKT | But you knew that
>_< or >< | Angry or frustrated | FITB | Fill in the blank
T_T | Crying | FWIW | For what it's worth
D: | Total fear | FYI | For your information
>O | Ouch | HTH | Hope this helps
X-( | Angry | IMO/IMHO | In my opinion/In my humble opinion
:_( or :'( or QQ | Crying | LOL | Lots of luck/love or laughing out loud
:o | Surprised | NC | No comment
| | NP | No problem
| | NRN | No reply necessary
| | OMW | On my way
| | TIA | Thanks in advance
| | TTYL | Talk to you later
| | TYVM | Thank you very much

Source: Anthony et al., 2010, p. 19. Adapted with permission.

### Determining the Appropriateness of TAC for Clients

As with all modes of service provision, some clients are better suited to TAC than others. For the services to be effective, the client's strengths and resources must match the selected treatment approaches. The International Society for Mental Health Online (2010) identifies some considerations when screening clients for TAC (Exhibit 2.2-4).

Exhibit 2.2.-4 Considerations Regarding the Appropriateness of TAC

Communication preferences:

- Does the client prefer in-person communication, video messaging, phone, email, instant messaging, or chat?
- Is the client able to benefit from communication methods that he/she does not prefer?

Computer knowledge, skill, and resources:

- Does the client have access to a computer system and the Internet?
  Is the client knowledgeable of his or her computer system and the Internet?
- Does the client have the motivation and capacity to experiment with new technologies?
- Are the client's computer resources compatible with the agency or clinician's system?
- Does the location where the client accesses the computer or Internet pose privacy or technological concerns (including firewalls)?
- If Internet access is interrupted, are there workable alternatives, such as email or telephone?

Online communication knowledge:

- Does the client already use technology to communicate with others?
- What type of experience does the client have with online communications?
- Does the client participate in online support groups? What is the quality of these interactions?

Suitability for text-based communication:

- What kinds of experiences has the client had with reading and writing?
- Are there physical, cognitive, or literacy limitations that would interfere with the client's ability or comfort with reading and writing?
- How well does the client type?
- Does the client enjoy in-person and phone conversations? Why?
- Does the client prefer spontaneous communication, such as chat or IM, versus taking the time to compose, edit, and reflect, such as when using email?

Prior or current treatment experiences:

- How might prior treatment experiences or expectations of treatment influence the client's attitude about participating in online therapy?
- Does the client currently participate in counseling or therapy, and how might this experience influence the online therapy experience?

Presenting or co-occurring problems:

- What is the most appropriate level of care for the presenting problem, and will online therapy be able to meet the needs of the client?
- Is the client suicidal or engaging in risky behaviors?
- Does the client have problems or behaviors that might prevent him or her from responding to online therapy (e.g., impulsiveness, difficulty with boundaries)?
- Does the client have physical health conditions or disabilities that may influence his or her ability to use online therapy?
- Does the client have mental or physical health problems that need to be continuously assessed visually, such as slurred speech, tremors, or flat affect?

Cultural considerations:

- Are there language barriers that may create obstacles to text-based communication?
- Are there cultural considerations that enhance or detract from the usefulness of online therapy?

Other resources or referrals:

- Are there other resources that would better serve the client?
- Are there other supports or resources that can supplement online therapy?

Source: Suler, 2001. Adapted with permission.

### Internet Security and Privacy Considerations for Clinicians and Clients

Social networking and online mutual-help groups present a host of support opportunities that transcend geographical boundaries and create opportunities for anonymity that in-person support cannot offer. Nonetheless, social networking and online support also expose users to new risks. Providers delivering TAC, as well as behavioral health program administrators, should know the opportunities and risks associated with social networking, online support, and Internet privacy; they should help their clients minimize Internet security and privacy risks. Many federal, state, and community-based organizations provide information on using social media and other Internet resources safely. The Office of the National Coordinator for Health Information Technology offers information about protecting personal health information, including protecting health information when using mobile devices (see http://www.healthit.gov/patients-families/what-you-can-do-protect-your-health-information). The National Cyber Security Alliance's Stay Safe Online Initiative provides fact sheets, toolkits, and other information on cybersafety. The checklists that follow provide information on cybersafety; administrators, providers, and clients can use them to minimize the risks associated with seeking online support:

- Safety Tips for Social Networking (http://www.staysafeonline.org/stay-safe-online/protect-your-personal-information/social-networks)
- Privacy Tips for Teens & Young Adults (https://www.staysafeonline.org/data-privacy-day/teen-and-young-adult-resources)
- Safety Tips for Mobile Devices (http://www.staysafeonline.org/stay-safe-online/mobile-and-on-the-go/mobile-devices)

Checklist of HIPAA Security Policy Considerations Related to Remote Access and Mobile Devices

Checklist of Technology Fluency

The use of mobile devices and external storage devices in the delivery of clinical services creates additional challenges to ensuring the security of protected health information (PHI). Entities that are covered by the Health Insurance Portability and Accountability Act (HIPAA) must implement policies and procedures to ensure that the electronic PHI they generate or share meets all HIPAA security requirements. The following checklist extracted from the U.S. Department of Health and Human Services (HHS) HIPAA Security Guidance (2006) summarizes some of the key considerations for organizations using mobile devices in the delivery of behavioral health services.

## Staff Recruitment and Supervision

### Screening Staff Members for Technology Competence

A variety of measures assess computer use, attitudes, and fluency and are available for organizational use (Bunz, 2004). Use the following checklist to initiate a discussion with staff members about their comfort with and skills using technology. The list includes items from the Computer-Email-Web Fluency Scale (Bunz, 2004). More detailed questions about computer use appear in the original scale. You can also ask staff members to demonstrate their computer skills in a timed session.

### Supervisor Competencies

There are distinct competencies that supervisors who oversee TAC must master. These competencies are generally derived from using technology in their own practice. In addition, supervisors who use technology to deliver long-distance clinical supervision must have a distinct set of competencies if they are to be adequately prepared to use technology to conduct supervision effectively. Exhibit 2.2-5 depicts the knowledge, skills, and attitudes required for two types of supervisors: those who supervise care providers in their delivery of TAC and those who use technology to deliver supervision.

Exhibit 2.2-5 Technological Competencies for Supervision

Knowledge Area | Supervision of TAC | Supervision via technology
All of the knowledge-related competencies required of clinicians | ✓ | ✓
Ethical and confidentiality concerns related to transmitting clinical information | ✓ | ✓
Benefits of technology-delivered supervision | | ✓
Scope of practice requirements and risks | ✓ | ✓
Regulations related to delivery of technology-based care | ✓
Regulations related to delivery of technology-based supervision | | ✓
Organizational policies on privacy, confidentiality, security, and informed consent | ✓ | ✓
Common ethical, privacy, security, and risk management issues faced when providing technology-based clinical care | ✓
Common ethical, privacy, security, and risk management issues faced when providing technology-based supervision | | ✓
Skill Area | Supervision of TAC | Supervision via technology
All of the skill-related competencies required of clinicians | ✓ | ✓
Development of working alliances with and discerning nonverbal cues of supervisees when using technology | | ✓
Identification of red flags in clients through text, video, clinical records, and clinician reports | ✓ | ✓
Strategies to structure technology-delivered supervision | | ✓
Ability to make a remote supervision session lively and relevant to clinical rather than administrative supervision needs | | ✓
Attitudes | Supervision of TAC | Supervision via technology
Interest in adoption of new practice/supervision techniques | ✓ | ✓
Willingness to work through technology interruptions/glitches | ✓ | ✓

## Sample Telehealth Policies

Policies and procedures vary based on the type of technology used, risks associated with the intervention, the organization's regulatory climate, and the size and scope of the organization itself. The sample policies that follow are adapted from an internal policies and procedures manual developed by The Billings Clinic in Billings, MT, and provided by TIP Consensus Panelist Thelma McClosky Armstrong, M.A. They provide a snapshot of some issues that organizations may wish to consider in developing policies for technology-assisted services. Some of the sample policies clearly relate to telehealth for physical disorders or when a telehealth provider may need a close or thorough physical view of the client. Although telebehavioral health will not often require such a physical review of the client, the policies have been included to foster integrated care in case the telebehavioral health administrator wishes to share these sample policies with a general telehealth administrator.

### Room Evaluation

The goal of this section is to provide a process for evaluation of a room to ensure optimal conditions during a telemedicine consult.

Sound:

- A quiet room is ideal. Fabric (e.g., curtains, walls) and carpeting are beneficial to reduce the reflection of sound in the room.
- Be aware of ambient noise. Listen for fans, furnace, air conditioning, overhead speakers, vacuuming, and noises from nearby rooms. Eliminate noises if possible.
- If the room has a phone, turn the ringer down. Mute or turn volume down on intercom systems if this is an option.

Walls and windows:

- Solid blue or gray walls are ideal. Avoid patterns on the wall or wallpaper.
- Walls behind the client may be covered with blue cloth. Blue enhances skin tones.
- Cover windows with darkening curtains.
- Note objects in the room that may be distracting to cameras and participants. Keep items such as light switches, screens, or reflective items out of frame.

Lighting:

- Fluorescent lighting creates good video. The bulbs should be 3200 to 4700 degrees Kelvin. (Average fluorescent lighting is 3500 degrees Kelvin.)
- Most fluorescent lights are directed down into a room, resulting in darkened eyes.
- Ideal lights are directed to reflect off the ceiling, resulting in indirect lighting. Other options include front lighting or lights mounted on the walls to direct light at the front of participants.

#### Key points

- Solid backgrounds without patterns are preferred for video conferencing.
- Eliminate background noise.
- Curtains should block daylight coming through windows.

### Client Positioning

This section provides instruction on positioning a client for an exam over telemedicine for the ultimate visual clarity and safety:

- Seat the client so that he/she has a clear view of the consultant on the monitor.
- Place the monitor so that the presenter may also see the video being sent to the provider.
- Note the camera angles needed to ensure that the provider sees the exam without the presenter blocking the view. This may involve the use of more than one camera for various parts of an exam.
- Determine the client's mobility status. The client may be asked to walk, jump, balance, squat, and arise from a seated position. Inform the provider of any concerns. Stay by the client's side for these assessments.
- Provide a safe, obstacle-free environment.
- The client may be initially seated in a chair and later move to an exam table.
- The client may need to turn so the camera views the back while assessing lung sounds or other views involving the back. This may also be accomplished by using two camera presets.
- Have blue cloth draping available during a consult. Blue enhances skin tones.

#### Key points

- A presenter needs to see both client and monitor during a telemedicine exam.
- Use blue towels or pads when examining skin to ensure accurate skin tones.

### Camera Placement

This section gives instruction in the use and placement of cameras during a telemedicine consult. Several cameras can be used to evaluate clients for clinical visits, including polycom video conferencing cameras, document cameras, and peripheral cameras.

The high-definition camera:

- Is the primary camera.
- Frame the client in the picture slightly left of center to allow space for the picture-in-picture (PIP) at the consulting site without obscuring the client.
- If more than one person is attending the consult, place chairs close to one another.
- Preset camera settings so that each individual is visible alone in a close shot and together in another shot.
- Preset a close shot of the client's upper body and a full-body shot. The provider can better assess posture and nonverbal communication with these views.
- When adjusting your camera, try to fill the screen as much as possible with people rather than with the table, chairs, walls, lights, or the floor.

The document camera:

- Use a preset for the document camera.
- May be used by either the provider or the client to share printed matter, pictures, X-rays, or three-dimensional objects.
- May be used to assess hands or arms. The lighting and magnification are ideal. Use a blue background to enhance skin tones.

The peripheral camera:

- Use a tripod. Even minimal movement made while holding the camera is magnified on the screen. When practical, it is preferable to use the tripod.
- Use a preset for the peripheral camera.
- Refer to the camera instructions to white balance and focus the camera prior to each use. Compare skin color on the monitor screen with actual color off camera to determine accurate color settings.
- To assess gait, place the camera 12 to 18 inches off the floor. The provider must see the feet, legs, arms, and torso of the client.
- When assessing skin, use a blue cloth pad or blue drape for the background.
- For close shots of the skin, it is best to set the camera for a wide shot and then move the camera very close to the skin.
- Be aware of camera angles when showing the right and left sides of the body—for example, when shooting arm reflexes. Allow the presenter to be in the alignment needed and work around her/him.

#### Key points

- Ensure that the peripheral camera has been white balanced every time it is used.
- Set the camera on wide angle and bring it in close to get a clear picture of the skin.
- Fill the screen as much as possible with the individual(s) in the room.

### Microphone Use

This section directs the placement and use of the microphone for telemedicine consults:

- Place the microphone at least 3 to 5 feet away from the video conferencing unit.
- Place the microphone at least 2 feet from the speaker facing away from the monitor.
- Speak in a normal voice; do not shout.
- Note that the microphone is very sensitive and will pick up and amplify noises such as clicking pens and shuffling paper.
- If the microphone must be relocated during a conference, mute the microphone and then move it to the new location.
- If one site hears an echo or sound distortion over the video conferencing equipment, the most likely cause is microphone placement at the site. The solution is for the offending site to move the microphone away from the monitor speaker and/or turn down the volume.
- Mute microphones when a call comes into the site to protect the confidentiality of the participants until they are ready to join the conference.
- Instruct the users in the control of the mute button and the volume adjustment on the remote.
- Limit side conversations if there are additional people involved in the consultation.
- Ask the people at the other site if they can hear. Have them introduce themselves to evaluate sound quality.
- Pause briefly for others to answer or make comments, due to the fact that the audio has a very slight delay.

#### Key points

- Place the microphone at least 3 feet from the video conferencing unit.
- Check the microphone after the call connects to ensure that the mute is off.
- Ask the site you are connected with to check microphone placement and volume if your voice echoes back,.

### Privacy

This section offers instruction for ensuring that telemedicine visits are private:

- Place a sign on the room's door to noting that a private consult is in session.
- Allow the consulting provider or designee to introduce any other individual(s) in the room and ask the client's permission to have that individual(s) present during the consult. If the client denies permission, the individual(s) will exit the room.
- Allow the consulting provider to pan the room with the camera at the client's request to assure the client that no other parties are attending the consult.
- Ask the client his or her preference regarding the site facilitator staying in the room. Repeat this question at each visit.
- Have the site facilitator wait outside the room or leave a number that the client may call for assistance if he or she is not in the room for the consult.
- If the facilitator will not remain in the room for the consult, adjust the camera prior to exiting so that the provider sees the upper half of the client's body, unless instructed otherwise.
- Inform clients about the video conferencing system and its capabilities, risks, and benefits. Review with them the process that will occur during the consultation.
- Obtain consents for participation in the telemedicine consultation. Maintain the original in the client's medical record at the consulting site. A copy may be made for the records at the client's site.
- Give clients the option of terminating the telemedicine encounter at any time and opting to see the consulting physician in person.

#### Key points

- A client shall sign a consent form for a telemedicine consult.
- The client shall be made aware of all individuals in the room at the far site.
- The site facilitator shall be available to the client during a consult.

### Client Preparation

The goal of this section is to provide instruction in educating the client in preparation for a telemedicine encounter:

- When the initial telemedicine appointment is made, instruct the client to arrive 15 to 30 minutes prior to the appointment with the consultant. Instruct those who must complete registration forms to arrive 30 minutes prior to the appointment and to bring insurance cards and a copy of their current prescriptions.
- In some cases, the consulting doctor's office may send forms to the client to be completed and brought to the visit or mailed back prior to the visit. If a client arrives with completed forms, fax these forms to the consulting provider.
- Give the client the site location name and address and the site facilitator's name and phone number.
- If the client is seeing a [agency name] provider, the rural site will register him or her as a [agency name] client. In the case of a follow-up visit by a previously registered client, further registration may be unnecessary. The telemedicine nurse will notify the site if registration is required. The client bill will come from the consulting provider.
- Introduce yourself to the client and escort the client to the exam room.
- Explain the telemedicine visit and give the client a chance to ask questions.
- Cover these points:
  – The provider is located at an office in a distant town.
  – The client sees the provider on a monitor just as the provider sees the client on a monitor. There are cameras and microphones at both sites.
  – The consultation is private.
  – Ensure the introduction of each person in the rooms at both sites and the issuing of statements as to the role each person plays.
  – Introduce any additional peripheral devices to be used: cameras, electronic stethoscope, document stand, and video otoscope. There may be a need to get a close view of the client using a camera during the consult.
  – The client may be asked to don a gown so that the physical assessment may be completed.
  – Take turns speaking so that all participants can hear the conversation. If the provider wants a certain person in the room to answer a question, the provider will specifically address that individual. Allow the queried individual to respond. Sometimes, providers are assessing speech, cognition, or memory.
  – If the client is uncomfortable with any part of the exam, he or she may refuse to continue that portion of the exam.
  – If the client wants to speak to the provider privately, instruct him or her to let the site facilitator know.
  – Encourage the client/family to ask the provider questions.

#### Key points

- Only clients seeing a [agency name] provider will register using the [agency name] forms.
- The site facilitator shall explain that the telemedicine visit is private.
- Clients should be instructed to take turns speaking during a visit.

### Scheduling Telemedicine Appointments

This section describes a process for scheduling telemedicine appointments.

Option one:

1. When a provider or client requests a telemedicine appointment, call the telemedicine office. (Provider <phone number> or Main Office <phone number>)
2. Initial information required includes the type of specialty consult needed, the referring provider's name and number, and the sites connecting for the consult.
3. Telemedicine staff may need to contact a consulting provider to determine whether the request can be met. The consulting provider may request further medical information to determine whether a client is appropriate for a telemedicine consult.
4. The telemedicine office will set the date and time after consulting with the client, provider, and any other individuals who must be present (presenters or referring providers) and the schedule. Site facilitators may assist in this communication.
5. Client initials are logged in the scheduler. The telemedicine nurse or consulting office staff notifies the site of the client's name.
6. The telemedicine nurse will determine what equipment needs there will be for the appointment and inform the site; note these in the reservation.
7. The appointment scheduler will email appointment information automatically to all involved parties.
8. The scheduling of follow-up appointments will occur in the same manner as described in Steps 1-7.

Option two:

1. When a client or provider requests a telemedicine appointment, place a call to the telemedicine office, the central appointment desk <phone number>, or the consulting specialist's office.
2. Request client information from the caller.
3. The scheduling process continues with steps 5, 6, 7, and 8 under option one.

#### Key points

- A medical consult over telemedicine requires scheduling of the client, the consulting provider, the rooms at both sites, and possibly a presenter.
- The telemedicine site knows which equipment to set up by referring to the telemedicine scheduler.
- Client information on the telemedicine scheduler is limited to the client initials.

### Telemedicine Visit Documentation

The goal of this section is to provide instruction to ensure that proper documentation occurs with telemedicine consults:

- Ensure that a client who participates in a telemedicine visit signs a Client Consent for a Telemedicine Encounter form. If the client previously signed this document, the client need not sign again. Send the original to the consulting site to be filed in the medical records the provider's office keeps. Give a copy to the client.
- Register clients seeing [agency name] providers for the first into the system. Clients must complete forms in the registration packets located at the rural site including Conditions of Registration, [agency name] Face Sheet, and Medicare Secondary Payer (if Medicare eligible). Refer to the [agency name] Telemedicine Registration for New Clients instructions. Send original documents to the telemedicine office for inclusion in the [agency name] chart.
- Offer each client a question and answer form to complete and a self-addressed stamped envelope to mail the completed form back to the [agency name] office if desired. The site facilitator will send the completed form to the [agency name] office in the event that the client leaves the form at the rural site.
- Allow clients to bring to the visit any forms they have received from providers to complete prior to the visit, and send these forms to the appropriate provider.
- Before the visit, review clinical guidelines to determine if this type of visit requires additional information or questionnaires.
- Consider making copies of these documents accessible on the members-only section of the [agency name] Web site.
- Prepare for visits that may require documentation of client vital signs (e.g., weight, temperature, pulse, respiration, blood pressure). The site facilitator may document vital signs on the visit template if appropriate and send them to the provider or verbally report them to the consultant.
- Keep all original documentation at the consulting provider site, as is the case with in-person care. Keep copies at the client site at the discretion of the regional center.

#### Key points

- Have clients sign a consent form for a telemedicine visit even if you are uncertain as to whether it is necessary.
- Keep all original telemedicine documents at the consulting site in the client's chart.

### Records Access

This section ensures that consultants have documents in place for a telemedicine consult:

- Make client records stored at the client site readily available during the consult.
- The consulting provider or staff person working with the provider may request that you provide certain documents prior to the consult.
- Follow the rules that govern sharing of medical information; a consulting provider may access client information from a referring doctor.
- Documents requested may include a referral note, lab reports, X-ray reports or films, scans, or other studies.
- Send client records at the consulting site to the provider in the same manner as occurs with an onsite visit.
- Make a computer with access to the client's electronic medical record available for use by the consultant at the time of the visit.

#### Key points

- It is permissible to share site medical records with a consulting doctor.
- Send documents requested by the consultant via secure fax, mail, or a picture archiving and communication system.

### Prescriptions

This section describes a process for ensuring that a client receives the required prescription(s) following a telemedicine encounter:

- During a consult, a provider may choose to order a new medication or to change the medication the client is currently using.
- The provider may ask the client what pharmacy he or she uses and order the prescription directly.
- The provider may mail a prescription to the client.
- The provider may fax a prescription to the pharmacy used by the client.

#### Key points

- The provider may call a new medication order into the client's pharmacy directly.
- The provider may mail a prescription to the client.

### Additional Tips

- When presenting a client or planning to be on camera for another reason, be aware of clothing choices. Solids are preferable to checks, plaids, geometric shapes, or stripes. Red, vibrant orange, hot pink, and white may cause a color bleeding effect over video. The color of choice is blue, as it enhances natural skin tones.
- A blue drape or cloth pad should be available for all medical consults. Covering carpet to examine feet or draping the client to better examine a limb or face or cover distracting clothing is important to provide quality pictures.
- Client gowns shall be blue (preferably) or a solid color.
- If a provider inquires about a specific area on the client, offer to show that area to allow for assessment. Providers may not be certain of the technology or the convenience of moving the cameras.
- Observe the client for gait, posture, affect, care of clothing, odor (alcohol or body odor), and tremors. Report observations to the provider via the system or by phone when the client is not present. If appropriate, bring up the topic during the encounter. You may say, “I noticed that you are unsteady when you are walking.”
- Model good communication for the client. Encourage the client to ask questions of the provider. If the client has shared a concern prior to the visit, be certain to bring up the topic for the provider to address (e.g., “Mary mentioned that she has noted increased ringing in her ears since she last saw you”).
- You are the connection to the provider. You are the key to a successful consult.

#### Key points

- Presenters should wear clothing in a solid color without patterns.
- Clients may forget important questions once the provider enters the room. If a client shared a concern prior to the provider being present, be certain that it is addressed in the visit.
- Show the provider areas mentioned so that he/she sees everything in question.

The policies presented in this section serve only as an example of how one agency has formulated its telehealth policies. Every administrator must make decisions that reflect the clients, the agency, the services, and the circumstances at hand. Such policies will require updating due to changing needs, circumstances, and technologies.