# Results of Meta-Analyses

Appendix F Figure 1 Ipsilateral Stroke (Nonperioperative) for CEA Compared With Medical Therapy

This figure displays a forest plot showing a meta-analysis of 3 studies reporting rates of ipsilateral stroke with CEA or medical therapy. A positive risk difference (RD) favors medical therapy. Meta-analysis of the 3 trials found an RD of -0.04 with a 95% confidence interval of -0.05 to -0.03 with an I-squared value of 22.7%.

Study | RD | [95% Conf. Interval] | | % Weight
ACAS | -0.042 | -0.060 | -0.024 | 37.60
ACST | -0.035 | -0.049 | -0.021 | 53.56
VACS | -0.071 | -0.114 | -0.028 | 8.84
D+L pooled RD | -0.041 | -0.054 | -0.027 | 100.00

Appendix F Figure 2 Any Stroke (Nonperioperative) for CEA Compared With Medical Therapy

This figure displays a forest plot showing a meta-analysis of 3 studies reporting rates of any stroke with CEA or medical therapy. A positive risk difference (RD) favors medical therapy. Meta-analysis of the 3 trials found an RD of -0.05 with a 95% confidence interval of -0.07 to -0.04 with an I-squared value of 0.0%.

Study | RD | [95% Conf. Interval] | | % Weight
ACAS | -0.050 | -0.075 | -0.025 | 35.98
ACST | -0.057 | -0.077 | -0.037 | 55.88
VACS | -0.059 | -0.111 | -0.006 | 8.14
D+L pooled RD | -0.055 | -0.070 | -0.039 | 100.00

Appendix F Figure 3 Perioperative Stroke/Death or Any Subsequent Stroke for CEA Compared With Medical Therapy

This figure displays a forest plot showing a meta-analysis of 3 studies reporting rates of perioperative stroke/death or any subsequent stroke with CEA or medical therapy. A positive risk difference (RD) favors medical therapy. Meta-analysis of the 3 trials found an RD of -0.03 with a 95% confidence interval of -0.05 to -0.02 with an I-squared value of 0.0%.

Study | RD | [95% Conf. Interval] | | % Weight
ACAS | -0.030 | -0.058 | -0.003 | 36.57
ACST | -0.039 | -0.061 | -0.017 | 55.81
VACS | -0.024 | -0.084 | 0.035 | 7.62
D+L pooled RD | -0.035 | -0.051 | -0.018 | 100.00

Appendix F Figure 4 Perioperative Stroke/Death or Any Subsequent Stroke for CEA Compared With Medical Therapy, Sensitivity Analysis Including Angiogram-Related Events

This figure displays a forest plot showing a meta-analysis of 3 studies reporting rates of perioperative stroke/death or any subsequent stroke, including angiogram-related events, with CEA or medical therapy. A positive risk difference (RD) favors medical therapy. Meta-analysis of the 3 trials found an RD of -0.03 with a 95% confidence interval of -0.05 to -0.02 with an I-squared value of 0.0%.

Study | RD | [95% Conf. Interval] | | % Weight
ACAS | -0.030 | -0.058 | -0.003 | 36.72
ACST | -0.039 | -0.061 | -0.017 | 56.03
VACS | -0.010 | -0.072 | 0.051 | 7.24
D+L pooled RD | -0.034 | -0.050 | -0.017 | 100.00

Appendix F Figure 5 Perioperative Stroke/Death or Any Subsequent Ipsilateral Stroke for CEA Compared With Medical Therapy

This figure displays a forest plot showing a meta-analysis of 3 studies reporting rates of perioperative stroke/death or any subsequent ipsilateral stroke with CEA or medical therapy. A positive risk difference (RD) favors medical therapy. Meta-analysis of the 3 trials found an RD of -0.02 with a 95% confidence interval of -0.03 to -0.01 with an I-squared value of 0.0%.

Study | RD | [95% Conf. Interval] | | % Weight
ACAS | -0.022 | -0.044 | -0.001 | 36.21
ACST | -0.017 | -0.033 | 0.000 | 57.67
VACS | -0.037 | -0.088 | 0.015 | 6.12
D+L pooled RD | -0.020 | -0.033 | -0.007 | 100.00

Appendix F Figure 6 Perioperative Stroke/Death or Any Subsequent Ipsilateral Stroke for CEA Compared With Medical Therapy, Sensitivity Analysis Including Angiogram-Related Events

This figure displays a forest plot showing a meta-analysis of 3 studies reporting rates of perioperative stroke/death or any subsequent ipsilateral stroke, including angiogram-related events, with CEA or medical therapy. A positive risk difference (RD) favors medical therapy. Meta-analysis of the 3 trials found an RD of -0.02 with a 95% confidence interval of -0.03 to -0.01 with an I-squared value of 0.0%.

Study | RD | [95% Conf. Interval] | | % Weight
ACAS | -0.022 | -0.044 | -0.001 | 36.38
ACST | -0.017 | -0.033 | 0.000 | 57.95
VACS | -0.022 | -0.076 | 0.031 | 5.68
D+L pooled RD | -0.019 | -0.032 | -0.006 | 100.00

Appendix F Figure 7 All-Cause Mortality for CEA Compared With Medical Therapy

This figure displays a forest plot showing a meta-analysis of 3 studies reporting rates of all-cause mortality with CEA or medical therapy. A positive risk difference (RD) favors medical therapy. Meta-analysis of the 3 trials found an RD of 0.01 with a 95% confidence interval of -0.02 to 0.03 with an I-squared value of 13.1%.

Study | RD | [95% Conf. Interval] | | % Weight
ACAS | -0.006 | -0.035 | 0.023 | 51.81
ACST | 0.026 | -0.008 | 0.060 | 40.93
VACS | -0.003 | -0.091 | 0.085 | 7.26
D+L pooled RD | 0.007 | -0.017 | 0.031 | 100.00

Appendix F Figure 8 Any Stroke or Death for CEA Compared With Medical Therapy

This figure displays a forest plot showing a meta-analysis of 3 studies reporting rates of any stroke or death with CEA or medical therapy. A positive risk difference (RD) favors medical therapy. Meta-analysis of the 3 trials found an RD of -0.03 with a 95% confidence interval of -0.05 to -0.00 with an I-squared value of 0.0%.

Study | RD | [95% Conf. Interval] | | % Weight
ACAS | -0.032 | -0.068 | 0.004 | 45.17
ACST | -0.022 | -0.057 | 0.013 | 47.89
VACS | -0.030 | -0.122 | 0.062 | 6.94
D+L pooled RD | -0.027 | -0.051 | -0.003 | 100.00

Appendix F Figure 9 Perioperative Stroke or Death for CEA Compared With Medical Therapy

This figure displays a forest plot showing a meta-analysis of 3 studies reporting rates of perioperative stroke or death with CEA or medical therapy. A positive risk difference (RD) favors medical therapy. Meta-analysis of the 3 trials found an RD of 0.02 with a 95% confidence interval of 0.01 to 0.03 with an I-squared value of 0.0%.

Study | RD | [95% Conf. Interval] | | % Weight
ACAS | 0.019 | 0.008 | 0.030 | 40.84
ACST | 0.018 | 0.008 | 0.028 | 53.55
VACS | 0.034 | 0.004 | 0.064 | 5.60
D+L pooled RD | 0.019 | 0.012 | 0.026 | 100.00

Appendix F Figure 10 Perioperative Stroke or Death for CEA Compared With Medical Therapy, Sensitivity Analysis Including Angiogram-Related Events

This figure displays a forest plot showing a meta-analysis of 3 studies reporting rates of perioperative stroke or death, including angiogram-related events, with CEA or medical therapy. A positive risk difference (RD) favors medical therapy. Meta-analysis of the 3 trials found an RD of 0.02 with a 95% confidence interval of 0.01 to 0.03 with an I-squared value of 35.6%.

Study | RD | [95% Conf. Interval] | | % Weight
ACAS | 0.023 | 0.011 | 0.035 | 41.27
ACST | 0.018 | 0.008 | 0.028 | 50.39
VACS | 0.048 | 0.015 | 0.082 | 8.34
D+L pooled RD | 0.023 | 0.012 | 0.033 | 100.00

Appendix F Figure 11 Perioperative Nonfatal Myocardial Infarction for CEA Compared With Medical Therapy

This figure displays a forest plot showing a meta-analysis of 2 studies reporting rates of nonfatal MI with CEA or medical therapy. A positive risk difference (RD) favors medical therapy. Meta-analysis of the 2 trials found an RD of 0.01 with a 95% confidence interval of -0.00 to 0.02 with an I-squared value of 45.8%.

Study | RD | [95% Conf. Interval] | | % Weight
ACST | 0.006 | 0.002 | 0.010 | 74.94
VACS | 0.019 | -0.001 | 0.039 | 25.06
D+L pooled RD | 0.009 | -0.003 | 0.021 | 100.00

Appendix F Figure 12 Perioperative Death or Stroke Rate After CEA, by Study Design

This figure displays a forest plot showing a meta-analysis of 7 cohort studies and 6 trials reporting rates of perioperative stroke or death after CEA. Meta-analysis of the 7 cohort studies found an effect size of 3.32 with a 95% confidence interval (CI) of 2.73 to 3.91 with an I-squared value of 67.0%. Meta-analysis of the 6 trials found an effect size of 2.41 with a 95% CI of 1.71 to 3.12 with an I-squared value of 30.3%.

Appendix F Figure 13 Perioperative Death or Stroke Rate After CEA, Sensitivity Analysis Including Studies Rated as Poor Quality, by Study Design

This figure displays a forest plot showing a meta-analysis of 12 cohort studies and 7 trials reporting rates of perioperative stroke or death after CEA. Meta-analysis of the 12 cohort studies found an effect size of 2.80 with a 95% confidence interval (CI) of 2.13 to 3.46 with an I-squared value of 92.5%. Meta-analysis of the 7 trials found an effect size of 2.35 with a 95% CI of 1.73 to 2.97 with an I-squared value of 19.0%.

Appendix F Figure 14 Perioperative Death or Stroke Rate After CAAS, by Study Design

This figure displays a forest plot showing a meta-analysis of 1 cohort study and 2 trials reporting rates of perioperative stroke or death after CAAS. Meta-analysis of the 1 cohort study found an effect size of 3.80 with a 95% confidence interval (CI) of 2.68 to 4.91. Meta-analysis of the 2 trials found an effect size of 3.12 with a 95% CI of 2.68 to 3.56 with an I-squared value of 0.1%.

Appendix F Figure 15 Perioperative Death or Stroke Rate After CAAS, Sensitivity Analysis Including Studies Rated as Poor Quality, by Study Design

This figure displays a forest plot showing a meta-analysis of 3 cohort studies and 3 trials reporting rates of perioperative stroke or death after CEA. Meta-analysis of the 3 cohort studies found an effect size of 4.32 with a 95% confidence interval (CI) of 3.64 to 4.99 with an I-squared value of 0.0%. Meta-analysis of the 3 trials found an effect size of 2.79 with a 95% CI of 1.90 to 3.67 with an I-squared value of 40.8%.

Appendix F Figure 16 Ipsilateral Stroke (Nonperioperative) for CEA Compared With Medical Therapy, Sensitivity Analysis Using Profile Likelihood Methods

This figure displays a forest plot showing a meta-analysis of 3 studies reporting rates of ipsilateral stroke with CEA or medical therapy. Meta-analysis of the 3 trials found an effect size of -0.04 with a 95% confidence interval of -0.06 to -0.03.

Study | Effect | [95% Conf. Interval] | | % Weight
ACAS | -0.042 | -0.060 | -0.024 | 34.67
ACST | -0.035 | -0.049 | -0.021 | 59.04
VACS | -0.071 | -0.114 | -0.028 | 6.29
Overall effect (pl) | -0.039 | -0.058 | -0.028 | 100.00

Appendix F Figure 17 Any Stroke (Nonperioperative) for CEA Compared With Medical Therapy, Sensitivity Analysis Using Profile Likelihood Methods

This figure displays a forest plot showing a meta-analysis of 3 studies reporting rates of any stroke with CEA or medical therapy. Meta-analysis of the 3 trials found an effect size of -0.06 with a 95% confidence interval of -0.07 to -0.04.

Study | Effect | [95% Conf. Interval] | | % Weight
ACAS | -0.050 | -0.075 | -0.025 | 35.98
ACST | -0.057 | -0.077 | -0.037 | 55.88
VACS | -0.059 | -0.111 | -0.006 | 8.14
Overall effect (pl) | -0.055 | -0.071 | -0.038 | 100.00

Appendix F Figure 18 Perioperative Stroke/Death or Any Subsequent Stroke for CEA Compared With Medical Therapy, Sensitivity Analysis Using Profile Likelihood Methods

This figure displays a forest plot showing a meta-analysis of 3 studies reporting rates of perioperative stroke/death or any subsequent stroke with CEA or medical therapy. Meta-analysis of the 3 trials found an effect size of -0.04 with a 95% confidence interval of -0.05 to -0.02.

Study | Effect | [95% Conf. Interval] | | % Weight
ACAS | -0.030 | -0.058 | -0.003 | 36.57
ACST | -0.039 | -0.061 | -0.017 | 55.81
VACS | -0.024 | -0.084 | 0.035 | 7.62
Overall effect (pl) | -0.035 | -0.052 | -0.015 | 100.00

Appendix F Figure 19 Perioperative Stroke/Death or Any Subsequent Stroke for CEA Compared With Medical Therapy, Sensitivity Analysis Including Angiogram-Related Events and Using Profile Likelihood Methods

This figure displays a forest plot showing a meta-analysis of 3 studies reporting rates of perioperative stroke/death or any subsequent stroke, including angiogram-related events, with CEA or medical therapy. Meta-analysis of the 3 trials found an effect size of -0.03 with a 95% confidence interval of -0.05 to -0.01.

Study | Effect | [95% Conf. Interval] | | % Weight
ACAS | -0.030 | -0.058 | -0.003 | 36.72
ACST | -0.039 | -0.061 | -0.017 | 56.03
VACS | -0.010 | -0.072 | 0.051 | 7.24
Overall effect (pl) | -0.034 | -0.051 | -0.013 | 100.00

Appendix F Figure 20 Perioperative Stroke/Death or Any Subsequent Ipsilateral Stroke for CEA Compared With Medical Therapy, Sensitivity Analysis Using Profile Likelihood Methods

This figure displays a forest plot showing a meta-analysis of 3 studies reporting rates of perioperative stroke/death or any subsequent ipsilateral stroke with CEA or medical therapy. Meta-analysis of the 3 trials found an effect size of -0.02 with a 95% confidence interval of -0.04 to -0.01.

Study | Effect | [95% Conf. Interval] | | % Weight
ACAS | -0.022 | -0.044 | -0.001 | 36.21
ACST | -0.017 | -0.033 | 0.000 | 57.67
VACS | -0.037 | -0.088 | 0.015 | 6.12
Overall effect (pl) | -0.020 | -0.036 | -0.007 | 100.00

Appendix F Figure 21 Perioperative Stroke/Death or Any Subsequent Ipsilateral Stroke for CEA Compared With Medical Therapy, Sensitivity Analysis Including Angiogram-Related Events and Using Profile Likelihood Methods

This figure displays a forest plot showing a meta-analysis of 3 studies reporting rates of perioperative stroke/death or any subsequent ipsilateral stroke, including angiogram-related events, with CEA or medical therapy. Meta-analysis of the 3 trials found an effect size of -0.02 with a 95% confidence interval of -0.03 to -0.01.

Study | Effect | [95% Conf. Interval] | | % Weight
ACAS | -0.022 | -0.044 | -0.001 | 36.38
ACST | -0.017 | -0.033 | 0.000 | 57.95
VACS | -0.022 | -0.076 | 0.031 | 5.68
Overall effect (pl) | -0.019 | -0.034 | -0.005 | 100.00

Appendix F Figure 22 All-Cause Mortality for CEA Compared With Medical Therapy, Sensitivity Analysis Using Profile Likelihood Methods

This figure displays a forest plot showing a meta-analysis of 3 studies reporting rates of all-cause mortality with CEA or medical therapy. Meta-analysis of the 3 trials found an effect size of 0.01 with a 95% confidence interval of -0.02 to 0.04.

Study | Effect | [95% Conf. Interval] | | % Weight
ACAS | -0.006 | -0.035 | 0.023 | 53.91
ACST | 0.026 | -0.008 | 0.060 | 40.08
VACS | -0.003 | -0.091 | 0.085 | 6.02
Overall effect (pl) | 0.007 | -0.024 | 0.038 | 100.00

Appendix F Figure 23 Any Stroke or Death for CEA Compared With Medical Therapy, Sensitivity Analysis Using Profile Likelihood Methods

This figure displays a forest plot showing a meta-analysis of 3 studies reporting rates of any stroke or death with CEA or medical therapy. Meta-analysis of the 3 trials found an effect size of -0.03 with a 95% confidence interval of -0.05 to -0.00.

Study | Effect | [95% Conf. Interval] | | % Weight
ACAS | -0.032 | -0.068 | 0.004 | 45.17
ACST | -0.022 | -0.057 | 0.013 | 47.89
VACS | -0.030 | -0.122 | 0.062 | 6.94
Overall effect (pl) | -0.027 | -0.054 | -0.001 | 100.00

Appendix F Figure 24 Perioperative Stroke or Death for CEA Compared With Medical Therapy, Sensitivity Analysis Using Profile Likelihood Methods

This figure displays a forest plot showing a meta-analysis of 3 studies reporting rates of perioperative stroke or death with CEA or medical therapy. Meta-analysis of the 3 trials found an effect size of 0.02 with a 95% confidence interval of 0.01 to 0.03.

Study | Effect | [95% Conf. Interval] | | % Weight
ACAS | 0.019 | 0.008 | 0.030 | 40.84
ACST | 0.018 | 0.008 | 0.028 | 53.55
VACS | 0.034 | 0.004 | 0.064 | 5.60
Overall effect (pl) | 0.019 | 0.012 | 0.028 | 100.00

Appendix F Figure 25 Perioperative Stroke or Death for CEA Compared With Medical Therapy, Sensitivity Analysis Including Angiogram-Related Events and Using Profile Likelihood Methods

This figure displays a forest plot showing a meta-analysis of 3 studies reporting rates of perioperative stroke or death, including angiogram-related events, with CEA or medical therapy. Meta-analysis of the 3 trials found an effect size of 0.02 with a 95% confidence interval of 0.01 to 0.04.

Study | Effect | [95% Conf. Interval] | | % Weight
ACAS | 0.023 | 0.011 | 0.035 | 38.34
ACST | 0.018 | 0.008 | 0.028 | 56.94
VACS | 0.048 | 0.015 | 0.082 | 4.72
Overall effect (pl) | 0.021 | 0.014 | 0.035 | 100.00

Appendix F Figure 26 Perioperative Nonfatal Myocardial Infarction for CEA Compared With Medical Therapy, Sensitivity Analysis Using Profile Likelihood Methods

This figure displays a forest plot showing a meta-analysis of 3 studies reporting rates of perioperative nonfatal MI with CEA or medical therapy. Meta-analysis of the 3 trials found an effect size of 0.01 with a 95% confidence interval of 0.00 to 0.02.

Study | Effect | [95% Conf. Interval] | | % Weight
ACST | 0.006 | 0.002 | 0.010 | 95.97
VACS | 0.019 | -0.001 | 0.039 | 4.03
Overall effect (pl) | 0.006 | 0.001 | 0.019 | 100.00

Appendix F Figure 27 Perioperative Death or Stroke Rate Reported in Trials After CAAS, Sensitivity Analysis Using Profile Likelihood Methods

This figure displays a forest plot showing a meta-analysis of 2 studies reporting rates of perioperative death or stroke rate reported in trials after CAAS. Meta-analysis of the 2 trials found an effect size of 3.1 with a 95% confidence interval of 2.2 to 3.7.

Profile Likelihood method selected

Study | Effect | [95% Conf. Interval] | | % Weight
Brott 2010 | 2.500 | 1.238 | 3.762 | 11.86
Gray 2009 | 3.200 | 2.737 | 3.663 | 88.14
Overall effect (pl) | 3.117 | 2.224 | 3.661 | 100.00

Appendix F Figure 28 Perioperative Death or Stroke Rate Reported in Trials After CAAS, Sensitivity Analysis Using Profile Likelihood Methods and Including Poor Quality Studies

This figure displays a forest plot showing a meta-analysis of 3 studies reporting rates of perioperative death or stroke rate reported in trials after CAAS, including a poor quality study. Meta-analysis of the 3 trials found an effect size of 3.0 with a 95% confidence interval of 1.2 to 3.6.

Study | Effect | [95% Conf. Interval] | | % Weight
Brott 2010 | 2.500 | 1.238 | 3.762 | 11.31
Zarins 2005 | 1.000 | -0.970 | 2.970 | 4.64
Gray 2009 | 3.200 | 2.737 | 3.663 | 84.05
Overall effect (pl) | 3.019 | 1.202 | 3.582 | 100.00

Appendix F Figure 29 Perioperative Death or Stroke Rate Reported in Cohort Studies After CAAS, Sensitivity Analysis Using Profile Likelihood Methods and Including Poor Quality Studies

This figure displays a forest plot showing a meta-analysis of 3 studies reporting rates of perioperative death or stroke rate reported in cohort studies after CAAS. Meta-analysis of the 3 trials found an effect size of 4.0 with a 95% confidence interval of 1.6 to 6.4.

Study | Effect | [95% Conf. Interval] | | % Weight
Hopkins 2010 | 3.800 | 2.683 | 4.917 | 36.34
Schermerhorn 2013 | 4.700 | 3.798 | 5.602 | 55.80
Lindstrom 2012 | 3.952 | 1.551 | 6.353 | 7.87
Overall effect (pl) | 4.314 | 3.329 | 5.115 | 100.00