# Additional Results

Appendix E Table 1 Accuracy of Screening With Duplex Ultrasonography to Detect CAS (KQ 3)

Appendix E Table 2 Characteristics of Additional Studies Rated as Poor Quality and Reporting Rates of Periprocedural Complications of CEA or CAAS for Adults With Asymptomatic CAS

Appendix E Table 3 Results From Additional Studies Rated as Poor Quality and Reporting Rates of Periprocedural Complications of CEA or CAAS for Adults With Asymptomatic CAS

## Appendix E. References

1 Nowak J, Jogestrand T. Duplex ultrasonography is an efficient diagnostic tool for the detection of moderate to severe internal carotid artery stenosis. Clin Physiol Funct Imaging. May. 2007;27(3):144-7. [pmid: 17445064].
2 Jogestrand T, Lindqvist M, Nowak J. Diagnostic performance of duplex ultrasonography in the detection of high grade internal carotid artery stenosis. Eur J Vasc Endovasc Surg. Jun. 2002;23(6):510-8. [pmid: 12093067].
3 Jahromi AS, Cina CS, Liu Y, et al. Sensitivity and specificity of color duplex ultrasound measurement in the estimation of internal carotid artery stenosis: a systematic review and meta-analysis. J Vasc Surg. Jun. 2005;41(6):962-72. [pmid: 15944595].
4 Nederkoorn PJ, Graaf Y, Hunink M. Duplex ultrasound and magnetic resonance angiography compared with digital subtraction angiography in carotid artery stenosis: a systematic review. (Structured abstract). Stroke. 2003;34(5):1324-31. [pmid: 12690221].
5 Blakeley DD, Oddone EZ, Hasselblad V, et al. Noninvasive carotid artery testing. A meta-analytic review. Ann Intern Med. 1995;122(5):360-7. [pmid: 7847648].
6 Hwang CS, Liao KM, Lee JH, et al. Measurement of carotid stenosis: comparisons between duplex and different angiographic grading methods. J Neuroimaging. Apr. 2003;13(2):133-9. [pmid: 12722495].
7 Wolff T, Guirguis-Blake J, Miller T, et al. Screening for Asymptomatic Carotid Artery Stenosis. Evidence Synthesis Number 50. AHRQ Publication No. 08-05102-EF-1. Agency for Healthcare Research and Quality. December. 2007. Rockville, MD.
8 Wolff T, Guirguis-Blake J, Miller T, et al. Screening for carotid artery stenosis: an update of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. Dec. 18. 2007;147(12):860-70. [pmid: 18087057].
9 Sabeti S, Schillinger M, Mlekusch W, et al. Quantification of internal carotid artery stenosis with duplex US: comparative analysis of different flow velocity criteria. Radiology. Aug. 2004;232(2):431-9. [pmid: 15286315].
10 Horner RD, Oddone EZ, Stechuchak KM, et al. Racial variations in postoperative outcomes of carotid endarterectomy: evidence from the Veterans Affairs National Surgical Quality Improvement Program. Med Care. Jan. 2002;40(1 Suppl):I35-43. [pmid: 11789630].
11 Samsa G, Oddone EZ, Horner R, et al. To what extent should quality of care decisions be based on health outcomes data? Application to carotid endarterectomy. Stroke. Dec. 2002;33(12):2944-9. [pmid: 12468795].
12 Woo K, Garg J, Hye RJ, et al. Contemporary results of carotid endarterectomy for asymptomatic carotid stenosis. Stroke. May. 2010;41(5):975-9. [pmid: 20339122].
13 Garg J, Frankel DA, Dilley RB. Carotid endarterectomy in academic versus community hospitals: the national surgical quality improvement program data. Ann Vasc Surg. May. 2011;25(4):433-41. [pmid: 21435832].
14 Wallaert JB, De Martino RR, Finlayson SR, et al. Carotid endarterectomy in asymptomatic patients with limited life expectancy. Stroke. Jul. 2012;43(7):1781-7. [pmid: 22550053].
15 Fokkema M, Bensley RP, Lo RC, et al. In-hospital versus postdischarge adverse events following carotid endarterectomy. J Vasc Surg. Jun. 2013;57(6):1568-75. 75 e1. 3. [pmid: 23388394].
16 Theiss W, Hermanek P, Mathias K, et al. Predictors of death and stroke after carotid angioplasty and stenting: a subgroup analysis of the Pro-CAS data. Stroke. Aug. 2008;39(8):2325-30. [pmid: 18583556].
17 Palombo D, Lucertini G, Mambrini S, et al. Carotid endarterectomy: results of the Italian Vascular Registry. J Cardiovasc Surg (Torino). Apr. 2009;50(2):183-7. [pmid: 19282808].
18 Micari A, Stabile E, Cremonesi A, et al. Carotid artery stenting in octogenarians using a proximal endovascular occlusion cerebral protection device: a multicenter registry. Catheter Cardiovasc Interv. Jul. 1. 2010;76(1):9-15. [pmid: 20578188].
19 Menyhei G, Bjorck M, Beiles B, et al. Outcome following carotid endarterectomy: lessons learned from a large international vascular registry. Eur J Vasc Endovasc Surg. Jun. 2011;41(6):735-40. [pmid: 21450496].
20 Lindstrom D, Jonsson M, Formgren J, et al. Outcome after 7 years of carotid artery stenting and endarterectomy in Sweden - single centre and national results. Eur J Vasc Endovasc Surg. May. 2012;43(5):499-503. [pmid: 22342694].
21 Sidawy AN, Zwolak RM, White RA, et al. Risk-adjusted 30-day outcomes of carotid stenting and endarterectomy: results from the SVS Vascular Registry. J Vasc Surg. Jan. 2009;49(1):71-9. [pmid: 19028045].
22 Schermerhorn ML, Fokkema M, Goodney P, et al. The impact of Centers for Medicare and Medicaid Services high-risk criteria on outcome after carotid endarterectomy and carotid artery stenting in the SVS Vascular Registry. J Vasc Surg. May. 2013;57(5):1318-24. [pmid: 23406712].
23 Jim J, Rubin BG, Ricotta JJ 2nd, et al. Society for Vascular Surgery (SVS) Vascular Registry evaluation of comparative effectiveness of carotid revascularization procedures stratified by Medicare age. J Vasc Surg. May. 2012;55(5):1313-20. discussion 21. [pmid: 22459755].
24 Mercado N, Cohen DJ, Spertus JA, et al. Carotid artery stenting of a contralateral occlusion and in-hospital outcomes: results from the CARE (Carotid Artery Revascularization and Endarterectomy) registry. JACC Cardiovasc Interv. Jan. 2013;6(1):59-64. [pmid: 23347862].
25 Rajamani K, Kennedy KF, Ruggiero NJ, et al. Outcomes of carotid endarterctomy in the elderly: A report from the care registry(registered trademark). Stroke. 2012;43(2).
26 CaRESS Steering Committee. Carotid revascularization using endarterectomy or stenting systems (CARESS): Phase I clinical trial. J Endovasc Ther. Dec. 2003;10(6):1021-30. [pmid: 14723574].
27 McKinlay SM. Carotid Revascularization Using Endarterectomy or Stenting Systems (CaRESS) phase I clinical trial: 1-Year results. J Vasc Surg. 2005;42(2):213-9. [pmid: 16102616].
28 Zarins CK, White RA, Diethrich EB, et al. Carotid revascularization using endarterectomy or stenting systems (CaRESS): 4-year outcomes. J Endovasc Ther. Aug. 2009;16(4):397-409. [pmid: 19702339].