# Gaucher Disease: Current Issues in Diagnosis and Treatment [Draft]

Technology Assessment Conference Statement, February 27-March 1, 1995

## Introduction

Gaucher disease is a rare inherited enzyme deficiency, which researchers estimate may be present in 10,000-20,000 Americans. It is a panethnic disorder, with highest prevalence in the Ashkenazi Jewish population.

During the past decade, much progress has been made in understanding the molecular biology of the disease and in the ability to treat patients with the disorder. However, many issues regarding diagnosis, population screening, and therapy for patients with Gaucher disease are controversial.

Gaucher disease is characterized by a remarkable degree of variability in its clinical signs and symptoms, ranging from severely affected infants to asymptomatic adults. Many patients suffer from anemia, bone damage, and enlarged livers and spleens; a few develop severe central nervous system damage. Gaucher disease is a potentially lethal disorder. All patients with Gaucher disease have a genetic defect in the enzyme glucocerebrosidase, which results in the accumulation of the lipid glucocerebroside within intracellular structures known as lysosomes.

Patients with Gaucher disease have been classified into three major types on the basis of clinical signs and symptoms: type 1, non- neuronopathic (adult); type 2, acute neuronopathic (infantile); and type 3, subacute neuronopathic (juvenile). All types of Gaucher disease can be diagnosed by demonstrating a deficiency of glucocerebrosidase activity.

The most striking differences among the three types are the presence or absence of neurologic manifestations and the rate of their progression. However, people with the same type of the disorder may differ in their clinical presentation. For example, certain patients with type 1 Gaucher disease, which is by far the most common type, may display some combination of anemia, low blood platelet levels, massively enlarged livers and spleens, and extensive skeletal disease. In contrast, other type 1 patients may have no symptoms and can be identified only by screening or during evaluation for other diseases.

The gene for glucocerebrosidase, which is located on chromosome 1q21, has been characterized and sequenced. Many mutations in the glucocerebrosidase gene have been identified in DNA from different patients; several of these mutations are frequent. Although some patients with the same DNA mutations have similar clinical courses, other patients with the same mutations have very different clinical manifestations. It is still not clear to what extent a person's clinical features (phenotype) or prognosis can be accurately predicted through current mutation analysis. Furthermore, although the molecular techniques can be used for early prenatal diagnosis, detection of individuals carrying the disease gene, and population screening, the appropriate clinical application of these molecular techniques remains unresolved.

Gaucher disease has been traditionally managed by supportive therapy including total or partial removal of the spleen, blood transfusions, orthopedic procedures, and occasionally bone marrow transplantation. More recently, enzyme replacement therapy has become available and has proven effective in many patients. Enzyme replacement therapy has successfully reversed many of the manifestations of the disorder, including abnormal blood counts, increased liver and spleen size, and some skeletal abnormalities. The therapy is very costly, however, ranging from $100,000 to $400,000 annually for each patient.

The purpose of this Technology Assessment Conference was to evaluate current concepts concerning diagnosis, screening, genetic counseling, and management of Gaucher disease. In this effort, the National Institute of Mental Health, together with the Office of Medical Applications of Research of the National Institutes of Health, convened a Technology Assessment Conference, Gaucher Disease: Current Issues in Diagnosis and Treatment. The conference was cosponsored by the National Institute of Child Health and Human Development, the National Institute of Diabetes and Digestive and Kidney Diseases, the National Institute of Neurological Diseases and Stroke, the National Center for Research Resources, the National Center for Human Genome Research, and the Office of Rare Disease Research.

Following 1-1/2 days of presentations by experts in the relevant fields and discussions with the audience, an independent panel composed of specialists and generalists from the medical and other related scientific disciplines, as well as a public representative, considered the evidence and formulated a consensus statement in response to the following six previously stated questions:

- What is the natural history of Gaucher disease, and what is the appropriate technology to assess the severity and to predict the progression of this disorder?
- What are the roles of current molecular and enzymatic assays for ascertaining affected individuals and carriers in various populations?
- What are the indications for treatment of patients with Gaucher disease, and what are the appropriate modes of therapy?
- What are the goals for and consequences of treatment, and how can the therapeutic interventions be assessed?
- Under what circumstances could genotype/phenotype correlations be used for patient care and counseling?
- What are appropriate directions for future research and other relevant issues that should be pursued?

## What Is the Natural History of Gaucher Disease, and What Is the Appropriate Technology to Assess the Severity and to Predict the Progression of This Disorder?

The natural history of Gaucher disease is incompletely documented. The progression and outcome are well understood only in type 2 disease (infantile form). Type 3 disease (juvenile form) has a more variable course. The type 1 (adult) form is most common, especially variable, and least well characterized. Furthermore splenectomy, orthopedic intervention, and enzyme replacement therapy for type 1 Gaucher disease alter its course, natural progression, and outcome. Thus, it is important to standardize the reporting of the effects of these interventions.

Type 1 disease typically presents after infancy and often not until adult life. Indeed, some genotypically affected individuals may never come to medical attention, and their number is unknown. With DNA analysis of family members, many such individuals will be diagnosed. Current technologies may unmask and identify organ-specific manifestations in these asymptomatic individuals. Simple hematologic and biochemical assays and imaging techniques can be used to assess disease progression. Skeletal disease is especially difficult to assess. Mutation analysis provides precise diagnosis but may not give information concerning the severity or progression of the disease. In addition, there are considerable differences in the degree to which organ systems are affected. Furthermore, there are reports of intrafamilial variation. Differences in disease severity have been demonstrated even in identical twins. Thus, other genetic and nongenetic factors appear to be involved in the expression of the disease.

Prenatal diagnosis now affords an opportunity to assess the natural progression of the disease from before birth. Such information may be critical in choosing appropriate technology for prognosis and therapy. Appropriate systematic and quantitative description of the disease is essential to understand its natural course. Patient characterization requires clarification of the terminology used to describe patients, which at this time is confused (e.g., "asymptomatic" versus "asymptomatic but with physical signs and laboratory evidence of disease").

## What Are the Roles of Current Molecular and Enzymatic Assays for Ascertaining Affected Individuals and Carriers in Various Populations?

Enzyme analysis of leukocyte or fibroblast extracts is appropriate to confirm or exclude the diagnosis of Gaucher disease. Several methodologies for enzymatic diagnosis are currently available and are reliable in experienced hands. No consensus has yet been reached on a single most appropriate method, which makes it essential that each laboratory have rigid internal quality assurance and quality control of the method it uses.

The prognosis for patients with type 1 disease cannot be predicted from the residual enzyme activity measured in tissues. Enzymatic analysis cannot be used to detect carriers reliably.

Analysis of DNA for mutations by molecular methods (genotyping) is appropriate in all individuals with glucocerebrosidase deficiency. Genotyping of siblings and parents of affected individuals is important to ascertain other potentially affected individuals who may be asymptomatic and to identify carriers for genetic counseling. Enzyme analysis of parents of affected individuals is also valuable to exclude the possibility of asymptomatic glucocerebrosidase deficiency in a parent with two mutant alleles, only one of which was identified by genotyping. Although current genotype/phenotype correlations are imperfect, genotyping may indicate that neurologic complications are unlikely. It has less value in predicting the likelihood of other complications.

Molecular methods can provide accurate carrier detection, particularly in defined populations. For example, in the Ashkenazi Jewish population, screening for five mutations allows detection of approximately 95 percent of heterozygous individuals. The greater variety of mutations in non-Jewish populations makes carrier detection in these populations more challenging with currently available technology. Analysis of some mutations by DNA amplification can be complicated by the presence of a highly homologous pseudogene that is located nearby. Quality control of the molecular techniques is important, as is awareness of the complexities in interpreting data produced by these amplification methods.

Widespread application of genetic screening to detect either presymptomatic patients with Gaucher disease or heterozygous carriers is not appropriate at this time. The medical value of presymptomatic diagnosis of patients with Gaucher disease and carrier testing has not been established. For this reason, pilot studies examining the potential benefits and/or harms of such screening programs should be encouraged. Ideally, the target community should be involved in the implementation and evaluation of such pilot studies.

## What Are the Indications for Treatment of Patients With Gaucher Disease, and What Are the Appropriate Modes of Therapy?

The clinical features of type 1 glucocerebrosidase deficiency are highly variable, ranging from serious multisystem involvement to the absence of signs or symptoms. In addition, the age of onset of clinical features in those who develop symptoms is variable. This degree of variability raises several important issues that must be considered before initiating treatment. First, the characteristic signs of the disorder, which include anemia, thrombocytopenia without bleeding, hepatosplenomegaly without pain or discomfort, and radiologic changes without evidence of fractures or bone pain, must be differentiated from the symptoms of the disorder, such as bleeding, somatic pain, bone crises, and fractures. Second, knowledge is inadequate on the effect of treatment for patients who display signs but no symptoms of the disease. There is a reasonable consensus to treat those who exhibit symptoms; however, no agreement exists on the clinical criteria for initiating treatment. No consistent guidelines are available at this time because of the lack of sufficient information about the natural history of the disease.

In addition, a group of individuals, of unknown number, have the enzyme deficiency but have not developed signs or symptoms. Because we cannot predict whether these individuals will ever become symptomatic, the appropriateness of prophylactic therapy has not been determined.

A systematic evaluation of enzyme-deficient individuals to define the natural history of the disease is lacking. For symptomatic patients, there should be sufficient extant data given the number of patients who have already been identified, treated, and extensively followed. For asymptomatic individuals, it is necessary to develop protocols for longitudinal evaluation.

Conservative therapy has a role in Gaucher disease, such as hydration, analgesics, and narcotics for pain in bone crises and orthopedic surgical intervention for fractures. The use of vitamin D, calcium, and bisphosphonate in bone crises and for bone growth requires further study.

Although bone marrow transplantation is an effective form of therapy, the risk of mortality and morbidity makes this mode of treatment less desirable.

In type 1 disease, there is good evidence that enzyme replacement therapy with mannose-terminated placental or recombinant glucocerebrosidase is beneficial in reducing hepatosplenomegaly, improving hematologic parameters, and, to a lesser extent, in alleviating bone disease. Enzyme therapy appears to obviate the need for splenectomy in most cases.

Several patients with type 2 disease are reported to have been treated with enzyme replacement therapy, and there was no substantial improvement in their neurologic problems. With current technology, enzyme replacement therapy is unlikely to prove efficacious for patients with type 2 disease. The efficacy of enzyme replacement for neurologic abnormalities in type 3 disease remains to be established.

For individuals with type 1 disease, controversies continue over aspects of enzyme replacement therapy, such as dosage, methods and frequency of administration of the enzyme, and cost. The most contentious issue, and potentially the most difficult for patients and their physicians, is enzyme dosage. Clinical successes have been observed with both the "high" and "low" dosage regimens (described as amount of enzyme administered during a 4-week internval for purposes of comparison, independent of dosage schedule): the 120 U/kg/4 weeks and the 30 U/kg/4 weeks, respectively. Inadequate clinical responses were also reported for all dosage regimens tested. The debate about dosage is complicated by the failure to compare data adequately and by the diversity of protocols. Review of the data indicates two salient points. First, patients vary considerably and unpredictably in their responses. Second, many patients do well on lower dosage regimens. The use of low-dosage regimens for such patients would markedly reduce costs. Debates focusing on minimal differences in degrees and rate of improvement have detracted from the appreciation of the treatment's value.

Current studies are evaluating regimens with dosages even lower than 30 U/kg/4 weeks. The patients in these studies may respond well, but some respond more slowly. Initial and maintenance therapy should be directed at achieving sustained benefit with the lowest possible dosage. The choice of dosage and frequency of enzyme administration will have to be adjusted individually while each patient's progress is monitored. Response may be slow regardless of dosage.

Given the limited number of patients, the treatment strategies, including criteria for intake, dosage, and periodic reevaluation, should be standardized to ensure that data from multiple centers can be pooled to evaluate the proposed treatment regimens. The resolution of these treatment issues can be addressed best through carefully designed, cooperative, clinical trials. The questions to be answered by such trials will be refined if existing data sets are pooled and analyzed without preconceived constraints. In addition, further studies should include the development of more efficient cellular targeting and uptake of the enzyme. The clinical and ethical ramifications of enzyme therapy and the funding of clinical trials must be considered.

Studies to evaluate alternative forms of enzyme replacement therapy and alternative approaches, such as the use of inhibitors of sphingolipid biosynthesis, should be encouraged. Moreover, Gaucher disease is an excellent candidate for gene therapy, and continued research on this modality, including the use of animals models, is therefore indicated.

## What Are the Goals for and Consequences of Treatment, and How Can the Therapeutic Interventions Be Assessed?

The goals of treatment are the amelioration of the manifestations of Gaucher disease and the overall improvement of the health and quality of life of patients.

Although alglucerase has been shown to ameliorate many of the manifestations of type 1 Gaucher disease, the major current concerns are the proper indications to begin treatment, the most appropriate treatment regimens, and cost. Answering the many questions concerning the management of Gaucher disease will require a cooperative effort of considerable scale. For this cooperative effort to have its intended impact, the organizer of the cooperative effort must be free of real or perceived bias. The National Institutes of Health should take the initiative and foster the establishment of a cooperative group of investigators involved in the diagnosis and treatment of patients with Gaucher disease. Three phases in the operation of the proposed group are (1) establishment of a patient registry, (2) analysis of the existing data on natural history and response to therapy, and (3) design and conduct of clinical trials to address unanswered questions.

It would be advantageous to enter all patients with Gaucher disease into a registry. Such a registry would provide a valuable resource for increasing our knowledge of the natural history of the disease, help to identify predictors of response, and facilitate clinical trials to answer specific questions about therapy.

Clinical trials will be most informative if recruitment numbers are adequate to answer the questions addressed, if individuals are stratified for the most relevant variables (e.g., genotypes or baseline levels) to ensure comparability of the various subject groups, and if patients are randomized to treatment arms where appropriate.

A high priority for an early clinical trial is comparison of the dosage and frequency of enzyme administration to symptomatic patients. Outcomes to be assessed should include not only hemoglobin concentration, platelet count, spleen and liver size, and bone integrity but also the patients' functional state, convenience, satisfaction, quality of life, impact on the family, and cost.

A second priority for a clinical trial is to assess the need for enzymatic treatment of asymptomatic patients. Such a trial might initially be confined to high-risk, asymptomatic patients to increase the likelihood of observing a preventive effect of treatment.

## Under What Circumstances Could Genotype/Phenotype Correlations Be Used for Patient Care and Counseling?

More than 50 mutations of the glucocerebrosidase gene have been identified. Investigators are using disparate nomenclature for mutations with reference to genomic DNA, cDNA, the exon involved, and the amino acid alteration in the enzyme. For consistency and ease of communication, mutations should be described using both the amino acid sequence and cDNA, when appropriate.

Most investigators have categorized their study populations into Ashkenazi Jewish and non-Jewish cohorts. Four mutations are reported to account for 89-94 percent of type 1 Gaucher alleles in the Ashkenazi Jewish population and 60-75 percent of type 1 Gaucher alleles in non- Jewish populations. However, these studies do not provide an unbiased estimate of the allele frequencies. Therefore, accurate calculations of the number of individuals who carry the disease genotype are not possible.

Concordance between the genotype and phenotype in Gaucher disease is imperfect. Families with multiple affected members with different clinical presentations and families having discordant identical twins further demonstrate the imprecision of genotype/phenotype correlation. However, the following general conclusions can be drawn based on current data.

1. Homozygosity for N370S (1226G) precludes neuronopathic involvement; that is, it produces type 1 disease only. Nevertheless, this genotype is present in individuals with considerable variability in expression, ranging from absence of signs and symptoms, to mild to moderate disease, to, less commonly, severe type 1 Gaucher disease.
2. Compound heterozygotes with one N370S (1226G) allele have non- neuronopathic Gaucher disease (the one exception a child with oculomotor involvement). These individuals generally have more severe type 1 disease than do N370S (1226G) homozygotes.
3. Homozygotes for L444P (1448C) in the Swedish Norrbottnian population generally present with neuronopathic type 3 disease of variable severity. This same genotype in the Japanese population is associated with non-neuronopathic disease, indicating that genotype/phenotype correlations, to the extent that they exist, may vary with genetic background.

The lack of predictability of phenotype from genotype suggests other genetic and/or nongenetic effects on the phenotype. The opportunity exists to study ethnic isolates, such as the Swedish Norrbottnian and Israeli Jenin Arab populations, each with a single Gaucher genotype and variable expression, to determine the nature of these other genetic and nongenetic factors.

This imperfect agreement between genotype and phenotype limits the ability to establish the prognosis for individual patients and also restricts the usefulness of genotyping for population screening and prenatal diagnosis. The failure of genotype to predict phenotype complicates genetic counseling for newly diagnosed patients and their families, and for prenatal diagnosis.

Testing has been conducted for affected individuals, for carriers, and for prenatal diagnosis. Another reason for genotyping is to estimate carrier and affected frequencies in various populations. Genotyping of anonymous unselected populations is recommended to determine allele frequencies.

The benefits of general population screening for affected individuals are not clear, because treatment of individuals with glucocerebrosidase deficiency who do not have signs or symptoms has not yet been demonstrated to be necessary or efficacious. In addition, the genotype offers limited prognostic information for the individual. Extensive education of health care providers about Gaucher disease should be initiated to ensure accurate and early diagnosis of symptomatic patients.

Carrier screening has most commonly been conducted to provide reproductive counseling and options to couples. This requires

1. a simple, accurate, and relatively inexpensive test to identify most of the carriers (>95 percent sensitivity) with few false positives (high specificity);
2. a disorder of significant clinical severity;
3. a defined population for screening;
4. a test that allows accurate prediction of the clinical course of the disease;
5. a public and professional education program; and
6. informed consent for screening.

Although genotyping for Gaucher disease meets the test criteria, genetic counseling can provide only a risk assessment of passing on the gene but not a specific prognosis for future affected children. The uncertainty of disease severity in each affected individual and the lack of public and professional awareness of Gaucher disease argue against carrier screening in the general population at this time. Cultural mores within specific communities should be considered and may justify carrier screening. Carrier testing for family members of affected individuals is appropriate. In addition, peer-reviewed pilot studies of carrier screening programs may be of value.

Prenatal diagnosis for Gaucher disease is possible and allows couples at risk to make informed reproductive decisions. Because of the considerable variability in disease severity, personal experience with Gaucher disease in a family member will influence the genetic counseling process and ultimate decision. Genetic counseling is confounded by the inability to predict clinical prognosis uniformly, by the heightened anxiety engendered by facing probabilistic information, and by the availability of an encouraging but extremely expensive enzyme replacement therapy. The description of the illness, its manifestations, and its potential response to therapy all influence the decisions made by couples, individuals, and families.

## What Are Appropriate Directions for Future Research and Other Relevant Issues That Should Be Pursued?

Nomenclature must be standardized throughout the field, from the clinical setting to the molecular genetic laboratory. For example, a term as basic as "asymptomatic" is used by workers in the field in very different ways. It is recommended that the term asymptomatic be reserved for individuals who are truly without symptoms. The mutation designation also needs to be standardized for improved ease of communication.

A uniform clinical severity score for type 1 Gaucher disease must be developed and formally validated to permit effective communication regarding the efficacy of treatment. This clinical rating scale should be sensitive to both the signs and the symptoms of the disorder.

A nationwide clinical database should be established that is independent of any corporate entity, particularly those involved in the screening, diagnosis, management, or treatment of Gaucher disease. This will facilitate research to elucidate the natural history of the disease, identify key prognostic factors for disease progression, and determine the influence of various therapies. The database should accumulate extant information and collect missing data on extant patients to permit evaluation of enzyme targeting, uptake efficiency, optimal dosage and schedule, and clinical outcome. In the event of prenatal diagnosis, the neonatal, childhood, adolescent, and adult course of the disease should be carefully documented. Molecular genetic data should be determined and correlated with the clinical information to refine the limits of genotype/phenotype correlations. Such a database will permit the use of mathematical modeling to investigate these questions. The information in the database should be made available to investigators after formal review of their research proposals. Within the database, it should be recognized that multiplex families and identical twins represent unique groups for the study of other factors influencing phenotype.

Nationwide, cooperative, controlled clinical trials should be conducted to establish optimal regimens and to determine their efficacy for asymptomatic individuals with minimal clinical signs. These clinical trials should be free of influence from any commercial entity.

The available technology is not yet appropriate for large-scale, population-based screening for Gaucher disease. However, we recommend that additional pilot projects be supported, independent of corporate influence, to identify carriers and affected individuals. Examples of potential projects include estimation of the true prevalence of the various mutant alleles in defined or mixed populations by anonymous testing; further evaluation of educational needs within screened populations; and elucidation of the value of enzyme delivery to asymptomatic, enzyme-deficient individuals with varying clinical signs. Laboratories providing screening or diagnostic testing should participate in national quality assurance/quality control programs.

Studies to better understand the basic biochemistry and cell biology of the enzyme are needed. Identifying and developing animal models should be encouraged. They provide opportunities to improve the understanding of the pathogenesis and to test experimental strategies including gene therapy.

Enzyme replacement therapy clearly has improved the health and quality of life of individuals with Gaucher disease. This treatment has been made possible through the efforts of investigators at the National Institutes of Health and other researchers nationally and internationally. The cooperative efforts of government and industry have also proven effective. The contributions of the patients and their families, who have participated so willingly in many therapeutic trials, have been especially important.

The experience with enzyme replacement therapy to date has led to new understanding about the disease and its treatment. At the same time, this experience has raised concerns about the development of costly therapies for disorders of very low prevalence. These concerns include the following:

- Should the rights to exclusive marketing of an orphan drug be coupled to Federal approval of the price charged for the drug, and should uniform accounting practices be required?
- Can such price regulation of orphan drugs be imposed without deterring the development of effective drugs for uncommon diseases?
- How can it be ensured that the price citizens pay for a drug reflects the Federal contribution to its development?
- Should society be informed of corporate and other relationships between entities engaged in screening and the manufacturers of therapeutic agents?
- Should pharmaceutical companies and their representatives have direct access to patients?
- Given the potentially extraordinary costs of treatment, how should the benefits to affected individuals and their families be balanced with the other health care needs of society?
- Regarding costly treatments such as alglucerase, what are the implications for the future health care of patients and their families when insurance becomes exhausted and/or when coverage is provided by managed care systems employing fixed capitation limits?

## Conclusions

The success of enzyme replacement therapy for Gaucher disease is a credit to the investigators, the National Institutes of Health, the pharmaceutical manufacturer, and the many patients and their families. Evidence presented at this Technology Assessment Conference leads to the following conclusions:

- Despite the success of enzyme therapy, treatment is limited by the cost of the agent.
- The cost of the treatment makes it imperative to determine the lowest effective initial and maintenance dosages and the most cos effective dosage for clinical response, to define the appropriate clinical indications for treatment, and to establish uniform methods in order to optimize outcome assessment.
- The value of treatment for asymptomatic individuals has not been determined.
- General population screening for affected individuals and for carriers is not appropriate at this time.
- As a prototype for all rare diseases, the plight of the patients with Gaucher disease raises difficult financial and ethical issues that we as a society must address.

## Consensus Development Panel

- Edward R. B. McCabe, M.D., Ph.D.
- Panel and Conference Chairperson
- Professor and Executive Chair
- Department of Pediatrics
- UCLA School of Medicine
- Los Angeles, California

- Beth A. Fine, M.S.
- Assistant Professor and Genetic Counselor
- Department of Obstetrics and Gynecology
- Graduate Program in Genetic Counseling
- Northwestern University Medical School
- Chicago, Illinois

- Mitchell S. Golbus, M.D.
- Professor
- Department of Obstetrics, Gynecology, and Reproductive Science
- University of California, San Francisco
- San Francisco, California

- Joel B. Greenhouse, Ph.D.
- Professor
- Department of Statistics
- Carnegie-Mellon University
- Pittsburgh, Pennsylvania

- Geraldine L. McGrath
- Vice President for Consumers
- Alliance of Genetic Support Groups
- Cystinosis Foundation
- Floyd, Virginia

- Maria New, M.D.
- Professor and Chairman
- Chief of Endocrinology
- Department of Pediatrics
- The New York Hospital-Cornell Medical Center
- New York, New York

- William E. O'Brien, Ph.D.
- Professor
- Department of Molecular and Human Genetics
- Baylor College of Medicine
- Houston, Texas

- Peter T. Rowley, M.D.
- Professor of Medicine, Pediatrics, and Genetics
- Division of Genetics
- Department of Medicine
- University of Rochester School of Medicine
- Rochester, New York

- William S. Sly, M.D.
- Professor and Chairman
- Department of Biochemistry and Molecular Biology
- St. Louis University School of Medicine
- St. Louis, Missouri

- M. Anne Spence, Ph.D.
- Professor
- Department of Pediatrics
- Division of Human Genetics
- University of California, Irvine
- Irvine, California

- James A. Stockman III, M.D.
- President
- American Board of Pediatrics
- Consultant Professor of Pediatrics
- Duke University Medical Center
- Durham, North Carolina
- Clinical Professor of Pediatrics
- University of North Carolina School of Medicine
- Chapel Hill, North Carolina

- Michael Whyte, M.D.
- Professor of Medicine and Pediatrics
- Washington University School of Medicine
- St. Louis, Missouri

- Wesley Wilson, M.D.
- Internal Medicine/Hematologist
- Western Montana Clinic
- Missoula, Montana

- Barry Wolf, M.D., Ph.D.
- Professor
- Departments of Human Genetics and Pediatrics
- Medical College of Virginia/ Virginia Commonwealth University
- Richmond, Virginia

## Speakers

- Johannes M. F. G. Aerts, Ph.D.
- "Enzymatic Diagnosis and Biochemical Detection of Disease Manifestation"
- Department of Biochemistry
- E.C. Slater Institute
- University of Amsterdam
- Amsterdam, The Netherlands

- John A. Barranger, M.D., Ph.D.
- "Gene Therapy for Gaucher Disease"
- Professor
- Department of Human Genetics
- University of Pittsburgh Medical Center
- Pittsburgh, Pennsylvania

- Norman W. Barton, M.D., Ph.D.
- "Introduction to Enzyme Replacement Therapy"
- Chief
- Clinical Investigations Section
- Developmental and Metabolic Neurology Branch
- National Institute of Neurological Disorders and Stroke
- National Institutes of Health
- Bethesda, Maryland

- Ernest Beutler, M.D.
- "North American Patients With Gaucher Disease"
- "Binding, Internalization, and Degradation of Glucocerebrosidase by Macrophages"
- "Enzyme Replacement Therapy"
- Chairman
- Department of Molecular and Experimental Medicine
- The Scripps Research Institute
- La Jolla, California

- Roscoe O. Brady, M.D.
- "Overview and Introduction to Gaucher Disease"
- Chief
- Developmental and Metabolic Neurology Branch
- National Institute of Neurological Disorders and Stroke
- National Institutes of Health
- Bethesda, Maryland

- Ian J. Cohen, M.D., Ch.B.
- "Use of Enzyme Replacement Therapy and Bisphosphonate in Severely Affected Children in Gaucher Disease"
- National Center for Pediatric Hematology Oncology
- Children's Medical Center of Israel
- Petah Tikva, Israel

- Timothy M. Cox, M.D.
- "In Vivo Distribution of Mannose-Terminated Human Glucocerebrosidase in Patients With Gaucher Disease"
- Full Professor
- Department of Medicine
- University of Cambridge School of Clinical Medicine
- Addenbrooke's Hospital
- United Kingdom

- Rabbi Josef Ekstein
- "Premarital and Anonymous Screening for Recessive Genetic Diseases: Recent Experience With Gaucher Disease"
- Executive Director
- Dor Yeshorim-Committee for Prevention of Jewish Genetic Diseases
- Brooklyn, New York

- Christine M. Eng, M.D.
- "Genetic Screening in the Ashkenazi Jewish Population: Experience With a Program for the Simultaneous Screening of Three Genetic Diseases"
- Assistant Professor
- Department of Human Genetics
- Mount Sinai School of Medicine
- New York, New York

- Anders Erikson, M.D., Ph.D.
- "Norrbottnian Patients With Gaucher Disease"
- Department of Pediatrics
- County Hospital
- Boden, Sweden

- Deborah M. Findling, M.S.
- "Demographic Study From a National Gaucher Screening Program"
- Genetic Counselor
- Division of Genetics
- Department of Pediatrics
- University of Illinois at Chicago
- Chicago, Illinois

- Alan M. Garber, M.D., Ph.D.
- "Economic Considerations in Alglucerase Therapy of Gaucher Disease"
- Senior Research Associate
- General Internal Medicine Division
- Department of Veterans Affairs
- Associate Professor
- Department of Medicine
- Stanford University School of Medicine
- Stanford, California

- Edward I. Ginns, M.D., Ph.D.
- "Animal Models of Gaucher Disease"
- "Development of Alternative Therapies for Gaucher Disease"
- Chief
- Clinical Neuroscience Branch
- National Institute of Mental Health
- National Institutes of Health
- Bethesda, Maryland

- Gregory A. Grabowski, M.D.
- "Genotype-Phenotype Correlations in Gaucher Disease"
- "Enzyme Therapy in Gaucher Disease"
- Director
- Division of Human Genetics
- Children's Hospital Medical Center
- Professor
- Departments of Molecular Genetics, Microbiology and Biochemistry, and Pediatrics
- University of Cincinnati
- Cincinnati, Ohio

- Suvimol C. Hill, M.D.
- "Radiographic Assessments of Gaucher Disease"
- Staff Radiologist
- Diagnostic Radiology Department
- Henry M. Jackson Foundation
- Clinical Center
- National Institutes of Health
- Bethesda, Maryland

- Carla E. M. Hollak, M.D.
- "Individualized Low-Dose Alglucerase Therapy for Type 1 Gaucher Disease"
- Internist
- Department of Internal Medicine
- University of Amsterdam
- Amsterdam, The Netherlands

- Michael M. Kaback, M.D.
- "Type 1 Gaucher Disease: Heterozygote Screening in the Ashkenazi Jewish Population--An Alternative Perspective"
- Professor
- Departments of Pediatrics and Reproductive Medicine
- Division of Medical Genetics
- University of California, San Diego
- San Diego, California

- Robert E. Lee, M.D.
- "The Natural History and Pathology of Gaucher Disease"
- Professor
- Department of Pathology
- University of Pittsburgh School of Medicine
- Pittsburgh, Pennsylvania

- Henry J. Mankin, M.D.
- "Bone Disease in Patients With Gaucher Disease: Evolution, Assessment, and Therapy"
- Chief
- Orthopedic Service
- Department of Orthopedic Surgery
- Massachusetts General Hospital
- Harvard Medical School
- Boston, Massachusetts

- Pramod K. Mistry, Ph.D., M.R.C.P.
- "In Vivo Distribution of Mannose-Terminated Human Glucocerebrosidase in Patients With Gaucher Disease"
- Senior Lecturer
- Department of Medicine
- Royal Free Hospital
- London, United Kingdom

- Richard A. Moscicki, M.D.
- "Adverse Reactions and Development of Antibodies During Enzyme Replacement Therapy"
- Vice President
- Clinical, Medical, and Regulatory Affairs
- Genzyme Corporation
- Assistant Physician
- Massachusetts General Hospital
- Harvard Medical School
- Cambridge, Massachusetts

- Gary J. Murray, Ph.D.
- "In Vivo and In Vitro Studies on Targeting and Receptor-Mediated Uptake of Glucocerebrosidase"
- Developmental and Metabolic Neurology Branch
- National Institute of Neurological Disorders and Stroke
- National Institutes of Health
- Bethesda, Maryland

- Marvin Natowicz, M.D., Ph.D.
- "Ethical, Legal, Social, and Insurance Aspects of Screening for Genetic Diseases"
- Division of Medical Genetics
- Schriver Center
- Waltham, Massachusetts

- Gregory M. Pastores, M.D.
- "Enzyme Replacement Therapy for Gaucher Type 1 Disease: The Mount Sinai Experience"
- Assistant Professor
- Departments of Human Genetics and Pediatrics
- Mount Sinai School of Medicine
- New York, New York

- M. Clara Sa Miranda, Ph.D.
- "Phenotypic and Genotypic Characterization of Different Gaucher Populations: European/Asian Patients With Gaucher Disease"
- Head
- Department of Enzymology
- Instituto de Genetica Medica Jacinto de Magalhaes
- Porto, Portugal

- Ellen Sidransky, M.D.
- "DNA Mutational Analysis of Phenotypically Diverse Populations of Gaucher Patients"
- Chief
- Unit on Clinical Genetics
- Clinical Neuroscience Branch
- National Institute of Mental Health
- National Institutes of Health
- Bethesda, MD

- John E. Ware, Jr., Ph.D.
- "Estimating the Health Burden of Gaucher Disease and the Health Benefit of Enzyme Replacement Therapy: A Psychometric Approach"
- Senior Scientist
- Division of Health Improvement
- The Health Institute
- New England Medical Center
- Boston, Massachusetts

- Rob Willemsen
- "Visualization of Alglucerase Targeting: An Immunocytochemical Study on Mouse Liver"
- Department of Cell Biology and Genetics
- Erasmus University
- Rotterdam, The Netherlands

- Rina Zaizov, M.D.
- "Use of Enzyme Replacement Therapy and Bisphosphonate in Severely Affected Children in Gaucher Disease"
- Professor of Pediatrics
- Sackler School of Medicine
- Director
- National Center for Pediatric Hematology Oncology
- Children's Medical Center of Israel
- Petah Tikva, Israel

- Ari Zimran, M.D.
- "Phenotype Correlation in Israeli Patients With Gaucher Disease"
- "Results of Splenectomy, Partial Splenectomy, and Enzyme Replacement Therapy in Israel"
- Director
- Gaucher Clinic
- Department of Medicine
- Shaare Zedek Medical Center
- Jerusalem, Israel

## Planning Committee

- Ellen Sidransky, M.D.
- Chairperson
- Chief
- Unit on Clinical Genetics
- Clinical Neuroscience Branch
- National Institute of Mental Health
- National Institutes of Health
- Bethesda, MD

- John A. Barranger, M.D., Ph.D.
- Professor
- Department of Human Genetics
- University of Pittsburgh
- Pittsburgh, Pennsylvania

- Norman W. Barton, M.D., Ph.D.
- Chief
- Clinical Investigations Section
- Developmental and Metabolic Neurology Branch
- National Institute of Neurological Disorders and Stroke
- National Institutes of Health
- Bethesda, Maryland

- Inese Z. Beitins, M.D.
- Director
- General Clinical Research Centers Program
- National Center for Research Resources
- National Institutes of Health
- Bethesda, Maryland

- Robin Ely Berman, M.D.
- President and CEO Medical Director
- National Gaucher Foundation
- Rockville, Maryland

- Ernest Beutler, M.D.
- Chairman
- Department of Molecular and Experimental Medicine
- The Scripps Research Institute
- La Jolla, California

- Roscoe O. Brady, M.D.
- Chief
- Developmental and Metabolic Neurology Branch
- National Institute of Neurological Disorders and Stroke
- National Institutes of Health
- Bethesda, Maryland

- Jerry M. Elliott
- Program Analyst
- Office of Medical Applications of Research
- National Institutes of Health
- Bethesda, Maryland

- John H. Ferguson, M.D.
- Director
- Office of Medical Applications of Research
- National Institutes of Health
- Bethesda, Maryland

- Edward I. Ginns, M.D., Ph.D.
- Chief
- Clinical Neuroscience Branch
- National Institute of Mental Health
- National Institutes of Health
- Bethesda, Maryland

- Gregory A. Grabowski, M.D.
- Director
- Division of Human Genetics
- Children's Hospital Medical Center
- Professor
- Departments of Molecular Genetics, Microbiology and Biochemistry, and Pediatrics
- University of Cincinnati
- Cincinnati, Ohio

- William H. Hall
- Director of Communications
- Office of Medical Applications of Research
- National Institutes of Health
- Bethesda, Maryland

- Edward R. B. McCabe, M.D., Ph.D.
- Professor and Executive Chair
- Department of Pediatrics
- UCLA School of Medicine
- Los Angeles, California

- Catherine McKeon, Ph.D.
- Director
- Metabolic Diseases and Gene Therapy
- Division of Endocrinology and Metabolic Diseases
- National Institute of Diabetes and Digestive and Kidney Diseases
- National Institutes of Health
- Bethesda, Maryland

- Ralph M. Nitkin, Ph.D.
- Health Scientist Administrator
- Mental Retardation and Developmental Disabilities Branch
- National Institute of Child Health and Human Development
- National Institutes of Health
- Bethesda, Maryland

- Sandra L. Schlesinger, M.S.
- Genetics Counselor/Coordinator
- Interinstitute Medical Genetics Program
- National Center for Human Genome Research
- National Institutes of Health
- Bethesda, Maryland

- Philip H. Sheridan, M.D.
- Special Assistant to the Director
- National Institute of Neurological Disorders and Stroke
- National Institutes of Health
- Bethesda, Maryland

- Marilyn Weeks
- Public Affairs Specialist
- Office of Scientific Information
- National Institute of Mental Health
- National Institutes of Health
- Rockville, Maryland

## Conference Sponsors

- National Institute of Mental Health
- Rex W. Cowdry, M.D.
- Acting Director

- NIH Office of Medical Applications of Research
- John H. Ferguson, M.D.
- Director

## Conference Cosponsors

- National Institute of Child Health and Human Development
- Duane F. Alexander, M.D.
- Director

- National Institute of Diabetes and Digestive and Kidney Diseases
- Phillip Gorden, M.D.
- Director

- National Institute of Neurological Disorders and Stroke
- Zach W. Hall, Ph.D.
- Director

- National Center for Research Resources
- Judith L. Vaitukaitis, M.D.
- Director

- National Center for Human Genome Research
- Francis S. Collins, M.D., Ph.D.
- Director

- NIH Office of Rare Disease Research
- Stephen Groft, Pharm.D.
- Director

## About the NIH Technology Assessment Program

NIH Technology Assessment Conferences and Workshops are convened to evaluate available scientific information related to a biomedical technology. The resultant NIH Technology Assessment Statements and published reports are intended to advance understanding of the technology or issue in question and to be useful to health professionals and the public.

Some Technology Assessment Conferences and Workshops adhere to the NIH Consensus Development Conference (CDC) format because the process is altogether appropriate for evaluating highly controversial, publicized, or politicized issues. In the CDC format, NIH Technology Assessment Statements are prepared by a nonadvocate, non-Federal panel of experts, based on (1) presentations by investigators working in areas relevant to the consensus questions during a 1-1/2 day public session, (2) questions and statements from conference attendees during open discussion periods that are part of the public session, and (3) closed deliberations by the panel during the remainder of the second day and morning of the third. Each statement is an independent report of the panel and is not a policy statement of the NIH or the Federal Government.

Other Technology Assessment Conferences and Workshops are organized around unique formats. Usually, speakers present findings or perspectives on the issue. Policy implications may be discussed. The public is invited to address questions to the speakers. A report of the findings can emerge in one of a variety of formats including publication in a clinical or scientific journal.

### Statement Availability

Preparation and distribution of this statement is the responsibility of the Office of Medical Applications of Research of the National Institutes of Health. Free copies of this statement as well as all other available NIH Technology Assessment Statements and NIH Consensus Statements may be obtained from the following resources:

- NIH Consensus Program Information Service
- P.O. Box 2577
- Kensington, MD 20891
- Telephone 1-800-NIH-OMAR (644-6627)
- Fax (301) 816-2494

Full-text versions of all these statements are also available online through an electronic bulletin board system and through the Internet:

- NIH Information Center BBS (301) 480-5144
- Internet
- Gopher gopher://gopher.nih.gov/Health and Clinical Information
- World Wide Web http://text.nlm.nih.gov
- ftp ftp://public.nlm.nih.gov/hstat/nihcdcs

* The final version of this statement is generally available 6-8 weeks following the date of the conference.