# Preface

from the Surgeon General U.S. Public Health Service

The immediate impetus for this Surgeon General's Report on Youth Violence was the Columbine High School tragedy that occurred in Colorado in April 1999, resulting in the deaths of 14 students, including 2 perpetrators, and a teacher. In the aftermath of that shocking event, both the Administration and Congress requested a report summarizing what research has revealed to us about youth violence, its causes, and its prevention.

Our review of the scientific literature supports the main conclusion of this report: that as a Nation, we possess knowledge and have translated that knowledge into programs that are unequivocally effective in preventing much serious youth violence. Lest this conclusion be considered understated or muted, it is important to realize that only a few years ago, substantial numbers of leading experts involved in the study and treatment of youth violence had come to a strikingly different conclusion. Many were convinced then nothing could be done to stem a tide of serious youth violence that had erupted in the early 1980s. During the decade extending from 1983 to 1993, arrests of youths for serious violent offenses surged by 70 percent; more alarmingly, the number of young people who committed a homicide nearly tripled over the course of that deadly decade. In many quarters, dire predictions about trends in youth violence yielded to resignation; elsewhere, fear and concern prompted well-meaning officials and policy makers to grasp at any proposed solutions, often with little, if any, systematic attention to questions of the efficacy or effectiveness of those approaches.

Fortunately, the past two decades have also been distinguished by the sustained efforts of researchers, legislators, and citizens from all walks of life to understand and address the problem of youth violence. One seminal contribution to these efforts was an initiative taken by one of my predecessors, Surgeon General C. Everett Koop, to address violence as a public health issue; that is, to apply the science of public health to the treatment and prevention of violence. As evident throughout this report, that endorsement was key to encouraging multiple Federal, state, local, and private entities to invest wisely and consistently in research on many facets of youth violence and to translate the knowledge gained into an exciting variety of intervention programs.

Although much remains to be learned, we can be heartened by our accomplishments to date. For one, our careful analyses, together with those conducted by components of the justice system, have demonstrated the pervasiveness of youth violence in our society; no community is immune. In light of that evidence, it has been most encouraging to me to see that the citizens with whom I have interacted in hundreds of communities around the Nation want us to find answers that will help all of our youth. There is a powerful consensus that youth violence is, indeed, our Nation's problem, and not merely a problem of the cities, or of the isolated rural regions, or any single segment of our society.

Equally encouraging have been our findings that intervention strategies exist today that can be tailored to the needs of youths at every stage of development, from young childhood to late adolescence. There is no justification for pessimism about reaching young people who already may be involved in serious violence. Another critical bit of information from our analyses of the research literature is that all intervention programs are not equally suited to all children and youths. A strategy that may be effective for one age may be ineffective for older or younger children. Certain hastily adopted and implemented strategies may be ineffective -- and even deleterious -- for all children and youth.

Understanding that effectiveness varies underscored for us the importance of bridging the gap between science and practice. Only through rigorous research and thorough, repeated evaluations of programs as they operate in the real world will we be assured that we are using our resources wisely.

In presenting this Surgeon General's report, I wish to acknowledge our indebtedness to the many scientists who have persisted in their work in this difficult, often murky area and whose results we have scrutinized and drawn on. We are also immensely grateful to the countless parents, police officers, teachers, juvenile advocates, health and human service workers, and people in every walk of life who recognize the inestimable value of our Nation's youth and the importance of peace, security, and comity in their lives.

David Satcher, M.D., Ph.D.Surgeon General