# Foreword

The opportunity for three Federal agencies, each with a distinct public health mission, to collaborate in developing the Surgeon General's report on youth violence has been an invigorating and rewarding intellectual challenge. We and our respective staffs were pleased to find that the importance that we collectively assign to the topic of youth violence transcended any impediments to a true, shared effort. Obstacles that one might have anticipated -- for example, difficulties in exchanging data and discussing concepts that emanate from many different scientific disciplines -- proved to be surmountable. Indeed, many of the differences in perspective and scientific approach that distinguish the Centers for Disease Control and Prevention (CDC), the National Institutes of Health (NIH), and the Substance Abuse and Mental Health Services Administration (SAMHSA), when combined, afforded us a much fuller appreciation of the problem and much firmer grounds for optimism that the problem can be solved than is obvious from within the boundaries, or confines, of a single organization.

The mission of CDC is to promote health and quality of life by preventing and controlling disease, injury, and disability. The NIH, of which the National Institute of Mental Health (NIMH) is one component, is responsible for generating new knowledge that will lead to better health for everyone. SAMHSA is charged with improving the quality and availability of prevention, treatment, and rehabilitation services in order to reduce illness, death, disability, and cost to society resulting from substance abuse and mental illnesses. Common to each of the agencies is an interest in preventing problems before they have a chance to impair the health of individuals, families, communities, or society in its entirety. Toward this end, CDC, NIH/NIMH, and SAMHSA each support major long-term research projects involving nationally representative samples of our Nation's youth. These studies, which are introduced and described in the report that follows, are designed both to monitor the health status of young Americans and to identify factors that can be shown to carry some likelihood of risk for jeopardizing health -- information that lends itself to mounting effective interventions.

The designation of youth violence as a public health issue complements the more traditional status of the problem as a criminal justice concern. Here again, it has been satisfying for all of us in the public health sector to reach across professional and disciplinary boundaries to our colleagues in law, criminology, and justice and work to meld data that deepen our understanding of the patterns and nature of violence engaged in by young people throughout our country.

What has emerged with startling clarity from an exhaustive review of the scientific literature and from analyses of key new data sources is that we as a Nation have made laudable progress in gaining an understanding of the magnitude of the problem. We have made great strides in identifying and quantifying factors that, in particular settings or combinations, increase the probability that violence will occur. And we have developed an array of interventions of well-documented effectiveness in helping young people whose lives are already marked by a propensity for violence as well as in preventing others from viewing violence as a solution to needs, wants, or problems.

CDC, NIH/NIMH, and SAMHSA look forward to continuing collaborations, begun during the development of this report, that will extend further the abilities of policy makers, communities, families, and individuals to understand youth violence and how to prevent it.

- effrey P. Koplan, M.D., M.P.H.
  Director
  Centers for Disease Control and Prevention
- Steven E. Hyman, M.D.
  Director
  National Institute of Mental Health for The National Institutes of Health
- Joseph H. Autry III, M.D.
  Acting Administrator
  Substance Abuse and Mental Health Services Administration