# Workshop Proceedings

This document summarizes the views expressed by invited speakers and discussants at the Surgeon General's Workshop on Osteoporosis and Bone Health.