# Break-out Group Recommendations for the Surgeon General’s Report

The workshop included time for attendees to break into six small groups to discuss challenges and opportunities to improve bone health. These challenges and recommended actions will help to set priorities and directions for the writing of The Surgeon General’s Report on Osteoporosis and Bone Health. The groups focused on six key issues related to bone health: public awareness and marketing, health care professional knowledge and attitudes, research on health promotion (surveillance and evaluation), early prevention through healthy lifestyles and awareness, access to diagnosis, screening, and treatment, and state and local strategies.

What follows is a summary of the key insights from these discussions, organized as follows: common challenges identified by the groups, top priority areas for overcoming these challenges, and key action steps within each priority area.

## Challengs

- ▪ Educating and promoting awareness of bone health among policymakers, health care professionals, other professionals, and the general public, with the goal of making it a compelling issue
- ▪ Overcoming cultural pressures to maintain a certain body image
- ▪ Promoting exercise and improved eating habits in a technology-driven society that promotes sedentary lifestyles and the choice of fast food
- ▪ Clarifying mixed messages about nutritional supplements
- ▪ Delivering different messages to different audiences—there are no official mechanisms for information transfer
- ▪ Determining—in collaboration with other groups—how to avoid competing messages on healthy lifestyles (and work with complementary ones)
- ▪ Empowering patients to obtain and understand health information
- ▪ Ensuring adequate access to preventive services and treatment, in part by reducing geographic and cost barriers
- ▪ Ensuring that all providers have a strong knowledge of issues and conditions related to bone diseases; current medical education curricula does not focus adequate attention on bone health
- ▪ Forging a consensus statement among various stakeholders related to bone health care, prevention, and treatment
- ▪ Facilitating effective implementation of--and innovation within--programs to improve bone health
- ▪ Increasing basic and translational research on issues such as exercise, diagnostics, nutrition, hormones, and opportunities for prevention and ensuring adherence to recommendations
- ▪ Ensuring consistency in coverage and reimbursement at the state level
- ▪ Realizing adequate funding for programs, research, and professional education

## Priorities

1. Create a base of common knowledge about bones by educating individuals, communities, and society at large about the importance of healthy lifestyles throughout life to promote bone health.
2. Create and disseminate different messages tailored to different audiences.
3. Address access issues (including access to knowledge, diagnosis, and treatment) and all of their implications.
4. Help individuals and communities adopt and maintain behaviors that promote healthy lifestyles for bone health.
5. Educate health professionals to the level necessary for them to prevent, treat, and manage bone diseases.
6. Develop standards and guidelines for individuals, providers, and communities to promote bone health.
7. Create synergies and partnerships among organizations that develop or promote healthy lifestyle messages.
8. Stimulate basic, clinical, and epidemiological research to obtain better data on the surveillance, prevalence, and outcomes of interventions.
9. Raise funding levels for research, intervention programs, and education.

### Priority 1: Create a base of common knowledge about bones by educating individuals, communities, and society at large about the importance of healthy lifestyles throughout life to promote bone health

#### Action Steps

- ➢ Define bone health throughout the life span and elevate bone health to the level of other common health concerns
- ➢ Understand the different aspects of bone health in different groups
- ➢ Identify lifestyle issues universally applicable to bone health (e.g., smoking, exercise, calcium, nutrition)

### Priority 2: Create and disseminate different messages tailored to different audiences

#### Action Steps

- ➢ Develop both general and targeted messages for osteoporosis and other bone diseases that engage listeners (e.g., through an emotional hook)
- ➢ Bring together different perspectives to guide the development and delivery of messages
- ➢ Make development of a cohesive message on healthy lifestyles a key objective of Healthy People 2020
- ➢ Develop ways to evaluate messages’ effectiveness and to refine as required
- ➢ Promote healthy lifestyles through point-of-decision prompts (e.g., to use the stairs rather than the elevator)
- ➢ Develop a national speaker's bureau to disseminate information about bone health and bone disease to health professionals
- ➢ Link osteoporosis to issues raised in the Institute of Medicine report on ethnic disparities in health and to the need to develop osteoporosis programs in community health centers
- ➢ Develop a modifiable web-based educational tool on bone health from which people can select appropriate levels of information about bone diseases
- ➢ Create a National Bone Education Campaign and identify celebrity spokespersons (e.g., public officials, actors) to deliver messages
- ➢ Create a clearinghouse for existing educational material
- ➢ Create a brand identity, such as a logo that is a visual cue for bone health
- ➢ Work with the media

### Priority 3: Address access issues (including access to knowledge, diagnosis, and treatment) and all of their implications

#### Action Steps

- ➢ Develop standards of care for diagnosis and treatment of bone diseases (including for special populations such as children, the disabled, and non-Caucasian men and women) and build public awareness around these standards
- ➢ Make standard care available to all who need it, which will require adequate local resources, reimbursement, and commitment
- ➢ Promote programs sponsored by pharmaceutical companies that make drugs available to low-income individuals
- ➢ Develop less costly treatments and supplements
- ➢ Offer better financing of clinical services
- ➢ Increase availability of mobile DXA

### Priority 4: Help individuals and communities adopt and maintain behaviors that promote healthy lifestyles for bone health

#### Action Steps

- ➢ Develop tools for volunteers and advocates to take action in local communities
- ➢ Encourage schools and work sites to make healthy food available
- ➢ Promote activity through accessible and safe indoor and outdoor space (e.g., trails, walkways, stairs)
- ➢ Develop multidisciplinary centers that house all aspects of bone health under one roof, including bone density screening, physical therapy, and other services
- ➢ Publish best practices in community interventions
- ➢ Engage policymakers in discussions of local needs

### Priority 5: Educate health professionals to the level necessary for them to prevent, treat, and manage bone diseases

#### Action Steps

- ➢ Issue a call for inclusion of information about bone health in the curricula of health professionals
- ➢ Define basic competencies for all health professionals for the prevention and treatment of osteoporosis and other bone diseases
- ➢ Develop a tiered approach to training health professionals about bone health (e.g., use curriculum “bytes” that are appropriate at various levels of education)

### Priority 6: Develop standards and guidelines for individuals, providers, and communities to promote bone health

#### Action Steps

- ➢ Develop nutrition and exercise guidelines, curricula, and messages that are gender, age, and culturally appropriate
- ➢ Engage patients in the health care decision-making process around bone health
- ➢ Develop multidisciplinary, evidence-based protocols to promote bone health and identify and treat patients with bone disease
- ➢ Develop a simple uniform policy for the treatment of bone disease
- ➢ Identify relevant system components for quality bone health care, including the role of physicians, nurses, and physical therapists
- ➢ Identify and promote community best practices
- ➢ Expand nutritional labeling to restaurants
- ➢ Develop national practice guidelines to assist in the implementation of state-level quality-of-care programs
- ➢ Implement performance measures (e.g., HEDIS) to evaluate quality of care of bone diseases

### Priority 7: Create synergies and partnerships among organizations that develop or promote healthy lifestyle messages

#### Action Steps

- ➢ Develop collaborative public-private partnerships to fund research, education, and interventions, and to promote access to policymakers
- ➢ Develop a committee of health professional organizations to identify clinical practice priorities and specific treatment objectives for bone disease
- ➢ Collaborate with non-medical community entities (e.g., churches and senior centers) to provide consistent information about prevention and treatment of bone disease
- ➢ Partner with the food industry on initiatives to improve bone health (e.g., approach fast food restaurants about changing the standard drink in children's meals from soda to milk, work with grocery stores to put signs in the dairy section saying “stop here for bone health”)
- ➢ Create interdisciplinary networks to shape an educational and research agenda

### Priority 8: Stimulate basic, clinical, and epidemiological research to obtain better data on the surveillance, prevalence, and outcomes of interventions

#### Action Steps

- ➢ Develop a better understanding of the mechanisms that lead to osteoporosis, with an eye toward early interventions (e.g., for pre-menopausal women)
- ➢ Strive to alter the pathophysiology of diseases such as Osteogenesis Imperfecta and fibrous dysplasia
- ➢ Conduct further research into restorative therapies and innovative therapeutic strategies (e.g., combination therapies, sequencing of therapies, appropriate duration)
- ➢ Increase research on medical and behavioral interventions and outcomes among specific populations including providers
- ➢ Evaluate data on positive and negative messages to determine what effect they have on behavior change
- ➢ Define optimal nutrition and exercise prescriptions
- ➢ Increase research on physical activity strategies for special needs populations
- ➢ Increase epidemiological research
- ➢ Develop methods to better track trends in data on bone health
- ➢ Collect data about bone health on diverse populations to guide treatment practices
- ➢ Improve reporting of fracture incidence and develop a state and local public health fracture surveillance network across age spans
- ➢ Develop outcome measures as a database for messages to policymakers
- ➢ Increase the focus on the development of standardized, measurable objectives to achieve better bone health

### Priority 9: Raise funding levels for research, intervention programs, and education

#### Action Steps

- ➢ Increase funding for national and state partnerships and prevention programs to promote healthy lifestyles and to expand education and outreach programs
- ➢ Have public and private payers offer separate coverage for screening and adjust codes so that they are more consistent in their coverage of screening tests
- ➢ Increase funding for research to inform innovative programs

## Key Lessons and Discussion from Break-out Group Recommendations

Dr. Moritsugu highlighted the key lessons that emerged from the small-group discussions:

- ▪ Teamwork: Just as each individual is responsible for the product of the group, each stakeholder must play a role as a part of a team that works together to promote bone health.
- ▪ Crosswalk of themes and issues: Issues such as education, awareness, involvement, research, partnerships, and others cut across all the groups.
- ▪ Richness: Given how rich the results from the group discussion were in such a short period of time, the opportunity to tackle the issue of osteoporosis by coming together to form an integrated strategy has never been greater.

Following Dr. Moritsugu’s remarks, attendees engaged in a general discussion of the break-out group recommendations. The key insights from these discussions follow.

### Policy and Coding Issues

Much of the discussion centered on issues related to policy and coding. The NOF has a coding committee that is working with payers on coding issues related to osteoporosis, including bone density screenings. The Centers for Medicare and Medicaid Services (CMS) has also developed a new set of codes that should go a long way toward resolving some of the issues related to osteoporosis; providers need to be made aware of the existence of these new codes. That said, state CMS carriers still maintain control over what coding is acceptable in a local area. Each state has an advisory group to help with this issue. CMS headquarters is unlikely to change their policy of giving deference to these local carriers.

Several attendees warned that the failure to fix coding issues could lead to “unfunded mandates.” For example, if the Surgeon General’s Report were to recommend bone density screening for all elderly patients hospitalized with a fracture without there also being a change in Medicare DRG coding, hospitals would be under pressure to offer such screenings without payment for them. Other attendees raised policy issues that must be addressed, such as the January 2003 implementation of a $1,500 cap on rehabilitation services for each Medicare patient. The fear is that full function cannot be restored with this type of reimbursement constraint.

Another policy issue relates to support of basic research. While much is known about bone disease and how to prevent, diagnose, and treat it, further investment in basic research is critical to filling in those many remaining gaps in knowledge and areas of uncertainty.

### Partnering with Industry

Several attendees urged the development of closer collaboration with the pharmaceutical, dairy, and other industries that are major stakeholders in bone health. While their primary motive for being involved is to make profits, these industries have financial reserves that dwarf those in the bone health community. These resources can be helpful with many different types of activities, including awareness campaigns, testing of therapies (e.g., combination therapies), and other initiatives. The critical challenge is to find ways to make it in the financial interest of these companies to lend support to efforts to improve bone health. Examples of successful partnerships with private industry do exist. For example, Merck heavily supported the NORA study. The National Cholesterol Education Campaign successfully partnered with the pharmaceutical and food industries. Formal guidelines can help to set the terms for private sector participation. Negotiations may also be necessary.

### Partnering within the Medical Profession

The bone health community should consider joining forces with stakeholders (e.g., professional societies, accrediting bodies) in other areas of the health care field, including other specialties (e.g., dermatology, cardiology, and oncology). These partnerships can be valuable assets in education and training initiatives. For example, the Medical Reserve Corps is a new initiative being developed in local areas. Community volunteers in these areas are addressing a wide variety of public health issues. Information on best practices is being shared via the Internet.