# Acknowledgments

The Surgeon General expresses sincere appreciation to all who contributed time, experience, and knowledge to support the development of the Surgeon General’s Workshop on Osteoporosis and Bone Health and this report. The Surgeon General would especially like to acknowledge the following:

## THE PUBLIC

Among the most valuable contributions were those from members of the public, who participated in the following ways:

- ♦ Approximately 200 comments were received at the Surgeon General’s website to provide input on the priorities for the Surgeon General’s Workshop and The Surgeon General’s Report on Osteoporosis and Bone Health.
- ♦ The participants, speakers, moderators, and resource consultants at the Surgeon General’s Workshop on Osteoporosis and Bone Health, especially individuals and family members, shared their personal perspectives on living with bone diseases and what can be done to promote better bone health.

## NATIONAL AND STATE ORGANIZATIONS

Many national and state organizations of advocates, patients, and health care professionals supported the Surgeon General’s effort by sharing their expert knowledge, and by participating in the Workshop. In particular, the Surgeon General would like to recognize the major efforts contributed by the following organizations:

- American Society of Bone and Mineral Research
- National Osteoporosis Foundation
- Osteogenesis Imperfecta Foundation
- The Paget Foundation

The support and continued interest of the following national organizations also are appreciated:

- American Academy of Orthopedic Surgeons
- American Academy of Physician Assistants
- American Osteopathic Association
- Association of State and Territorial Health Officials
- Association of Women’s Health, Obstetric and Neonatal Nurses
- Foundation for Osteoporosis Research and Education
- National Asian Women’s Health Organization
- National Medical Association
- National Women’s Health Network
- North American Menopause Society
- Society for Women’s Health Research
- YWCA of the USA

The support and continued interest of the following state organizations also are appreciated:

- Elder Floridians Foundation
- Georgia Division of Public Health
- Michigan Public Health Institute
- North Carolina Department of Health and Human Services

## GOVERNMENT AGENCIES

The Surgeon General’s Workshop on Osteoporosis and Bone Health was sponsored by the following government agencies in the Department of Health and Human Services:

- Administration on Aging
- Agency for Healthcare Research and Quality
- Centers for Disease Control and Prevention
- Centers for Medicare and Medicaid Services
- Food and Drug Administration
- Health Resources and Services Administration
- National Institute on Aging
- National Institute of Arthritis and Musculoskeletal and Skin Diseases
- National Institute of Diabetes and Digestive and Kidney Diseases
- National Institute of Environmental Health Sciences
- National Institute of Nursing Research
- Office of Disease Prevention and Health Promotion
- Office on Minority Health
- Office on Women’s Health
- Office of the Surgeon General
- President’s Council on Physical Fitness and Sports
- Regional Health Administrators

## PLANNING COMMITTEE

The Surgeon General would especially like to recognize the following individuals for their assistance in conceptualizing the effort, organizing the Workshop, and preparing this report.

- Scientific Editors
- Joan A. McGowan, Ph.D.
- Lawrence G. Raisz, M.D.

- Scientific Editor from the Office of the Surgeon General
- CAPT Allan S. Noonan, M.D., M.P.H.

- Managing Editor and Project Director
- Ann L. Elderkin, P.A.

- Science Writer
- Larry Stepnick

- Interagency Work Group
- Nell Armstrong, Ph.D., R.N.
- Gilberto Cardona, M.D.
- William H. Dietz, M.D.
- Martin N. Erlichman, M.S.
- Christine M. Everett
- Deborah Galuska, Ph.D., M.P.H.
- Annette Kirschner, Ph.D.
- Anita Linde
- Jean Lloyd, M.S., R. D.
- Anne Looker, Ph.D.
- Deborah Maiese
- Ronald Margolis, Ph.D.
- Saralyn Mark, M.D.
- Debra Nichols, M.D.
- CAPT Allan S. Noonan, M.D., M.P.H.
- Susana Perry, M.S.
- Geraldine Pollen, M.A.
- Sherry Sherman, Ph.D.
- Jean Scott, Dr. P.H., R.N.
- Christine Spain, M.A.
- Valerie Welsh
- Susan Wood
- Other Contributors
- Leane Jerome
- Aisha Wilson

## REPORT IMAGES

The following individuals are acknowledged for the use of their presentation slides in this report:

- Dennis Black, Ph.D.
- David Buchner, M.D., M.P.H.
- Susan Greenspan, M.D.
- Douglas P. Kiel, M.D.
- Raynard S. Kington, M.D., Ph.D.
- L. Joseph Melton, III, M.D.
- Miriam Nelson, Ph.D.
- Eric S. Orwoll, M.D.
- B. Lawrence Riggs, M.D.
- Clifford Rosen, M.D.
- Ethel S. Siris, M.D.
- Connie M. Weaver, Ph.D.

## SPECIAL ACKNOWLEDGMENT

The Surgeon General would like to give special acknowledgment to the former Assistant Secretary for Health and the Deputy Surgeon General for their leadership and support for this initiative:

- Former Assistant Secretary for Health
- Eve Slater, M.D.

- Deputy Surgeon General
- RADM Kenneth P. Moritsugu, M.D., M.P.H.