# Improving Bone Health: Comments from the Surgeon General's Web Site

Beginning on September 13, 2002, the Office of the Surgeon General, through its website, started soliciting input from a broad range of interested groups, associations, and individuals regarding key issues in improving bone health. The purpose of this solicitation was to identify and address critical topics for the December 12–13, 2002 Surgeon General's Workshop on Osteoporosis and Bone Health, a meeting that will go on to inform the development of The Surgeon General's Report on Osteoporosis and Bone Health. Over the 45-day comment period, which ran through November 1, 2002, two hundred comments regarding key issues in improving bone health were submitted from a wide range of professionals and consumers.^1^

1 The two hundred respondents included 36 allied health care professionals, 26 consumers, 25 physicians, 19 registered nurses, 19 researchers/scientists (MD), 19 advocacy organization representatives, 15 researchers/scientists (non-MD), 13 state/local government representatives, 11 industry representatives, 10 Federal government representatives, one physical therapist, one other individual, and five individuals responding from outside the United States.

Visitors to the website were invited to provide comments regarding six separate questions. Specifically, they were asked to identify the highest priority issues; major challenges to promoting and preserving bone health; primary barriers to accessing necessary care, services and referrals; major challenges that limit the use of newest research findings; and directions for future research on prevention, treatment and management.

Permeating the responses to each of these questions were six overarching themes where respondents identified greatest needs:

- Offering more education to the public on bone health;
- Providing more education and training to health care professionals;
- Ensuring appropriate access to and coverage of services;
- Targeting special and at-risk populations;
- Conducting more research and establishing guidelines about prevention, screening, diagnosis, and treatment; and
- Increasing funding for bone health initiatives.

More information about these issues and other concerns raised by respondents are discussed in further detail below.

## I. Offering More Education to the Public on Bone Health

The need to raise public awareness about osteoporosis and its prevention, treatment, and management was repeatedly emphasized by health care professionals, researchers, public health officials, advocates, and consumers. According to many respondents, most of the public remains poorly informed about osteoporosis and bone health issues, and specific at-risk groups, including those who have experienced some bone loss but not enough for a diagnosis of osteoporosis, should be better targeted with bone health promotional messages. The fact that the disease is still associated with old age and that osteoporosis risk issues are not taken seriously also present challenges. Suggested public education or awareness messages should encompass osteoporosis risk (including clearer information about genetic factors, risk factors and who is considered at risk); prevention and modification of lifestyles to maximize peak bone mass; early screening and consumer understanding of bone mineral density tests; better consumer education and awareness of treatment options; and an understanding of fall and fracture prevention for individuals living with osteoporosis.

"Americans need clear, concise messages of what they can do regarding their bone health. There seems to be too many conflicting messages of what folks should do.” (Consumer)

Any education initiative should also try to combat the difficulties in motivating people to change behaviors and adopt healthy lifestyle habits, including adoption of physical activity, healthy nutrition, smoking cessation, calcium supplementation, and reduction of soda consumption. Finally, to facilitate increased public awareness of osteoporosis and bone health issues, an industry representative emphasized the need for improved coordination vehicles between the public (government), non-profit (advocacy organizations or foundations) and private sectors.

"The major challenge is to convince people to adopt healthier lifestyles that include the appropriate nutrition and exercise to preserve bone health." (Consumer)

Better knowledge dissemination will play a key role in getting these messages across. Some respondents noted how the media contributes to misinformation of findings by distorting the latest research studies; more often than not, research findings are either not translated appropriately into lay terms or are misconstrued. This includes information about the current controversies involving the long-term use of hormone replacement therapy (HRT). Suggested public avenues to disseminate research information included teen magazines, women's and men's magazines, health magazines, etc.

## II. Providing More Education and Training to Health Care Professionals

The need for increased provider awareness was also raised by many respondents (including health care providers themselves), particularly in the context of early detection, diagnosis, and treatment for osteoporosis. Respondents from across the board noted that provider training related to bone health promotion, osteoporosis prevention, diagnosis, and treatment (along with other related bone diseases) is still minimal in medical schools and residency programs. There is also an overall health system emphasis on disease treatment rather than prevention. Consequently, health care providers have a somewhat fragmented knowledge about the evaluation of osteoporosis, and bone health and osteoporosis preventive services are rarely incorporated into routine primary care practice. Better translation and dissemination of research findings was noted as an important need. The need for more effective standardized training and/or certification of health care professionals who are involved in bone density screening procedures was also mentioned repeatedly; a number of respondents brought up the importance of assuring appropriate education and certification of professionals who perform bone density tests as well as those who interpret them.

"Primary care physicians do not see osteoporosis as an important health care issue...many still view this as a natural consequence of aging." (Industry Representative)

Many respondents asserted that primary care providers need to be aware that osteoporosis is preventable and treatable, that it is not a normal part of aging, and incorporate osteoporosis assessment into their regular patient checkup visits. Along these lines, respondents also noted that physicians seem to lack consensus on when to assess bone quality in their patients as well as how to provide appropriate educational information to their patients. Physician confusion about interpreting bone mineral density test results, underdiagnosis, and undertreatment of the disease, along with inappropriate treatment of compression fractures, were identified as critical issues. The awareness of other health care professionals (nurses, physical therapists, pharmacists, etc.) should also be increased so that they can recognize patients with osteoporosis and counsel them appropriately. Moreover, the need to increase providers' awareness of the psychosocial components of osteoporosis to improve quality of life and self-image for those with the disease was also noted as an urgent priority. Additionally, one physician also urged "distancing the influence of pharmaceutical companies in physician and public education."

"Greater resources need to be applied to the social and psychological effects of these diseases on patients and their families...Patients often retreat into isolation, depression, and anxiety along with their physical pain." (Consumer)

## III. Ensuring Appropriate Access to and Coverage of Services

Another significant priority identified by respondents involves increasing access to preventive, diagnostic, and treatment services, and ensuring that these services are kept affordable and covered by insurance. Current barriers to services include inadequate coverage for screening (especially for men) and treatment; low Medicare reimbursement and low reimbursement rates for providers for all osteoporosis-related services; and high costs of screening, medications, calcium supplements, and/or insurance co-pays. The elderly and uninsured particularly face problems with cost and insurance coverage barriers. Moreover, several respondents felt that the United States' third-party-financed health care system limits universal access to health care, places a low priority on osteoporosis evaluation and treatment, and, in the case of managed care, discourages providers from spending more time with their patients. Also noted was the problem of the lack of insurance coverage for non-pharmaceutical therapies, such as physical therapy.

Other barriers cited by respondents include the high costs of patient education programs, screening, treatment, and medicines for the general population, and the health care system's and insurance companies' emphasis on treatment, rather than prevention and early detection. Rural residents face a lack of health care providers, transportation barriers, and the limited availability of bone mineral density (BMD), or dual-energy X-ray absorptiometry (DXA), scans. To facilitate universal access to screening for geographically isolated populations, one consumer suggested the establishment of "remote diagnostic facilities that transmit findings to a central location." Access to care for the elderly is also a major challenge, and some respondents mentioned that lack of support for frail elderly in nursing homes.

"It is critical for people of both genders, all ages, and all races to have equality of access to osteoporosis prevention and treatment." (Research Scientist)

A small handful of respondents (public health officials, health care professionals, and industry representatives) also commented on the need for future health care systems research to assess and/or evaluate health insurance coverage of or health financing models of bone health and osteoporosis services in the United States. This research would help the current treatment-based service system transition toward a prevention-based system by facilitating and ensuring earlier diagnosis, increased access to bone health related services (and comprehensive insurance coverage and reimbursement of these services), and by managing costs via cost-effective models of care.

## IV. Targeting Special and At-risk Populations

The majority of respondents also mentioned the need for a greater public health focus on racial/ethnic minorities, males, children/adolescents, and the frail elderly in osteoporosis prevention, screening, treatment, and research initiatives. Numerous challenges were cited in identifying and providing outreach to these populations, including the need to develop culturally appropriate and culturally sensitive educational messages, materials, and behavioral interventions. Several respondents noted specifically the challenges of addressing different nutrition and physical activity traditions in various cultures, disparities for lower income and minority children, and poor access to diagnostic services. A number of respondents also mentioned the pressing issue of inadequate calcium consumption and lactose intolerance among minorities, and the need to address calcium supplementation for lactose intolerant populations. Respondents also felt the need for more bone health and osteoporosis research and normative data collection on ethnic and racial minorities, men, younger women, and other at-risk populations, specifically addressing osteoporosis prevalence and incidence, risk factors, screening tools, and appropriate BMD scales, bone loss trends, and appropriate treatments in these groups.

"Many non-Caucasian groups do not realize their risk of osteoporosis nor do the health care providers that see them." (Physician)

Many respondents identified the need for a greater emphasis on prevention in children and adolescents, especially since calcium consumption is declining among today's youth, and obesity and soda consumption are on the rise. School-based prevention programs were suggested, and would include physical activity and nutrition components.

"There needs to be a greater focus and emphasis on children. Osteoporosis prevention starts in childhood." (Physician)

## V. Conducting More Research and Establishing Guidelines on Prevention, Screening, Diagnosis, Treatment, and Management

Underlying many of the concerns was the need to conduct more research on bone diseases and to use this research to establish clear guidelines for prevention, screening, diagnosis, treatment, and management. Several respondents cited the need to assess the effects of nutrition, physical activity, smoking, and excessive dieting on bone formation and to identify more effective treatments with fewer side effects. Health care providers and researchers in particular recommended developing a more comprehensive system of risk assessment and further pursuing genetic research to identify genomic links. In addition, a considerable number of comments reflected the recent controversies on hormone replacement therapy (HRT) for post-menopausal women and its risks versus benefits, and respondents called for research to explore other prophylactic interventions (including bisphosphonates, combination therapies, anabolic agents, antiresorptive agents, growth factors, and their long-term effects).

"With the HRT findings released recently, what impact will that have on the incidence of osteoporosis as women are stopping HRT." (Registered Nurse)

Respondents also emphasized the significant need for reliable and cost-effective screening techniques along with a need for baseline bone density screenings (and insurance coverage of these screenings). One respondent asserted that obese individuals in the U.S. are probably underdiagnosed because of inappropriate BMD scales for obese individuals, while another person expressed strong convictions about the heavily debated topic of early screening for women beginning at age 40, comparing today's bone density recommendations to the mammography recommendations of twenty years ago (which have since been modified for inclusion of younger ages).

"The public is confused by the conflicting research." (Registered Dietitian)

There was the sentiment, too, that better screening would lead to better treatment. Currently, treatment is thwarted by provider and patient confusion about HRT, unpleasant side effects of medications and the need to increase patient compliance with therapies, a lack of referrals to specialists or other health care professionals, and a lack of provider follow-up assessment and treatment after fractures in the elderly. According to several respondents, providers will often treat the symptom (the fracture) instead of the underlying disease, and there is also a significant need to explore the prevention and treatment of secondary osteoporosis. Some health care professionals discussed a need to develop regional databases of bone densitometry results. Still others asserted that the development of effective guidelines and recommendations may involve exploring innovative approaches to prevention and treatments.

## VI. Increasing Funding for Bone Health Initiatives

Underlying the needs for more research, guidelines, and increased provider and public awareness is the necessity of having more funding for bone health-related initiatives. Respondents specified the need for greater Federal and state funding for research and direct health services to continue public and provider education about the disease, while screening and treating more individuals. Funding should also be made available for program evaluation and research, for continued research and large clinical trials of medicines, for advances in technology and latest equipment to be able to apply latest research findings, and for public health organizations, state and local health departments, and local clinics to apply and use the latest research. Providers discussed the drive to keep costs down in health care and concerns with prevention intervention and direct service costs with regard to providing diagnostic and therapeutic services. Additionally, one advocate emphasized how challenging it is for low-budget public health nutrition campaigns to even attempt to compete with the food industry's powerful marketing advertisements of unhealthy foods.

"States are losing funds. Federal funding is needed to provide the necessary education. Unless this disease is made a priority to prevent and treat, we will be in a major epidemic in the future." (State Government Representative)

## VII. Other Concerns and Recommendations

In addition to the above challenges and recommendations that were cited by the majority of respondents, there were also a number of other areas in which more action and research should be taken. Respondents made suggestions regarding:

- Implications for public policy. Respondents saw a need for more government-sponsored initiatives and community-based programs to establish environmental and community supports that enable individuals to engage in healthy lifestyles conducive to osteoporosis prevention. Many also focused on schools' potential roles in early prevention initiatives by providing healthy environments and fostering healthy habits among children. An advocacy organization representative emphasized the absence of sufficient supports in place for girls' and young women's athletic programs, which "limits the opportunities for girls in sports and reduces the likelihood that they will be physically active."
- Prevention. According to respondents, effective prevention strategies and interventions for children, young adults, and early adults should also be investigated and implemented, along with effective fall and fracture prevention interventions for the elderly. Cultural barriers that may impede preventive behavioral change in various ethnic groups should also be addressed.
- Other related bone diseases. Finally, a small number of health care professionals and researchers called for further research on other related bone diseases such as osteogenesis imperfecta, osteomyelitis, Paget's disease, arthritis, rheumatoid arthritis, and polychondritis, and their treatments. The secondary links with bone health and osteoporosis and conditions such as gastrointestinal tract abnormalities, atherosclerosis, polycystic ovarian syndrome, sarcopenia, etc. should also be further investigated.