# Participant List

## Surgeon General’s Workshop on Osteoporosis and Bone Health

- Amy Allina
- Program and Policy Director
- National Women’s Health Network
- 514 10th Street, Suite 400
- Washington, DC 20004
- Phone: (202) 347-1140
- Fax: (202) 347-1168
- E-mail: aallina@womenshealthnetwork.org

- Nell Armstrong, Ph.D., R.N.
- Program Director
- National Institute of Nursing Research
- National Institutes of Health
- 6701 Democracy Boulevard
- Room 710, Mail Stop Code 4870
- Bethesda, MD 20892-4870
- Phone: (301) 594-5973
- Fax: (301) 480-8260
- E-mail: nell_armstrong@nih.gov

- David Atkins, M.D., M.P.H.
- Senior Health Policy Analyst
- Center for Practice and Technology Assessment
- Agency for Healthcare Research and Quality
- U.S. Department of Health and Human Services
- 6010 Executive Boulevard, Suite 300
- Rockville, MD 20852
- Phone: (301) 594-4016
- Fax: (301) 594-4027
- E-mail: datkins@ahrq.gov

- Roberta Biegel
- Director of Government Relations
- Society for Women’s Health Research
- 1828 L Street, NW, Suite 625
- Washington, DC 20036
- Phone: (202) 496-5007
- Fax: (202) 833-3472
- E-mail: roberta@womens-health.org

- Dennis Black, Ph.D.
- Professor
- Department of Epidemiology and Biostatistics
- University of California, San Francisco
- 74 New Montgomery Street, Suite 600
- San Francisco, CA 94105
- Phone: (415) 597-9112
- Fax: (415) 597-9213
- E-mail: dblack@psg.ucsf.edu

- Henry G. Bone, III, M.D.
- Director
- Michigan Bone and Mineral Clinic
- 22201 Moross Road, Suite 260
- Detroit, MI 48236
- Phone: (313) 640-7700
- Fax: (313) 640-1740
- E-mail: hgbone.md@att.net

- Joyce M. Briscoe
- Cavarocchi Ruscio Dennis Associates, LLC
- 316 Pennsylvania Avenue, SE, Suite 403
- Washington, DC 20003
- Phone: (202) 546-4732
- Fax: (202) 546-1257
- E-mail: jbriscoe@dc-crd.com

- David Buchner, M.D., M.P.H.
- Chief, Physical Activity and Health Branch
- Division of Nutrition and Physical Activity
- Centers for Disease Control and Prevention
- Department of Health and Human Services
- 4770 Buford Highway, NE, Mail Stop K-46
- Atlanta, GA 30341-3717
- Phone: (770) 488-5850
- Fax: (770) 488-5473
- E-mail: dbuchner@cdc.gov

- Mona S. Calvo, Ph.D.
- Expert Regulatory Review Scientist
- Office of Applied Research and Safety Assessment
- Center for Food Safety and Applied Nutrition
- Food and Drug Administration
- 8301 Muirkirk Road, Mail Stop HFS-025
- Laurel, MD 20708
- Phone: (301) 827-8492
- Fax: (301) 594-0571
- E-mail: mona.calvo@cfsan.fda.gov

- Thomas G. Carskadon, Ph.D.
- Professor of Psychology
- Mississippi State University
- P.O. Box 6161
- Mississippi State, MS 39762
- Phone: (662) 325-7655
- Fax: (662) 325-7212
- E-mail: tomcar@ra.msstate.edu

- Jane Cauley, Dr.P.H.
- Associate Professor
- Department of Epidemiology
- University of Pittsburgh
- 130 DeSoto Street, Crabtree Hall
- Room A-543
- Pittsburgh, PA 15261
- Phone: (412) 624-0218
- Fax: (412) 624-7397
- E-mail: jcauley@vms.cis.pitt.edu

- Nicholas G. Cavarocchi
- Cavorocchi Ruscio Dennis Associates, LLC
- 316 Pennsylvania Avenue, SE, Suite 403
- Washington, DC 20003
- Phone: (202) 546-4732

- David A. Chambers, Ph.D., M.Sc.
- Program Officer, Dissemination and Implementation Research Program
- Services Research and Clinical Epidemiology Branch
- National Institute of Mental Health
- National Institutes of Health
- 6001 Executive Boulevard
- Room 7133, Mail Stop 9631
- Bethesda, MD 20892-9631
- Phone: (301) 443-3747
- Fax: (301) 443-4045
- E-mail: dchamber@mail.nih.gov

- Katherine Moy Chin, R.D., L.D.
- Commissioner
- State of Maryland Governor’s Commission on Asian Pacific American Affairs
- 4100 North Charles Street, Unit 208
- Baltimore, MD 21218
- Phone: (410) 366-2466
- Fax: (410) 366-2466

- Wojtek Chodzko-Zajko, Ph.D.
- Professor and Department Chair
- Department of Kinesiology
- University of Illinois
- 117 Freer Hall, 906 South Goodwin
- Urbana, IL 61801
- Phone: (217) 244-0823
- Fax: (217) 244-7322
- E-mail: wojtek@uiuc.edu

- Kathleen Cody
- Executive Director
- Foundation for Osteoporosis Research and Education
- 300 27th Street, Suite 103
- Oakland, CA 94612
- Phone: (510) 832-2663
- Fax: (510) 208-7174
- E-mail: kathleenc@fore.org

- Rosaly Correa-de-Araujo, M.D.
- Health Scientist Administrator
- Agency for Healthcare Research and Quality
- 2101 East Jefferson Street, Suite 600E
- Rockville, MD 20852
- Phone: (301) 594-6662
- Fax: (301) 594-2168
- E-mail: rcorrea@ahrq.gov

- Judith Cranford
- Executive Director
- National Osteoporosis Foundation
- 1232 22nd Street, NW
- Washington, DC 20037
- Phone: (202) 223-2226
- Fax: (202) 457-4004
- E-mail: judith@nof.org

- Denise Cyzman
- Senior Project Coordinator
- Health Promotion and Disease Prevention
- Osteoporosis and Other Chronic Conditions
- Michigan Public Health Institute
- 2436 Woodlake Circle, Suite 300
- Okemos, MI 48864
- Phone: (517) 324-7397
- Fax: (517) 324-7370
- E-mail: dcyzman@mphi.org

- Susan Davidson
- National Osteoporosis Foundation
- 1232 22nd Street, NW
- Washington, DC 20037-1292
- Phone: (202) 223-2226
- E-mail: susan.davidson@strickland-inc.org

- Bess Dawson-Hughes, M.D.
- Professor of Medicine
- Metabolism Lab
- Tufts University
- USDA Human Research Center on Aging
- 711 Washington Street
- Boston, MA 02111
- Phone: (617) 556-6064
- Fax: (617) 556-3305
- E-mail: bess.dawson-hughes@tufts.edu

- Susan Dentzer
- Health Correspondent
- NewsHour with Jim Lehrer
- 2700 South Quincy, Suite 240
- Arlington, VA 22206
- Phone: (703) 998-1857
- Fax: (703) 998-1841
- E-mail: sdentzer@newshour.org

- Barbara DeVinney, Ph.D.
- Office of Behavioral and Social Sciences Research
- Office of the Director
- National Institutes of Health
- Building 1, Room 256
- One Center Drive
- Bethesda, MD 20892
- Phone: (301) 402-3930
- Fax: (301) 402-1150
- E-mail: devinneb@od.nih.gov

- Ann L. Elderkin, P.A.
- Managing Editor/Project Director
- Surgeon General’s Report on Osteoporosis and Bone Health
- Health Systems Research, Inc.
- Four Milk Street, Third Floor
- Portland, ME 04101-4164
- Phone: (207) 772-1410
- Fax: (207) 772-1650
- E-mail: aelderkin@hsrnet.com

- Martin Erlichman, M.S.
- Senior Health Science Analyst
- Center for Practice and Technology Assessment
- Agency for Healthcare Research and Quality
- U.S. Department of Health and Human Services
- 6010 Executive Boulevard, Suite 300
- Rockville, MD 20852
- Phone: (301) 594-2601
- Fax: (301) 594-4027
- E-mail: merlichm@ahrq.gov

- Christine M. Everett
- Food and Drug Administration
- 5600 Fishers Lane
- Room 1665, Mail Stop HF-8
- Rockville, MD 20857
- Phone: (301) 827-0938
- Fax: (301) 827-0926
- E-mail: ceverett@oc.fda.gov

- Suzanne Feetham, Ph.D., R.N., F.A.A.N.
- Senior Advisor
- Office of Director
- Bureau of Primary Health Care
- Health Resources and Services Administration
- 4350 East West Highway
- Bethesda, MD 20814
- Phone: (301) 443-2710
- Fax: (301) 594-4072
- E-mail: sfeetham@hrsa.gov

- Lawrence Fields, M.D.
- Senior Executive Advisor to the Assistant Secretary for Health
- Department of Health and Human Services
- 200 Independence Avenue, SW, Room 716G
- Washington, DC 20201
- Phone: (202) 690-7694
- Fax: (202) 690-6960
- E-mail: lefields@osophs.dhhs.gov

- Michael Fleischman
- Intern
- President’s Council on Physical Fitness and Sports
- 200 Independence Avenue, SW
- Room 738-H
- Washington, DC 20201-0004
- Phone: (202) 690-4963
- E-mail: mfleischman@osophs.dhhs.gov

- Susan M. Friedman
- Deputy Director
- Government Relations
- American Osteopathic Association
- 1090 Vermont Avenue, NW
- Washington, DC 20005
- Phone: (202) 414-0143
- Fax: (202) 544-3525
- E-mail: sfriedman@aoa-net.org

- Deborah A. Galuska, Ph.D., M.P.H.
- Epidemiologist
- Division of Nutrition and Physical Activity
- Centers for Disease Control and Prevention
- U.S. Department of Health and Human Services
- 4770 Buford Highway, NE
- Atlanta, GA 30341
- Phone: (770) 488-6017
- Fax: (770) 488-6027
- E-mail: dgaluska@cdc.gov

- Jean Gearing, Ph.D., M.P.H.
- Acting Osteoporosis Program Manager
- Chronic Disease Prevention and Health Promotion Branch
- Georgia Division of Public Health
- Two Peachtree Street, NW, Cube 16-453
- Atlanta, GA 30303
- Phone: (404) 657-6631
- Fax: (404) 657-6643
- E-mail: jmgearing@dhr.state.ga.us

- Deborah T. Gold, Ph.D.
- Associate Professor
- Departments of Psychiatry and Behavioral Sciences, Sociology, and Psychology: Social and Health Sciences
- Duke University Medical Center
- Box 3003
- Durham, NC 27710
- Phone: (919) 660-7530
- Fax: (919) 684-8569
- E-mail: dtg@geri.duke.edu

- Joan Goldberg
- Executive Director
- American Society for Bone and Mineral Research
- 2025 M Street, NW, Suite 800
- Washington, DC 20036-3309
- Phone: (202) 367-1161
- Fax: (202) 367-2161
- E-mail: joan_goldberg@dc.sba.com

- Jean Gonzalez
- 39342 Tollhouse Road
- Lovettsville, VA 20180
- Phone: (540) 822-4864
- E-mail: jimmygonzalez@hotmail.com

- Julie Gonzalez
- 39342 Tollhouse Road
- Lovettsville, VA 20180
- Phone: (540) 822-4864
- E-mail: jimmygonzalez@hotmail.com

- Christine W. Gould
- YWCA of the USA
- 1015 18th Street, NW, Suite 700
- Washington, DC 20036
- Phone: (202) 467-0801
- Fax: (202) 467-0802
- E-mail: cgould@ywca.org

- Amy Greene
- Director, Prevention Policy
- Adolescent Health
- Association of State and Territorial Health Officials
- 1275 K Street, NW, Suite 800
- Washington, DC 20005-4006
- Phone: (202) 371-9090
- Fax: (202) 371-9797
- E-mail: agreene@astho.org

- Susan L. Greenspan, M.D.
- Professor of Medicine
- University of Pittsburgh
- Kaufmann Medical Building
- 3471 Fifth Avenue, Suite 1110
- Pittsburgh, PA 15213
- Phone: (412) 692-2476
- Fax: (412) 692-2486
- E-mail: greenspans@msx.dept-med.pitt.edu

- Betty Lee Hawks
- Special Assistant to the Director
- Office of Minority Health
- Office of Public Health and Science
- U.S. Department of Health and Human Services
- Rockwall II
- 5515 Security Lane, Suite 1000
- Rockville, MD 20852
- Phone: (301) 443-5084
- Fax: (301) 594-0767
- E-mail: bhawks@osophs.dhhs.gov

- Leanne Jerome
- Office of the Surgeon General
- Department of Health and Human Services
- 5600 Fishers Lane, Suite 18-66
- Rockville, MD 20857
- Phone: (301) 443-4000

- Sara Johnson, Ph.D.
- Director
- Health Behavior Change Programs
- Pro-Change Behavior Systems, Inc.
- P.O. Box 755
- West Kingston, RI 02879
- Phone: (401) 874-5612
- Fax: (401) 874-4103
- E-mail: sjohnson@prochange.com

- Linda Johnson
- 3413 Webster Street
- Brentwood, MD 20722
- Phone: (301) 864-4734
- Fax: (301) 530-2208

- Wanda K. Jones, Dr.P.H.
- Deputy Assistant Secretary and Director of the Office of Women’s Health
- Office of the Secretary
- Office of Public Health and Science
- Department of Health and Human Services
- Hubert H. Humphrey Building
- 200 Independence Avenue, SW, Room 712E
- Washington, DC 20201
- Phone: (202) 690-7650
- Fax: (202) 401-4005
- E-mail: wjones@osophs.dhhs.gov

- Jason Jurkowski
- Office of the Surgeon General
- Department of Health and Human Services
- 5600 Fishers Lane, Suite 18-66
- Rockville, MD 20857
- Phone: (301) 443-4000

- Stephen Katz, M.D., Ph.D.
- Director
- National Institute of Arthritis and Musculoskeletal and Skin Diseases
- National Institutes of Health
- Building 31, 31 Center Drive
- Room 4C32, Mail Stop Code 2350
- Bethesda, MD 20892-2350
- Phone: (301) 496-4353
- Fax: (301) 402-3607
- E-mail: katzs@mail.nih.gov

- Douglas P. Kiel, M.D., M.P.H.
- Director of Medical Research
- Research and Training Institute
- Hebrew Rehabilitation Center for the Aged
- 1200 Centre Street
- Boston, MA 02131
- Phone: (617) 363-8544
- Fax: (617) 363-8936
- E-mail: kiel@mail.hrca.harvard.edu

- Raynard S. Kington, M.D., Ph.D.
- Deputy Director
- National Institutes of Health
- Department of Health and Human Services
- Building One
- One Center Drive, Room 126
- Bethesda, MD 20892-0148
- Phone: (301) 496-7322
- Fax: (301) 402-2700
- E-mail: kingtonr@od.nih.gov

- Richard L. Kravitz, M.D., M.S.P.H.
- Professor of Medicine
- Center for Health Services Research in Primary Care
- University of California, Davis Medical Center
- 4150 V Street, Suite 2500 PSSB
- Sacramento, CA 95817
- Phone: (916) 734-1248
- Fax: (916) 734-8731
- E-mail: rlkravitz@ucdavis.edu

- Peggy Lassanske
- President
- Elder Floridians Foundation
- P.O. Box 16183
- Tallahassee, FL 32317
- Phone: (850) 205-2500
- Fax: (850) 205-2503
- E-mail: pjl@elderfloridians.org

- Marie-Michele Leger, M.P.H., P.A.-C.
- Director, Professional Education
- American Academy of Physician Assistants
- 950 North Washington Street
- Alexandria, VA 22314
- Phone: (703) 836-2272
- Fax: (703) 684-1924
- E-mail: mleger@aapa.org

- Jewel F. Lewis
- Retired Chief Judge and Chair
- Board of Contract Appeals
- Department of Agriculture
- Associate General Counsel and General Counsel of Service Corps of Retired Executives
- 4506 Butterworth Place, NW
- Washington, DC 20016-4456
- Phone: (202) 363-3542

- Karen Lim
- Acting Executive Director
- National Asian Women’s Health Organization
- 250 Montgomery Street, Suite 900
- San Francisco, CA 94104
- Phone: (415) 989-9747
- Fax: (415) 989-9758
- E-mail: karen@nawho.org

- Anita M. Linde
- Senior Program Analyst
- Office of the Director
- National Institute of Arthritis and Musculoskeletal and Skin Diseases
- Building 31, 31 Center Drive
- Room 4C32, Mail Stop 2350
- Bethesda, MD 20892
- Phone: (301) 496-0803
- Fax: (301) 402-3607
- E-mail: lindea@mail.nih.gov

- Jean Lloyd, M.S., R.D.
- National Nutritionist
- Office of Community Based Services
- U.S. Administration on Aging
- U.S. Department of Health and Human Services
- Washington, DC 20201
- Phone: (202) 357-3582
- Fax: (202) 357-3549
- E-mail: jean.lloyd@aoa.gov

- Anne Looker, Ph.D.
- Senior Research Epidemiologist
- Health Examination Statistics
- National Center for Health Statistics
- Centers for Disease Control and Prevention
- 3311 Toledo Road, Room 4310
- Hyattsville, MD 20782
- Phone: (301) 458-4352
- Fax: (301) 458-4029
- E-mail: alooker@cdc.gov

- Robert Lorigan
- Two Loons Lane
- Orient, ME 04471
- Phone: (207) 448-2902
- E-mail: lorigan@nci2.net

- Annie Lorigan
- Two Loons Lane
- Orient, ME 04471
- Phone: (207) 448-2902
- E-mail: lorigan@nci2.net

- Kathryn R. Mahaffey, Ph.D.
- Director
- Office of Science Coordination and Policy
- Division of Exposure Assessment
- Environmental Protection Agency
- 1200 Pennsylvania Avenue, NW
- Room 4106A (EPA East)
- Washington, DC 20460
- Phone: (202) 564-8463
- Fax: (202) 564-8482
- E-mail: mahaffey.kate@epa.gov

- Edward W. Maibach, M.P.H., Ph.D.
- Worldwide Director of Social Marketing
- Porter Novelli
- 1909 K Street, NW, Suite 400
- Washington, DC 20006
- Phone: (202) 973-5800
- Fax: (202) 973-5858
- E-mail: emaibach@porternovelli.com

- Deborah Maiese
- Director
- Maternal and Child Health Bureau
- Office of Women’s Health
- Health Resources and Services Administration
- 5600 Fishers Lane, Room 10C-09
- Rockville, MD 20857
- Phone: (301) 443-8695
- Fax: (301) 443-8587
- E-mail: dmaiese@hrsa.gov

- Jean Mandeville
- Two West Saint Albans Road
- Hopkins, MN 55305
- Phone: (952) 936-0946
- Fax: (952) 936-0946
- E-mail: jjjmande@skypoint.com

- Ronald Margolis, Ph.D.
- Senior Advisor for Molecular Endocrinology
- Division of Diabetes, Endocrinology and Metabolism
- National Institute of Diabetes and Digestive and Kidney Diseases
- 6707 Democracy Boulevard, Room 693
- Bethesda, MD 20892-5460
- Phone: (301) 594-8819
- Fax: (301) 435-6047
- E-mail: rm76f@nih.gov

- Joan C. Marini, M.D., Ph.D.
- Chief
- Heritable Disorders Branch
- National Institute of Child Health and Human Development
- Building 10, 10 Center Drive
- 9000 Rockville Pike
- Room 9S241, Mail Stop Code 1830
- Bethesda, MD 20892-1830
- Phone: (301) 496-6683
- Fax: (301) 402-0234
- E-mail: oidoc@helix.nih.gov

- Saralyn Mark, M.D.
- Senior Medical Advisor
- Office on Women’s Health
- Office of Public Health and Science
- National Aeronautics and Space Administration
- Department and Health and Human Services
- 200 Independence Avenue, SW
- Washington, DC 20201
- Phone: (202) 690-6385
- Fax: (202) 401-4005
- E-mail: smark@osophs.dhhs.gov

- Jeff Martin
- Office of the Surgeon General
- Department of Health and Human Services
- 5600 Fishers Lane, Suite 18-66
- Rockville, MD 20857
- Phone: (301) 443-4000

- Joan A. McGowan, Ph.D.
- Director, Musculoskeletal Diseases Branch
- Extramural Program
- National Institute of Arthritis and Musculoskeletal and Skin Diseases
- National Institutes of Health
- One Democracy Plaza
- 6701 Democracy Boulevard, Suite 800
- Bethesda, MD 20892-4872
- Phone: (301) 594-5055
- Fax: (301) 480-4543
- E-mail: mcgowanj@mail.nih.gov

- John McGrath, Ph.D.
- Chief
- Public Information and Communications Branch
- National Institute of Child Health and Human Development
- National Institutes of Health
- Building 31
- 31 Center Drive, Room 2A32
- Bethesda, MD 20892-2425
- Phone: (301) 496-5135
- Fax: (301) 496-7101
- E-mail: mcgrathj@mail.nih.gov

- Taya McMillan
- Office of Women’s Health
- Office of the Secretary
- Office of Public Health and Science
- Department of Health and Human Services
- Hubert H. Humphrey Building
- 200 Independence Avenue, SW, Room 712E
- Washington, DC 20201
- Phone: (202) 690-7650
- Fax: (202) 401-4005
- E-mail: tmcmillan@osophs.dhhs.gov

- L. Joseph Melton, III, M.D.
- Eisenberg Professor
- Department of Health Sciences Research
- Mayo Clinic and Foundation
- 200 First Street, SW
- Rochester, MN 55905
- Phone: (507) 284-5550
- Fax: (507) 284-1516
- E-mail: melton.j@mayo.edu

- Kenneth P. Moritsugu, M.D., M.P.H.
- Deputy Surgeon General of the United States
- Office of the Surgeon General
- Department of Health and Human Services
- 5600 Fishers Lane, Suite 18-66
- Rockville, MD 20857
- Phone: (301) 443-4000

- Miriam Nelson, Ph.D.
- Director
- Friedman School of Nutrition Science and Policy
- Center for Physical Activity and Nutrition
- Tufts University
- 150 Harrison Avenue, Room 249
- Boston, MA 02111
- Phone: (617) 556-3094
- Fax: (617) 556-3083
- E-mail: miriam.nelson@tufts.edu

- Debra Nichols, M.D.
- Public Health Advisor
- Office of Disease Prevention and Health Promotion
- Office of Public Health and Science
- Department of Health and Human Resources
- 200 Independence Avenue, SW, Room 738G
- Washington, DC 20201
- Phone: (202) 401-0735
- Fax: (202) 205-9478
- E-mail: dnichols@osophs.dhhs.gov

- Allan S. Noonan, M.D., M.P.H.
- Senior Advisor
- Office of the Surgeon General
- 5600 Fishers Lane, Room 18-66
- Rockville, MD 20857
- Phone: (301) 443-0903
- Fax: (301) 443-1211
- E-mail: anoonan@osophs.dhhs.gov

- Eric S. Orwoll, M.D.
- Professor of Medicine
- Program Director, General Clinical Research Center
- Associate Dean for Clinical Research
- Assistant Vice President for Research
- Oregon Health and Science University
- 3181 Southwest Sam Jackson Park Road
- CR 113
- Portland, OR 97239
- Phone: (503) 494-0225
- Fax: (503) 494-4816
- E-mail: orwoll@ohsu.edu

- Lucille Norville Perez, M.D.
- 6419 Dahlonega Road
- Bethesda, MD 20816
- Phone: (301) 229-6081
- E-mail: drlucyperez@hotmail.com

- Diana Pethtel
- 4301 Connecticut Avenue, NW
- Washington, DC 20008
- Phone: (202) 237-1670

- Robert A. Phillips, Ph.D.
- Chief, Radiological Devices Branch
- Center for Devices and Radiological Health
- Office of Device Evaluation
- Food and Drug Administration
- 9200 Corporate Boulevard
- Rockville, MD 20850
- Phone: (301) 594-1212
- Fax: (301) 480-4224
- E-mail: rap@cdrh.fda.gov

- Vivian W. Pinn, M.D.
- Associate Director for Research on Women’s Health
- Office of the Director
- National Institutes of Health
- Building One
- 9000 Rockville Pike, Room 201
- Bethesda, MD 20892-0161
- Phone: (301) 402-1770
- Fax: (301) 402-1798
- E-mail: pinnv@od.nih.gov

- Geraldine B. Pollen, M.A.
- Research Activities Coordinator
- National Institute of Arthritis and Musculoskeletal and Skin Diseases
- Extramural Program
- National Institutes of Health
- One Democracy Plaza
- 6701 Democracy Boulevard, Suite 800
- Bethesda, MD 20892-4872
- Phone: (301) 451-9893
- Fax: (301) 480-4543
- E-mail: polleng@mail.nih.gov

- Lawrence G. Raisz, M.D.
- Division of Endocrinology and Metabolism
- University of Connecticut Health Center
- 263 Farmington Avenue
- Farmington, CT 06030
- Phone: (860) 679-3851
- Fax: (860) 679-1454
- E-mail: raisz@nso.uchc.edu

- Claudia Reid Ravin, C.N.M., M.S.N.
- Associate Director, Women’s Health Programs
- Association of Women’s Health, Obstetric and Neonatal Nurses
- 2000 L Street, NW, Suite 740
- Washington, DC 20036
- Phone: (800) 673-8766
- Fax: (202) 728-0575
- E-mail: claudiar@awhonn.org

- B. Lawrence Riggs, M.D.
- Distinguished Investigator, Mayo Foundation
- Purvis and Roberta Tabor Professor of Medical Research, Mayo Medical School
- Division of Endocrinology
- Mayo Clinic and Foundation
- 615 North 6 Plummer
- 200 First Street, SW
- Rochester, MN 55905
- Phone: (507) 284-3961
- Fax: (507) 284-8271
- E-mail: riggs.lawrence@mayo.edu

- Edward J. Roccella, Ph.D., M.P.H.
- Coordinator, National High Blood Pressure Education Program
- Office of Prevention, Education and Control
- National Heart, Lung and Blood Institute
- National Institutes of Health
- 31 Center Drive
- Room 4A-10, Mail Stop Code 2480
- Bethesda, MD 20892-2480
- Phone: (301) 496-1051
- Fax: (301) 402-1051
- E-mail: er16x@nih.gov

- Clifford Rosen, M.D.
- Osteoporosis Research Center
- St. Joseph Hospital
- 360 Broadway
- Bangor, ME 04401
- Phone: (207) 262-1176
- Fax: (207) 262-2060
- E-mail: rofe@aol.com

- Bruce S. Schneider, M.D.
- Medical Officer
- Division of Metabolic and Endocrine Drug Products
- Center for Drug Evaluation and Research
- Food and Drug Administration
- 5600 Fishers Lane, HFD-510
- Rockville, MD 20857
- Phone: (301) 827-6425
- E-mail: schneiderb@cder.fda.gov

- Jean Scott, Dr.P.H., R.N.
- CBC/QMHAG/DAPAC, S3-02-01
- Centers for Medicare and Medicaid Services
- Department of Health and Human Services
- 7500 Security Boulevard
- Baltimore, MD 21244
- Phone: (410) 786-6327
- Fax: (410) 786-8532
- E-mail: jscott2@cms.hhs.gov

- Jay Shapiro, M.D.
- Kennedy Krieger Institute
- 707 North Broadway, Room 125
- Baltimore, MD 21205
- Phone: (410) 502-9400
- Fax: (410) 295-3557
- E-mail: shapiroj@kennedykrieger.org

- Heller An Shapiro
- Executive Director
- Osteogenesis Imperfecta Foundation
- 804 West Diamond Avenue, Suite 210
- Gaithersburg, MD 20878
- Phone: (301) 947-0083
- Fax: (301) 947-0456
- E-mail: hshapiro@oif.org

- Sherry Sherman, Ph.D.
- Director
- Clinical Endocrinology and Osteoporosis Research
- National Institute on Aging
- National Institutes of Health
- Gateway Building, 7201 Wisconsin Avenue
- Bethesda, MD 20892-9205
- Phone: (301) 435-3048
- Fax: (301) 402-1784
- E-mail: shermans@nia.nih.gov

- Kathy Shipp, P.T., Ph.D.
- Assistant Research Professor
- Physical Therapy
- Community and Family Medicine
- Duke University Medical Center
- Box 3907
- Durham, NC 27710
- Phone: (919) 660-7548
- Fax: (919) 684-8569
- E-mail: kathy.shipp@duke.edu

- Ethel S. Siris, M.D.
- Madeline C. Stabile Professor of Clinical Medicine
- Endocrinology Division
- Columbia University and Columbia Presbyterian Medical Center
- Harkness Pavilion
- 180 Fort Washington Avenue, Room 9-964
- New York, NY 10032
- Phone: (212) 305-2529
- Fax: (212) 305-6482
- E-mail: es27@columbia.edu

- Eve Slater, M.D.
- Former Assistant Secretary for Health
- Department of Health and Human Services
- Hubert H. Humphrey Building
- 200 Independence Avenue, SW, Room 716G
- Washington, DC 20201
- Phone: (202) 690-7694
- Fax: (202) 690-6960

- Christine Snow, Ph.D., F.A.C.S.M.
- Director, Bone Research Laboratory
- Professor, Exercise and Sport Science
- College of Health and Human Sciences
- Oregon State University
- 13 Women’s Building
- Corvallis, OR 97331
- Phone: (541) 737-5935
- Fax: (541) 737-1341
- E-mail: christine.snow@oregonstate.edu

- Christine Spain, M.A.
- Director, Research, Planning, and Special Projects
- President’s Council on Physical Fitness and Sports
- 200 Independence Avenue, SW, Room 738-H
- Washington, DC 20201-0004
- Phone: (202) 690-5148
- Fax: (202) 690-5211
- E-mail: cspain@osophs.dhhs.gov

- Larry Stepnick, M.B.A.
- Consultant
- The Severyn Group, Inc.
- 21121 Stonecrop Place
- Ashburn, VA 20147
- Phone: (703) 723-0951
- Fax: (703) 858-9077
- E-mail: severyngroup@msn.com

- Jeannie Suarez-Reyes, M.P.H.
- Project Director
- Center for Consumers
- National Alliance for Hispanic Health
- 1501 16th Street, NW
- Washington, DC 20036
- Phone: (202) 797-4337
- Fax: (202) 797-4353
- E-mail: jsuarez-reyes@hispanichealth.org

- William W. Tipton, Jr., M.D.
- Executive Vice President
- American Academy of Orthopaedic Surgeons
- 6300 North River Road
- Rosemount, IL 60018
- Phone: (847) 823-7186
- Fax: (847) 823-8125
- E-mail: tipton@aaos.org

- Mehrdad Tondravi, M.D.
- Program Director
- Division of Diabetes, Endocrinology and Metabolic Diseases
- National Institute of Diabetes and Digestive and Kidney Diseases
- 6707 Democracy Boulevard, Room 603
- Bethesda, MD 20892-5460
- Phone: (301) 451-9871
- Fax: (301) 435-6047
- E-mail: mt270t@nih.gov

- Laura Tosi, M.D.
- Division Chief
- Orthopaedic Surgery and Sports Medicine
- Children’s National Medical Center
- 111 Michigan Avenue, NW
- Washington, DC 20010
- Phone: (202) 884-4063
- Fax: (202) 884-6520
- E-mail: ltosi@cnmc.org

- Anna N. Tosteson, Sc.D.
- Professor
- Departments of Medicine and Community and Family Medicine
- Dartmouth Medical School
- Clinical Research HB 7505
- One Medical Center Drive
- Lebanon, NH 03756
- Phone: (603) 650-6390
- Fax: (603) 650-8972
- E-mail: anna.tosteson@dartmouth.edu

- Wulf H. Utian, M.D., Ph.D.
- Executive Director
- North American Menopause Society
- 5900 Landerbrook Drive
- Mayfield Heights, OH 44124
- Phone: (440) 442-7680
- Fax: (440) 442-2660
- E-mail: utian@menopause.org

- Charlene Waldman
- Executive Director
- The Paget Foundation
- 120 Wall Street, Suite 1602
- New York, NY 10005
- Phone: (212) 509-5335
- Fax: (212) 509-8492
- E-mail: charlenewaldman@aol.com

- Nelson Watts, M.D.
- Director, Bone Health and Osteoporosis Center
- University of Cincinnati
- 222 Piedmont Avenue, Suite 4300
- Cincinnati, OH 45219
- Phone: (513) 475-7401
- Fax: (513) 475-7410
- E-mail: nelson.watts@uc.edu

- Connie M. Weaver, Ph.D.
- Distinguished Professor
- Department Head, Foods and Nutrition
- Purdue University
- 1264 Stone Hall
- 700 West State Street
- West Lafayette, IN 47907-2059
- Phone: (765) 494-8237
- Fax: (765) 494-0674
- E-mail: weavercm@cfs.purdue.edu

- Mike White
- Consultant, Michael F. White and Associates
- Women’s Health Council
- Association of State and Territorial Directors of Chronic Disease Programs
- 601 King Street, Suite 400
- Alexandria, VA 22314
- Phone: (703) 739-1363
- Fax: (703) 916-7495
- E-mail: mfwhite@earthlink.net

- Susan Whittier, M.H.A.
- Director
- NIH ORBD-NRC
- National Osteoporosis Foundation
- 1232 22nd Street, NW
- Washington, DC 20037
- Phone: (202) 721-6357
- Fax: (202) 293-2356
- E-mail: susanw@nof.org

- Michael P. Whyte, M.D.
- Professor of Medicine, Pediatrics, and Genetics
- Bone and Mineral Diseases
- Department of Medicine
- Barnes-Jewish Hospital at Washington University School of Medicine
- 216 South Kings Highway
- St. Louis, MO 63110
- Phone: (314) 454-7765
- Fax: (314) 872-8305
- E-mail: mwhyte@shrinenet.org

- Lynne Wilcox, M.D., M.P.H.
- Editor-in-Chief
- Preventing Chronic Disease
- National Center for Chronic Disease Prevention and Health Promotion
- Centers for Disease Control and Prevention
- U.S. Department of Health and Human Services
- 4770 Buford Highway, NE, Mail Stop K-40
- Atlanta, GA 30341
- Phone: (770) 488-5131
- Fax: (770) 488-5962
- E-mail: lwilcox@cdc.gov

- Betty H. Wiser, Ed.D.
- Director of Older Adult Health Branch
- Division of Public Health
- North Carolina Department of Health and Human Services
- 1915 Mail Service Center
- Raleigh, NC 27699-1915
- Phone: (919) 715-0122
- Fax: (919) 733-0488
- E-mail: betty.wiser@ncmail.net

- Susan Wood
- Director
- Office of Women’s Health
- Food and Drug Administration
- 5600 Fishers Lane, Room 1665, Mail Stop H8
- Rockville, MD 20857
- Phone: (301) 827-0350
- Fax: (301) 827-0926
- E-mail: swood1@oc.fda.gov