# Appendices

Appendix A Speaker Biographies

Appendix B Participant List

Appendix C Improving Bone Health: Comments from the Surgeon General's Web Site

Appendix D Acknowledgments