# Acknowledgments

This report was prepared by the U.S. Department of Health and Human Services under the general direction of the Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health.

- David Satcher, M.D., Ph.D.,
- Surgeon General,
- Office of Public Health and Science,
- Office of the Secretary,
- Washington, D.C.

- Jeffrey P. Koplan, M.D., M.P.H.,
- Director,
- Centers for Disease Control and Prevention,
- Atlanta, Georgia.

- James S. Marks, M.D., M.P.H.,
- Director,
- National Center for Chronic Disease Prevention and Health Promotion,
- Centers for Disease Control and Prevention,
- Atlanta, Georgia.

- Lawrence W. Green, Dr.P.H.,
- Acting Director,
- Office on Smoking and Health,
- National Center for Chronic Disease Prevention and Health Promotion,
- Centers for Disease Control and Prevention,
- Atlanta, Georgia.

- Nicole Lurie, M.D., M.S.P.H.,
- Principal Deputy Assistant Secretary for Health,
- Office of Public Health and Science,
- Office of the Secretary,
- Washington, D.C.

- Beverly L. Malone, Ph.D., R.N., F.A.A.N.,
- Deputy Assistant Secretary for Health,
- Office of Public Health and Science,
- Office of the Secretary,
- Washington, D.C.

- Arthur Lawrence, Ph.D., R.Ph.,
- Assistant Surgeon General,
- U.S. Public Health Service and Deputy Assistant Secretary for Health (Operations),
- Office of Public Health and Science,
- Office of the Secretary,
- Washington, D.C.

- Kenneth Moritsugu, M.D., M.P.H.,
- Deputy Surgeon General,
- U.S. Public Health Service,
- Office of the Surgeon General,
- Office of the Secretary,
- Washington, D.C.

- Allan S. Noonan, M.D., M.P.H., CAPT,
- Senior Advisor,
- U.S. Public Health Service,
- Office of the Surgeon General,
- Office of the Secretary,
- Washington, D.C.

Special thanks to

- Michael P. Eriksen, Sc.D.,
- Centers for Disease Control and Prevention Assignee to the World Health Organization,
- Geneva, Switzerland.

- Elizabeth Majestic, M.P.H.,
- Associate Director for Planning, Evaluation, and Legislation,
- National Center for Chronic Disease Prevention and Health Promotion,
- Centers for Disease Control and Prevention,
- Atlanta, Georgia.

- Terry F. Pechacek, Ph.D.,
- Associate Director for Science,
- Office on Smoking and Health,
- National Center for Chronic Disease Prevention and Health Promotion,
- Centers for Disease Control and Prevention,
- Atlanta, Georgia.

The editors of the report were

- Virginia L. Ernster, Ph.D.,
- Senior Scientific Editor, Professor and Vice Chair,
- Department of Epidemiology and Biostatistics and Associate Director for Epidemiology, Prevention, and Control,
- UCSF Comprehensive Cancer Center,
- University of California,
- San Francisco, California.

- Gayle Lloyd, M.A.,
- Managing Editor, Office on Smoking and Health,
- National Center for Chronic Disease Prevention and Health Promotion,
- Centers for Disease Control and Prevention,
- Atlanta, Georgia.

- Leslie A. Norman,
- Managing Editor,
- Office on Smoking and Health,
- National Center for Chronic Disease Prevention and Health Promotion,
- Centers for Disease Control and Prevention,
- Atlanta, Georgia.

- Anne McCarthy,
- Technical Editor,
- Consultant to Palladian Partners, Inc.,
- Silver Spring, Maryland.

- Audrey L. Pinto,
- Technical Medical Writer and Editor,
- Consultant to Palladian Partners, Inc.,
- Silver Spring, Maryland.

Contributing editors were

- David G. Altman, Ph.D.,
- Professor, Department of Public Health Sciences,
- Wake Forest University School of Medicine,
- Winston-Salem, North Carolina.

- John A. Baron, M.D.,
- Professor, Department of Medicine and Community and Family Medicine,
- Dartmouth Medical School,
- Hanover, New Hampshire.

- Ellen R. Gritz, Ph.D.,
- Professor and Chair, Frank T. McGraw Memorial Chair in the Study of Cancer, Department of Behavioral Science,
- The University of Texas,
- M. D. Anderson Cancer Center,
- Houston, Texas.

- Corinne G. Husten, M.D., M.P.H.,
- Chief, Epidemiology Branch,
- Office on Smoking and Health,
- National Center for Chronic Disease Prevention and Health Promotion,
- Centers for Disease Control and Prevention,
- Atlanta, Georgia.

- Richard B. Rothenberg, M.D., M.P.H.,
- Professor, Department of Family and Preventive Medicine,
- Emory University School of Medicine,
- Atlanta, Georgia.

- Beti Thompson, Ph.D.,
- Member, Fred Hutchinson Cancer Research Center,
- Seattle, Washington.

Contributing authors were

- David G. Altman, Ph.D.,
- Professor, Department of Public Health Sciences,
- Wake Forest University School of Medicine,
- Winston-Salem, North Carolina.

- Amanda Amos, Ph.D.,
- Senior Lecturer in Health Promotion, Public Health Sciences,
- Department of Community Health Sciences,
- University of Edinburgh Medical School,
- Edinburgh, United Kingdom.

- John A. Baron, M.D.,
- Professor, Department of Medicine and Community and Family Medicine,
- Dartmouth Medical School,
- Hanover, New Hampshire.

- Neal Benowitz, M.D.,
- Professor of Medicine, Psychiatry, and Biopharmaceutical Sciences,
- University of California,
- and Chief, Clinical Pharmacology,
- San Francisco General Hospital,
- San Francisco, California.

- Lois Biener, Ph.D.,
- Senior Research Fellow, Center for Survey Research,
- University of Massachusetts,
- Boston, Massachusetts.

- William J. Blot, Ph.D.,
- Chief Executive Officer,
- International Epidemiology Institute, Ltd.,
- Rockville, Maryland.

- Edward J. Boyko, M.D., M.P.H.,
- Professor of Medicine, University of Washington and
- Director, Epidemiologic Research and Information Center,
- Veterans Affairs Puget Sound Health Care System,
- Seattle, Washington.

- Louise A. Brinton, Ph.D.,
- Chief, Environmental Epidemiology Branch,
- National Cancer Institute,
- Bethesda, Maryland.

- David N. Burns, M.D., M.P.H.,
- Medical Officer, Pediatric, Adolescent, and Maternal AIDS Branch,
- Center for Research for Mothers and Children,
- National Institute of Child Health and Human Development,
- Bethesda, Maryland.

- Graham A. Colditz, M.D., Dr.P.H.,
- Professor of Medicine, Channing Laboratory, School of Medicine,
- Harvard University,
- Boston, Massachusetts.

- David B. Coultas, M.D.,
- Professor of Internal Medicine and Chief, Division of Epidemiology and Preventive Medicine,
- School of Medicine,
- University of New Mexico,
- Albuquerque, New Mexico.

- Alyssa N. Easton, Ph.D., M.P.H.,
- Epidemiologist, Office on Smoking and Health,
- National Center for Chronic Disease Prevention and Health Promotion,
- Centers for Disease Control and Prevention,
- Atlanta, Georgia.

- Brenda Eskenazi, Ph.D.,
- Professor of Maternal and Child Health and Epidemiology Director,
- Center for Children's Environmental Health Research,
- School of Public Health,
- University of California,
- Berkeley, California.

- Edwin B. Fisher, Ph.D.,
- Professor of Psychology, Medicine, and Pediatrics and
- Head, Division of Health Behavior Research,
- Departments of Medicine and Pediatrics,
- Washington University,
- St. Louis, Missouri.

- Brian R. Flay, D.Phil.,
- Director, Health Research and Policy Centers,
- Chicago, Illinois.

- Brian S. Flynn, Sc.D.,
- Research Professor and Director, Office of Health Promotion Research,
- College of Medicine,
- University of Vermont,
- Burlington, Vermont.

- Elizabeth T. Fontham, Dr.P.H.,
- Professor and Chairman, Department of Public Health and Preventive Medicine,
- Louisiana State University Health Science Center,
- New Orleans, Louisiana.

- Elizabeth A. Gilpin, M.S.,
- Clinical Professor of Biostatistics and Director, Biostatistics Shared Resource,
- University of California at San Diego Cancer Center,
- La Jolla, California.

- Deborah Grady, M.D.,
- Professor and Vice Chair, Department of Epidemiology and Biostatistics and Department of Medicine,
- University of California,
- San Francisco, California.

- Andrew Grandinetti, Ph.D.,
- Assistant Researcher, Pacific Biomedical Research Center,
- University of Hawaii at Manoa,
- Honolulu, Hawaii.

- Sharon M. Hall, Ph.D.,
- Professor and Vice-Chair, Psychiatry, Department of Psychiatry,
- University of California,
- San Francisco, California.

- Dorothy Hatsukami, Ph.D.,
- Professor, Department of Psychiatry,
- University of Minnesota,
- Minneapolis, Minnesota.

- S. Jane Henley, M.S.P.H.,
- Epidemiologist, Department of Epidemiology and Surveillance Research,
- American Cancer Society,
- Atlanta, Georgia.

- Frank B. Hu, M.D., Ph.D.,
- Assistant Professor, Department of Nutrition,
- Harvard School of Public Health,
- Boston, Massachusetts.

- Corinne G. Husten, M.D., M.P.H.,
- Chief, Epidemiology Branch, Office on Smoking and Health,
- National Center for Chronic Disease Prevention and Health Promotion,
- Centers for Disease Control and Prevention,
- Atlanta, Georgia.

- Nancy J. Kaufman, R.N., M.S.,
- Vice President, The Robert Wood Johnson Foundation,
- Princeton, New Jersey.

- Ichiro Kawachi, M.D., Ph.D.,
- Assistant Professor of Medicine, Channing Laboratory, School of Medicine and
- Associate Professor of Health and Social Behavior,
- School of Public Health,
- Harvard University,
- Boston, Massachusetts.

- Robert C. Klesges, Ph.D.,
- Executive Director, University of Memphis Center for Community Health,
- University of Memphis,
- Memphis, Tennessee.

- Edward Lichtenstein, Ph.D.,
- Senior Research Scientist, Oregon Research Institute,
- Eugene, Oregon.

- Alan D. Lopez, Ph.D.,
- Epidemiologist, Prevention, Advocacy and Promotion,
- Programme on Substance Abuse,
- World Health Organization,
- Geneva, Switzerland.

- Everly Macario, M.S., Ed.M.,
- Associate Professor, Department of Health and Social Behavior,
- Harvard School of Public Health,
- Boston, Massachusetts.

- Judith Mackay, MBE, FRCP (Edin), FRCP (Lon), FHKAM,
- Director, Asian Consultancy on Tobacco Control,
- Hong Kong, China.

- Nejma Macklai,
- Epidemiologist, Tobacco-Free Initiative,
- World Health Organization,
- Geneva, Switzerland.

- Ann M. Malarcher, Ph.D.,
- Epidemiologist, Division of Chronic Disease Control and Community Intervention,
- National Center for Chronic Disease Prevention and Health Promotion,
- Centers for Disease Control and Prevention,
- Atlanta, Georgia.

- Ruth E. Malone, R.N., Ph.D.,
- Assistant Professor of Nursing and Health Policy,
- Institute for Health Policy Studies and Department of Physiological Nursing,
- University of California,
- San Francisco, California.

- Joseph K. McLaughlin, Ph.D.,
- President, International Epidemiology Institute, Ltd.,
- Rockville, Maryland.

- Deborah L. McLellan, M.H.S.,
- Assistant Director, Center for Community Based Research,
- Division of Population Sciences,
- Dana-Farber Cancer Institute,
- Boston, Massachusetts.

- Robert K. Merritt, M.A.,
- Health Scientist, Division of Reproductive Health,
- National Center for Chronic Disease Prevention and Health Promotion,
- Centers for Disease Control and Prevention,
- Atlanta, Georgia.

- Sherry L. Mills, M.D., M.P.H.,
- Chief, Applied Sociocultural Research Branch,
- Behavioral Research Program,
- Division of Cancer Control and Population Studies,
- National Cancer Institute,
- Bethesda, Maryland.

- Micah H. Milton, M.P.H.,
- Behavioral Scientist, Office on Smoking and Health,
- National Center for Chronic Disease Prevention and Health Promotion,
- Centers for Disease Control and Prevention,
- Atlanta, Georgia.

- Heidi L. Miracle-McMahill, M.S.P.H.,
- Epidemiologist, Department of Epidemiology and Surveillance Research,
- American Cancer Society,
- Atlanta, Georgia.

- Patricia Dolan Mullen, Dr.P.H.,
- Professor of Behavioral Sciences and Health Education and Training Director,
- Center for Health Promotion and Prevention Research,
- University of Texas Science Center at Houston School of Public Health,
- Houston, Texas.

- Judith K. Ockene, Ph.D.,
- Professor of Medicine and Chief, Division of Preventive and Behavioral Medicine,
- Department of Medicine,
- University of Massachusetts Medical School,
- Worcester, Massachusetts.

- C. Tracy Orleans, Ph.D.,
- Senior Scientist, The Robert Wood Johnson Foundation,
- Princeton, New Jersey.

- Kathyrn Osann, Ph.D., M.P.H.,
- Associate Adjunct Professor, Division of Hematology and Oncology,
- Department of Medicine,
- College of Medicine,
- University of California,
- Irvine, California.

- John Petraitis, Ph.D.,
- Associate Professor, Department of Psychology,
- University of Alaska,
- Anchorage, Alaska.

- Phyllis Pirie, Ph.D.,
- Professor, Division of Epidemiology,
- School of Public Health,
- University of Minnesota,
- Minneapolis, Minnesota.

- Richard W. Pollay, Ph.D.,
- Professor of Marketing and Curator, History of Advertising Archives,
- Faculty of Commerce,
- University of British Columbia,
- Vancouver, British Columbia, Canada.

- Cynthia S. Pomerleau, Ph.D.,
- Senior Associate Research Scientist and Director, Nicotine Research Laboratory,
- Department of Psychiatry,
- University of Michigan,
- Ann Arbor, Michigan.

- Alex V. Prokhorov, M.D., Ph.D.,
- Associate Professor, Department of Behavioral Science,
- The University of Texas,
- M.D. Anderson Cancer Center,
- Houston, Texas.

- Herbert H. Severson, Ph.D.,
- Senior Research Scientist, Oregon Research Institute and Associate Professor of Counseling Psychology,
- College of Education,
- University of Oregon,
- Eugene, Oregon.

- Dana M. Shelton, M.P.H.,
- Assistant Director for Policy, Planning, and External Relations, Division of STD Prevention,
- National Center for HIV, STD, and TB Prevention,
- Centers for Disease Control and Prevention,
- Atlanta, Georgia.

- Laura Solomon, Ph.D.,
- Research Professor, Department of Psychology,
- University of Vermont,
- Burlington, Vermont.

- Glorian Sorensen, Ph.D., M.P.H.,
- Director, Community Based Research,
- Division of Cancer, Epidemiology, and Control,
- Dana-Farber Cancer Institute and Professor of Health and Social Behavior,
- Department of Health and Social Behavior,
- Harvard School of Public Health,
- Boston, Massachusetts.

- Margaret Spitz, M.D.,
- Chairman, Department of Epidemiology,
- The University of Texas,
- M.D. Anderson Cancer Center,
- Houston, Texas.

- Beti Thompson, Ph.D.,
- Member, Fred Hutchinson Cancer Research Center,
- Seattle, Washington.

- Michael J. Thun, M.D.,
- Vice President, Epidemiology and Surveillance Research,
- American Cancer Society,
- Atlanta, Georgia.

- Suzanne Tyas, Ph.D.,
- Postdoctoral Fellow, Centre on Aging,
- University of Manitoba,
- Winnipeg, Manitoba, Canada.

- Kenneth D. Ward, Ph.D.,
- Assistant Professor, University of Memphis Prevention Center,
- Memphis, Tennessee.

- Elisabete Weiderpass, M.D., M.Sc., Ph.D.,
- Associate Professor, Department of Medical Epidemiology,
- Karolinska Institutet,
- Stockholm, Sweden.

- Gayle Windham, Ph.D.,
- Senior Epidemiologist, Division of Environmental and Occupational Disease Control,
- California Department of Health Services,
- Oakland, California.

- Anna H. Wu, Ph.D.,
- Professor, Keck School of Medicine,
- Department of Preventive Medicine,
- Norris Comprehensive Cancer Center,
- University of Southern California,
- Los Angeles, California.

Reviewers were

- Duane Alexander, M.D.,
- Director, National Institute of Child Health and Human Development,
- National Institutes of Health,
- Bethesda, Maryland.

- Robert Barbieri, M.D.,
- Chairman, Department of Obstetrics and Gynecology,
- Brigham and Women's Hospital,
- Boston, Massachusetts.

- Glen Bennett, M.P.H.,
- Coordinator, Advanced Technologies Applications in Health Education,
- Office of Prevention, Education, and Control,
- National Heart, Lung, and Blood Institute,
- National Institutes of Health,
- Bethesda, Maryland.

- Michelle Bloch, M.D., Ph.D.,
- Medical Officer, Tobacco Control Research Branch,
- Division of Cancer Control and Population Sciences,
- National Cancer Institute,
- National Institutes of Health,
- Rockville, Maryland.

- Gilbert J. Botvin, Ph.D.,
- Professor and Director, Institute for Prevention Research,
- Department of Public Health,
- Cornell University Medical College,
- New York, New York.

- Michael B. Bracken, Ph.D.,
- Professor and Head, Division of Chronic Disease Epidemiology,
- Department of Epidemiology and Public Health,
- Yale University School of Medicine,
- New Haven, Connecticut.

- David M. Burns, M.D.,
- Professor of Medicine, Tobacco Control Policies Project,
- University of California,
- San Diego, California.

- Olivia Carter-Pokras, Ph.D.,
- Director, Division of Policy and Data,
- Office of Minority Health,
- Rockville, Maryland.

- Jane A. Cauley, Dr.P.H.,
- Associate Professor, Department of Epidemiology,
- University of Pittsburgh,
- Pittsburgh, Pennsylvania.

- Sven Cnattingius, M.D., Ph.D.,
- Professor, Department of Medical Epidemiology,
- Karolinska Institutet,
- Stockholm, Sweden.

- Daniel W. Cramer, M.D., Sc.D.,
- Professor of Obstetrics, Gynecology, and Reproductive Biology,
- Harvard University Medical School,
- Boston, Massachusetts.

- Byron L. Cryer, M.D.,
- Associate Professor of Medicine,
- University of Texas Southwestern Medical Center,
- Veterans Affairs Medical Center,
- Dallas, Texas.

- K. Michael Cummings, Ph.D., M.P.H.,
- Chairman and Senior Scientist, Department of Cancer Prevention,
- Epidemiology, and Biostatistics,
- Roswell Park Cancer Institute,
- Buffalo, New York.

- Susan Curry, Ph.D.,
- Director, Center for Health Studies,
- Group Health Cooperative,
- Seattle, Washington.

- Ronald M. Davis, M.D.,
- Director, Center for Health Promotion and Disease Prevention,
- Henry Ford Health System,
- Detroit, Michigan.

- Andrew K. Diehl, M.D., M.Sc.,
- Professor and Chief, Division of General Medicine,
- Department of Medicine,
- University of Texas Health Science Center,
- San Antonio, Texas.

- Jeffrey L. Fellows, Ph.D.,
- Health Economist, Office on Smoking and Health,
- National Center for Chronic Disease Prevention and Health Promotion,
- Centers for Disease Control and Prevention,
- Atlanta, Georgia.

- David Felson, M.D., M.P.H.,
- Professor of Medicine and Public Health, The Arthritis Center,
- School of Medicine,
- Boston University,
- Boston, Massachusetts.

- Roberta G. Ferrence, Ph.D.,
- Director, Ontario Tobacco Research Unit,
- University of Toronto,
- Toronto, Ontario, Canada.

- Frederick L. Ferris III, M.D.,
- Director, Division of Epidemiology and Clinical Research,
- Clinical Director, National Eye Institute,
- National Institutes of Health,
- Bethesda, Maryland.

- Gary A. Giovino, Ph.D., M.S.,
- Senior Research Scientist, Department of Cancer Prevention, Epidemiology, and Biostatistics,
- Roswell Park Cancer Institute,
- Buffalo, New York.

- Alexander H. Glassman, M.D.,
- Professor of Clinical Psychiatry, Department of Psychiatry,
- College of Physicians and Surgeons,
- Columbia University,
- New York, New York.

- Thomas J. Glynn, Ph.D.,
- Director, Cancer Science and Trends,
- American Cancer Society,
- Washington, D.C.

- Amy Borenstein Graves, Ph.D., M.P.H.,
- Associate Professor, Department of Epidemiology and Biostatistics,
- College of Public Health,
- University of South Florida,
- Tampa, Florida.

- Lorraine Greaves, Ph.D.,
- Executive Director, British Columbia Centre of Excellence for Women's Health,
- British Columbia Women's Hospital,
- Vancouver, British Columbia, Canada.

- Betty Lee Hawks, M.A.,
- Special Assistant to the Director, Office of Minority Health,
- U.S. Department of Health and Human Services,
- Rockville, Maryland.

- Jack E. Henningfield, Ph.D.,
- Associate Professor, Department of Psychiatry and Behavioral Sciences,
- The Johns Hopkins University School of Medicine,
- Bethesda, Maryland.

- Marc C. Hochberg, M.D., M.P.H.,
- Professor of Medicine and Epidemiology and Preventive Medicine,
- University of Maryland School of Medicine,
- Baltimore, Maryland.

- John R. Hughes, M.D.,
- Professor, Human Behavioral Pharmacology Laboratory,
- Department of Psychiatry,
- University of Vermont,
- Burlington, Vermont.

- Wanda K. Jones, Dr.P.H.,
- Deputy Assistant Secretary for Health (Women's Health),
- Office on Women's Health,
- Washington, D.C.

- Donald Kadunce, M.D.,
- Assistant Professor, Department of Dermatology,
- University of Utah,
- Salt Lake City, Utah.

- Denise Kandel, Ph.D.,
- Professor of Public Health in Psychiatry, Department of Psychiatry,
- College of Physicians and Surgeons of Columbia University and
- Chief, Department on the Epidemiology of Substance Abuse,
- New York State Psychiatric Institute,
- New York, New York.

- Ichiro Kawachi, M.D., Ph.D.,
- Assistant Professor of Medicine, Channing Laboratory,
- School of Medicine and Associate Professor of Health and Social Behavior,
- School of Public Health,
- Harvard University,
- Boston, Massachusetts.

- Kay-Tee Khaw,
- Professor, Clinical Gerontology Unit,
- University of Cambridge,
- Cambridge, United Kingdom.

- Douglas P. Kiel, M.D., M.P.H.,
- Director for Medical Research, Hebrew Rehabilitation Center for Aged,
- Research and Training Institute and
- Associate Professor, Division on Aging,
- Harvard Medical School,
- Boston, Massachusetts.

- Barbara Eden Kobrin Klein, M.D., M.P.H.,
- Professor, Department of Ophthalmology and Visual Sciences,
- Department of Preventive Medicine,
- School of Medicine,
- University of Wisconsin,
- Madison, Wisconsin.

- Lewis H. Kuller, M.D., Dr.P.H.,
- University Professor of Public Health and Professor and Chair, Department of Epidemiology,
- Graduate School of Public Health,
- University of Pittsburgh,
- Pittsburgh, Pennsylvania.

- John H. Kurata, Ph.D., M.P.H.,
- Chief, Chronic Disease Epidemiology Section,
- California Department of Health Services,
- Sacramento, California.

- Carlo La Vecchia, M.D.,
- Laboratory of Epidemiology,
- Mario Negri Institute for Pharmacological Research and University of Milan,
- Milan, Italy.

- Darwin R. Labarthe, M.D., Ph.D.,
- James W. Rockwell Professor of Public Health, School of Public Health,
- The University of Texas-Houston,
- Health Science Center,
- Houston, Texas.

- Harry A. Lando, Ph.D.,
- Professor, Division of Epidemiology,
- School of Public Health,
- University of Minnesota,
- Minneapolis, Minnesota.

- Douglas S. Lloyd, M.D., M.P.H.,
- HRSASenior Scholar, Association of Schools of Public Health,
- Washington, D.C.

- Richard Logan, B.Sc., MBChB, M.Sc., MFPHM, FRCP, FRCPE,
- Professor of Clinical Epidemiology, Division of Public Health and Epidemiology,
- University of Nottingham,
- Queens Medical Centre,
- Nottingham, England.

- Alexander H. Glassman, M.D.,
- Professor of Clinical Psychiatry, Department of Psychiatry,
- College of Physicians and Surgeons,
- Columbia University,
- New York, New York.

- Thomas J. Glynn, Ph.D.,
- Director, Cancer Science and Trends,
- American Cancer Society,
- Washington, D.C.

- Amy Borenstein Graves, Ph.D., M.P.H.,
- Associate Professor, Department of Epidemiology and Biostatistics,
- College of Public Health,
- University of South Florida,
- Tampa, Florida.

- Lorraine Greaves, Ph.D.,
- Executive Director, British Columbia Centre of Excellence for Women's Health,
- British Columbia Women's Hospital,
- Vancouver, British Columbia, Canada.

- Betty Lee Hawks, M.A.,
- Special Assistant to the Director, Office of Minority Health,
- U.S. Department of Health and Human Services,
- Rockville, Maryland.

- Jack E. Henningfield, Ph.D.,
- Associate Professor, Department of Psychiatry and Behavioral Sciences,
- The Johns Hopkins University School of Medicine,
- Bethesda, Maryland.

- Marc C. Hochberg, M.D., M.P.H.,
- Professor of Medicine and Epidemiology and Preventive Medicine,
- University of Maryland School of Medicine,
- Baltimore, Maryland.

- John R. Hughes, M.D.,
- Professor, Human Behavioral Pharmacology Laboratory,
- Department of Psychiatry,
- University of Vermont,
- Burlington, Vermont.

- Wanda K. Jones, Dr.P.H.,
- Deputy Assistant Secretary for Health (Women's Health), Office on Women's Health,
- Washington, D.C.

- Donald Kadunce, M.D.,
- Assistant Professor, Department of Dermatology,
- University of Utah,
- Salt Lake City, Utah.

- Denise Kandel, Ph.D.,
- Professor of Public Health in Psychiatry, Department of Psychiatry,
- College of Physicians and Surgeons of Columbia University and
- Chief, Department on the Epidemiology of Substance Abuse,
- New York State Psychiatric Institute,
- New York, New York.

- Ichiro Kawachi, M.D., Ph.D.,
- Assistant Professor of Medicine, Channing Laboratory,
- School of Medicine and
- Associate Professor of Health and Social Behavior, School of Public Health,
- Harvard University,
- Boston, Massachusetts.

- Kay-Tee Khaw,
- Professor, Clinical Gerontology Unit,
- University of Cambridge,
- Cambridge, United Kingdom.

- Douglas P. Kiel, M.D., M.P.H.,
- Director for Medical Research, Hebrew Rehabilitation Center for Aged,
- Research and Training Institute and
- Associate Professor, Division on Aging,
- Harvard Medical School,
- Boston, Massachusetts.

- Barbara Eden Kobrin Klein, M.D., M.P.H.,
- Professor, Department of Ophthalmology and Visual Sciences,
- Department of Preventive Medicine,
- School of Medicine,
- University of Wisconsin,
- Madison, Wisconsin.

- Lewis H. Kuller, M.D., Dr.P.H.,
- University Professor of Public Health and Professor and Chair, Department of Epidemiology,
- Graduate School of Public Health,
- University of Pittsburgh,
- Pittsburgh, Pennsylvania.

- John H. Kurata, Ph.D., M.P.H.,
- Chief, Chronic Disease Epidemiology Section,
- California Department of Health Services,
- Sacramento, California.

- Carlo La Vecchia, M.D.,
- Laboratory of Epidemiology,
- Mario Negri Institute for Pharmacological Research and University of Milan,
- Milan, Italy.

- Darwin R. Labarthe, M.D., Ph.D.,
- James W. Rockwell Professor of Public Health, School of Public Health,
- The University of Texas-Houston,
- Health Science Center,
- Houston, Texas.

- Harry A. Lando, Ph.D.,
- Professor, Division of Epidemiology,
- School of Public Health,
- University of Minnesota,
- Minneapolis, Minnesota.

- Douglas S. Lloyd, M.D., M.P.H.,
- HRSASenior Scholar, Association of Schools of Public Health,
- Washington, D.C.

- Richard Logan, B.Sc., MBChB, M.Sc., MFPHM, FRCP, FRCPE,
- Professor of Clinical Epidemiology, Division of Public Health and Epidemiology,
- University of Nottingham,
- Queens Medical Centre,
- Nottingham, England.

- Marc Manley, M.D., M.P.H.,
- Special Assistant for Tobacco Policy, National Cancer Institute,
- National Institutes of Health,
- Rockville, Maryland.

- Sonja M. McKinlay, Ph.D.,
- President, New England Research Institutes, Inc.,
- Watertown, Massachusetts.

- Robin Mermelstein, Ph.D.,
- Deputy Director, Health Research and Policy Centers and Department of Psychology,
- University of Illinois,
- Chicago, Illinois.

- Linda D. Meyers, Ph.D.,
- Deputy Director, Office of Disease Prevention and Health Promotion,
- Washington, D.C.

- Kenneth Moritsugu, M.D., M.P.H.,
- Deputy Surgeon General, U.S. Public Health Service,
- Office of the Surgeon General,
- Office of the Secretary,
- Washington, D.C.

- Polly A. Newcomb, Ph.D., M.P.H.,
- Member, Fred Hutchinson Cancer Research Center,
- Seattle, Washington, and
- Senior Scientist,
- University of Wisconsin,
- Madison, Wisconsin.

- Patrick O'Malley, Ph.D.,
- Research Scientist, Institute for Social Research,
- University of Michigan,
- Ann Arbor, Michigan.

- Regina Otero-Sabogal, Ph.D.,
- Associate Adjunct Professor, Institute for Health and Aging,
- University of California,
- San Francisco, California.

- Nancy S. Padian, Ph.D.,
- Co-Director, Center for Reproductive Health Research and Policy and
- Professor, Department of Obstetrics, Gynecology, and Reproductive Sciences,
- University of California,
- San Francisco, California.

- Julie R. Palmer, Sc.D.,
- Associate Professor, Slone Epidemiology Unit,
- Boston University School of Medicine,
- Brookline, Massachusetts.

- Donald Maxwell Parkin, M.D.,
- Chief, Unit of Descriptive Epidemiology,
- International Agency for Research on Cancer,
- Lyon, France.

- Terry F. Pechacek, Ph.D.,
- Associate Director for Science, Office on Smoking and Health,
- National Center for Chronic Disease Prevention and Health Promotion,
- Centers for Disease Control and Prevention,
- Atlanta, Georgia.

- Linda L. Pederson, Ph.D.,
- Visiting Scientist, Office on Smoking and Health,
- National Center for Chronic Disease Prevention and Health Promotion,
- Centers for Disease Control and Prevention,
- Atlanta, Georgia.

- Cheryl L. Perry, Ph.D.,
- Professor, Division of Epidemiology,
- School of Public Health,
- University of Minnesota,
- Minneapolis, Minnesota.

- Göran Pershagen, M.D., Ph.D.,
- Professor, Institute of Environmental Medicine,
- Karolinska Institutet,
- Stockholm, Sweden.

- Richard Peto, FRS,
- Professor, University of Oxford,
- Clinical Trial Service Unit,
- Radcliffe Infirmary,
- Oxford, England.

- Diana B. Pettiti, M.D., M.P.H.,
- Director, Department of Research and Evaluation,
- Kaiser Permanente of Southern California,
- Pasadena, California.

- John Pierce, Ph.D.,
- Professor, Cancer Prevention and Control,
- University of California at San Diego,
- La Jolla, California.

- Vivian Pinn, M.D.,
- Associate Director for Research on Women's Health,
- National Institutes of Health,
- Bethesda, Maryland.

- Ovide Pomerleau, Ph.D.,
- Director, Behavioral Medicine Program,
- Department of Psychiatry,
- University of Michigan School of Medicine,
- Ann Arbor, Michigan.

- Patrick L. Remington, M.D., M.P.H.,
- Associate Professor, Department of Preventive Medicine,
- University of Wisconsin Medical School,
- Madison, Wisconsin.

- Nancy A. Rigotti, M.D.,
- Director, Tobacco Treatment and Research Center,
- Massachusetts General Hospital and
- Associate Professor of Medicine,
- Harvard Medical School,
- Boston, Massachusetts.

- Barbara K. Rimer, Dr.P.H.,
- Director, Division of Cancer Control and Population Sciences,
- National Cancer Institute,
- National Institutes of Health,
- Rockville, Maryland.

- Thomas Rohan, M.D.,
- Professor and Chairman, Department of Epidemiology and Social Medicine,
- Albert Einstein College of Medicine,
- Bronx, New York.

- Elaine Ron, Ph.D.,
- Chief, Radiation Epidemiology Branch,
- National Cancer Institute,
- National Institutes of Health,
- Bethesda, Maryland.

- Lynn Rosenberg, Sc.D.,
- Associate Director, Slone Epidemiology Unit,
- Brookline, Massachusetts, and
- Professor, School of Public Health,
- Boston University,
- Boston, Massachusetts.

- Michael J. Rosenberg, M.D., M.P.H.,
- President, Health Decisions, Inc.,
- Chapel Hill, North Carolina.

- Rosemary Rosso, J.D.,
- Senior Attorney, Division of Advertising Practices,
- Federal Trade Commission,
- Washington, D.C.

- Richard B. Rothenberg, M.D., M.P.H.,
- Professor, Department of Family and Preventive Medicine,
- Emory University School of Medicine,
- Atlanta, Georgia.

- Jonathan M. Samet, M.D., M.S.,
- Professor and Chairman, Department of Epidemiology,
- School of Hygiene and Public Health,
- The Johns Hopkins University,
- Baltimore, Maryland.

- Ulonda Shamwell, M.S.W.,
- Associate Administrator for Women's Services,
- Substance Abuse and Mental Health Services Administration,
- Rockville, Maryland.

- Donald R. Shopland,
- Coordinator, Smoking and Tobacco Control Program,
- National Cancer Institute,
- National Institutes of Health,
- Rockville, Maryland.

- Nelson K. Steenland, Ph.D.,
- Senior Epidemiologist, Division of Surveillance, Hazard Evaluations, and Field Studies,
- National Institute for Occupational Safety and Health,
- Centers for Disease Control and Prevention,
- Cincinnati, Ohio.

- Robert S. Stern, M.D.,
- Carl J. Herzog Professor of Dermatology,
- Harvard Medical School at Beth Israel Deaconess Medical Center,
- Boston, Massachusetts.

- Scott L. Tomar, D.M.D., Dr.P.H.,
- Epidemiologist, Division of Oral Health,
- National Center for Chronic Disease Prevention and Health Promotion,
- Centers for Disease Control and Prevention,
- Atlanta, Georgia.

- Dimitrios Trichopoulos, M.D.,
- Vincent L. Gregory Professor of Cancer Prevention and Professor of Epidemiology,
- School of Public Health,
- Harvard University,
- Boston, Massachusetts.

- Jaylan Turkkan, Ph.D.,
- Chief, Behavioral Sciences Research Branch,
- National Institute on Drug Abuse,
- National Institutes of Health,
- Rockville, Maryland.

- K. M. Venkat Narayan, M.D.,
- Chief, Epidemiology Section,
- Epidemiology and Statistics Branch,
- Division of Diabetes Translation,
- National Center for Chronic Disease Prevention and Health Promotion,
- Centers for Disease Control and Prevention,
- Atlanta, Georgia.

- Ingrid Waldron, Ph.D.,
- Professor of Biology, Department of Biology,
- University of Pennsylvania,
- Philadelphia, Pennsylvania.

- Kenneth E. Warner, Ph.D.,
- Richard D. Remington Collegiate Professor of Public Health,
- Department of Health Management and Policy,
- School of Public Health,
- University of Michigan and Director,
- University of Michigan Tobacco Research Network,
- Ann Arbor, Michigan.

- Walter C. Willett, M.D., Dr.P.H.,
- Professor of Epidemiology and Nutrition and
- Chair, Department of Nutrition,
- Harvard School of Public Health,
- Boston, Massachusetts.

- Gayle Windham, Ph.D.,
- Senior Epidemiologist, Division of Environmental and Occupational Disease Control,
- California Department of Health Services,
- Oakland, California.

- Warren Winkelstein, Jr., M.D., M.P.H.,
- Professor Emeritus of Epidemiology,
- Division of Public Health, Biology, and Epidemiology,
- School of Public Health,
- University of California,
- Berkeley, California.

- Anna H. Wu, Ph.D.,
- Professor, Keck School of Medicine,
- Department of Preventive Medicine,
- Norris Comprehensive Cancer Center,
- University of Southern California,
- Los Angeles, California.

- Mitchell R. Zeller, J.D.,
- Director, Office of Tobacco Programs,
- Food and Drug Administration,
- Rockville, Maryland.

Other contributors were

- Kathleen Adams, Ph.D.,
- Associate Professor, Rollins School of Public Health,
- Emory University and
- Health Economist, Division of Reproductive Health,
- National Center for Chronic Disease Prevention and Health Promotion,
- Centers for Disease Control and Prevention,
- Atlanta, Georgia.

- Harmony Allison, M.P.H.,
- Visiting Fellow, Office on Smoking and Health,
- National Center for Chronic Disease Prevention and Health Promotion,
- Centers for Disease Control and Prevention,
- Atlanta, Georgia.

- Felicia M. Barlow,
- Project Coordinator, Palladian Partners, Inc.,
- Silver Spring, Maryland.

- Trudy Barnes,
- Project Coordinator, Palladian Partners, Inc.,
- Silver Spring, Maryland.

- Lara Boeck,
- Proofreader, Palladian Partners, Inc.,
- Silver Spring, Maryland.

- Alison Brown,
- Graphic Artist, Palladian Partners, Inc.,
- Silver Spring, Maryland.

- Tavian K. Cardwell,
- Graphic Artist, Palladian Partners, Inc.,
- Silver Spring, Maryland.

- Christine Choy,
- Administrative Assistant, Department of Epidemiology and Biostatistics,
- University of California,
- San Francisco, California.

- Robyn Ertwine,
- Indexer, Palladian Partners, Inc.,
- Silver Spring, Maryland.

- Luis G. Escobedo, M.D., M.P.H.,
- Border Health Epidemiologist, New Mexico Border Health Office,
- New Mexico Department of Health,
- Las Cruces, New Mexico.

- Wanda Foster,
- Word Processing Specialist, Palladian Partners, Inc.,
- Silver Spring, Maryland.

- Sarah Gregory,
- Acting Managing Editor, Office on Smoking and Health,
- National Center for Chronic Disease Prevention and Health Promotion,
- Centers for Disease Control and Prevention,
- Atlanta, Georgia.

- Barbara H. Hebb,
- Project Manager, SAIC,
- Oak Ridge, Tennessee.

- Elizabeth L. Hess, E.L.S.,
- Senior Technical Editor, Palladian Partners, Inc.,
- Silver Spring, Maryland.

- Lynn Hughley,
- Lead Graphic Artist, TRW, Inc.,
- Atlanta, Georgia.

- Yun Chen W. Lin, M.P.H.,
- Technical Information Specialist, Office on Smoking and Health,
- National Center for Chronic Disease Prevention and Health Promotion,
- Centers for Disease Control and Prevention,
- Atlanta, Georgia.

- William T. Marx, M.L.I.S.,
- Technical Information Specialist, Office on Smoking and Health,
- National Center for Chronic Disease Prevention and Health Promotion,
- Centers for Disease Control and Prevention,
- Atlanta, Georgia.

- Richard Mayeux, M.D., M.S.E.,
- Gertrude H. Sergievsky Professor of Neurology, Psychiatry, and Public Health (Epidemiology),
- Gertrude H. Sergievsky Center,
- Columbia University,
- New York, New York.

- Maribet McCarty, R.N., M.P.H.,
- Technical Information Specialist, The Orkand Corporation,
- Atlanta, Georgia.

- Cathy L. Melvin, Ph.D., M.P.H.,
- Chief, Program Services and Development Branch,
- Division of Reproductive Health,
- National Center for Chronic Disease Prevention and Health Promotion,
- Centers for Disease Control and Prevention,
- Atlanta, Georgia.

- Donald J. Sharp, M.D.,
- Medical Epidemiologist, Office on Smoking and Health,
- National Center for Chronic Disease Prevention and Health Promotion,
- Centers for Disease Control and Prevention,
- Atlanta, Georgia.

- Cate Timmerman,
- Co-President, Palladian Partners, Inc.,
- Silver Spring, Maryland.

- Angela Trosclair, M.S.,
- Statistician, TRW, Inc.,
- Atlanta, Georgia.

- Lynne Wilcox, M.D., M.P.H.,
- Director, Division of Reproductive Health,
- National Center for Chronic Disease Prevention and Health Promotion,
- Centers for Disease Control and Prevention,
- Atlanta, Georgia.

- Peggy E. Williams, M.S.,
- Writer-Editor, Analytical Sciences, Inc.,
- Marietta, Georgia.

- Trevor A. Woollery, Ph.D.,
- Health Economist, Office on Smoking and Health,
- National Center for Chronic Disease Prevention and Health Promotion,
- Centers for Disease Control and Prevention,
- Atlanta, Georgia.

- Derek Yach, M.D.,
- Program Manager, Tobacco-Free Initiative,
- World Health Organization,
- Geneva, Switzerland.