# Abbreviations

- µg
- microgram

- AARP
- American Association of Retired Persons

- ABPI
- ankle brachial pressure index

- ACCP
- American College of Chest Physicians

- ACS
- American Cancer Society

- AD
- Alzheimer's disease

- ADD
- attention deficit disorder

- AFexp
- attributable fraction among persons exposed

- AHCPR
- Agency for Health Care Policy and Research

- AIDS
- acquired immunodeficiency syndrome

- AMWA
- American Medical Women's Association

- APA
- American Psychiatric Association

- ASSIST
- American Stop Smoking Intervention Study

- AUTS
- Adult Use of Tobacco Survey

- BMI
- body mass index

- BRFS
- Behavioral Risk Factor Survey

- BRFSS
- Behavioral Risk Factor Surveillance System

- CASH
- Cancer and Steroid Hormone Study

- CDC
- Centers for Disease Control and Prevention

- CEPA
- California Environmental Protection Agency

- CHAD
- Community, Hypertension, Atherosclerosis, and Diabetes Program

- CHD
- coronary heart disease

- CI
- confidence interval

- CIN
- cervical intraepithelial neoplasia

- CIS
- Cancer Information Service

- CIS
- carcinoma in situ

- CNS
- central nervous system

- CO
- carbon monoxide

- COLD
- chronic obstructive lung disease

- COMMIT
- Community Intervention Trial for Smoking Cessation

- COPD
- chronic obstructive pulmonary disease

- CORIS
- Coronary Risk Factor Study

- CPS-I
- Cancer Prevention Study I

- CPS-II
- Cancer Prevention Study II

- CVD
- cardiovascular disease

- CYP1A1
- cytochrome P-450 1A1

- DES
- diethylstilbestrol

- DHEAS
- dehydroepiandrosterone sulfate

- DNA
- deoxyribonucleic acid

- DRD4
- D4 dopamine receptor

- DSM-III-R
- Diagnostic and Statistical Manual of Mental Disorders, third edition, revised

- DSM-IV
- Diagnostic and Statistical Manual of Mental Disorders, fourth edition

- EPA
- U.S. Environmental Protection Agency

- ER
- estrogen receptor

- ETS
- environmental tobacco smoke

- FCTC
- Framework Convention for Tobacco Control

- FDA
- U.S. Food and Drug Administration

- FEF25-75
- forced expiratory flow between 25 and 75 percent of FVC

- FEV0.75
- forced expiratory volume in 0.75 second

- FEV1
- forced expiratory volume in 1 second

- FTC
- Federal Trade Commission

- FVC
- forced vital capacity

- g
- gram

- GSTM1
- glutathione S-transferase M1

- HCFA
- Health Care Financing Administration

- HHANES
- Hispanic Health and Nutrition Examination Survey

- HIV
- human immunodeficiency virus

- HIV-1
- human immunodeficiency virus type 1

- HMO
- health maintenance organization

- HPV
- human papillomavirus

- HRT
- hormone replacement therapy

- IARC
- International Agency for Research on Cancer

- IBD
- inflammatory bowel disease

- ICD-9
- International Classification of Diseases, ninth revision

- IMPACT
- Initiatives to Mobilize for the Prevention and Control of Tobacco Use

- INWAT
- International Network of Women Against Tobacco

- IUGR
- intrauterine growth retardation

- JAMA
- Journal of the American Medical Association

- kg
- kilogram

- L
- liter

- LBW
- low birth weight

- LPL
- lipoprotein lipase

- m
- meter

- MDD
- major depressive disorder

- mg
- milligram

- MI
- myocardial infarction

- mL
- milliliter

- mm
- millimeter

- mm Hg
- millimeter of mercury

- MSA
- Master Settlement Agreement

- MTF
- Monitoring the Future Survey

- NAB
- N′-nitrosoanabasine

- NAT
- N′-nitrosoanatabine

- NAT1
- N-acetyltransferase 1

- NAT2
- N-acetyltransferase 2

- NCHS
- National Center for Health Statistics

- NCI
- National Cancer Institute

- ng
- nanogram

- NHANES
- National Health and Nutrition Examination Survey

- NHANES II
- National Health and Nutrition Examination Survey II

- NHANES III
- National Health and Nutrition Examination Survey III

- NHIS
- National Health Interview Survey

- NHSDA
- National Household Survey on Drug Abuse

- NIDA
- National Institute on Drug Abuse

- NIOSH
- National Institute for Occupational Safety and Health

- NNK
- 4-(methylnitrosamino)-1-(3-pyridyl)-1- butanone

- NNN
- N′-nitrosonornicotine

- NOW
- National Organization for Women

- NRC
- National Research Council

- NTTS
- National Teenage Tobacco Survey

- NYTS
- National Youth Tobacco Survey

- OA
- osteoarthritis

- OC
- oral contraceptive

- OSH
- Office on Smoking and Health

- PAH
- polycyclic aromatic hydrocarbon

- PD
- Parkinson's disease

- PHS
- U.S. Public Health Service

- PID
- pelvic inflammatory disease

- PPROM
- preterm premature rupture of the membranes

- PROM
- premature rupture of the membranes

- RA
- rheumatoid arthritis

- RR
- relative risk

- SAMHSA
- Substance Abuse and Mental Health Services Administration

- SAMMEC
- Smoking Attributable Mortality, Morbidity, and Economic Costs

- SEER
- Surveillance, Epidemiology, and End Results Program

- SES
- socioeconomic status

- SGA
- small for gestational age

- SIDS
- sudden infant death syndrome

- SLE
- systemic lupus erythematosus

- SMR
- standardized mortality ratio

- STD
- sexually transmitted disease

- SUDAAN
- Survey Data Analysis

- TAPS I
- Teenage Attitudes and Practices Survey I

- TAPS II
- Teenage Attitudes and Practices Survey II

- TIA
- transient ischemic attack

- TSH
- thyroid-stimulating hormone

- TSNA
- tobacco-specific nitrosamine

- USDHEW
- U.S. Department of Health, Education, and Welfare

- USDHHS
- U.S. Department of Health and Human Services

- WAGAT
- Women and Girls Against Tobacco

- WHO
- World Health Organization

- WHR
- waist-to-hip ratio

- WIC
- Special Supplemental Nutrition Program for Women, Infants, and Children

- YPLL
- years of potential life lost

- YRBS
- Youth Risk Behavior Survey

- YRBSS
- Youth Risk Behavior Surveillance System