# Stakeholder Submissions

ECRI Institute invited NPWT device manufacturers and other interested stakeholders (i.e., wound care-related organizations) to submit relevant clinical materials for consideration in the report (Table 14). Specifically, we requested the submission of published or unpublished randomized controlled trials, observational studies or other compelling evidence that examined the use of NPWT devices or systems to impact relevant clinical outcomes. We were also interested in the submission of materials regarding any ongoing clinical trials.

We initially identified the following relevant clinical materials from the submissions that had not been identified in our searches: one systematic review,(70) two comparison studies,(71,72) and 23 single arm studies(73–95) for inclusion in this report. In addition, we included one unpublished case series submitted by Smith and Nephew(96) giving us a total of 24 additional case series included in this report.

During the review process of the report, we received nine submissions for possible inclusion in the report. Of these additional submissions, we included one nonrandomized comparison study(106) in this report. Counting this additional submission, three comparison studies which were previously not identified by ECRI were included in the report. For more information on submissions by individual stakeholders, please see Appendix D.