# Results

## Key Question 1 Does any single NPWT system have a significant therapeutic distinction in terms of wound healing outcomes compared to any other NPWT system for the treatment of acute or chronic wounds?

Based on our defined search strategies (see Appendix A) and submissions from interested parties (Appendix D), no studies comparing one NPWT system to another NPWT system were identified that addressed this Key Question.

### Quantitative Synthesis of the Evidence Base

Due to the lack of studies that directly compared the efficacy and safety of one NPWT system to another NPWT system, we were unable to perform a quantitative synthesis to determine whether one system has any significant therapeutic distinction over another.

### Qualitative Synthesis of the Evidence Base

For the same reasons listed above for quantitative synthesis, no qualitative synthesis was possible.

### Was an indirect comparison possible?

Based on our pre-determined methodology, evidence for indirect comparisons was to be obtained from RCTs of commercially available NPWT systems versus a common comparator. Of 40 studies comparing a NPWT system to another wound care therapy, all were studies of the Kinetics Concepts Inc. (KCI) V.A.C.® system and only nine were RCTs. Therefore no indirect comparisons with other NPWT systems were possible.

In order to determine whether we could form evidence-based conclusions using methods of indirect comparison, we tabled important information from studies that compared NPWT to other wound therapies. Our systematic search of the literature, together with the submissions provided by manufacturers, identified 40 controlled studies comparing NPWT to other wound treatments. The material submitted by manufacturers contained two comparison studies involving NPWT systems that were not identified in our searches.(71,72) During the review process of the report, we also identified one additional comparison study of interest.(106) None of the submitted materials contained unpublished comparison studies with sufficient information to be included in this report. All of the identified studies evaluated the V.A.C.® Therapy system (KCI) in comparison to other wound therapies. Thus, we were unable to perform any indirect comparisons.

Despite the fact that we could not use the studies to answer the Key Question, we assessed the comparison studies for risk of bias and extracted data on treatment procedures, patient characteristics, wound types, comparator treatments, and study outcomes. We have provided tables with this information in Appendix C for the interested reader, and briefly discuss these studies here. The overall quality of the evidence base of 40 studies was considered low (significant potential for bias) based on a median quality score of 4.32 (see Study Quality Assessment in Methods Section). None of the studies received a high-quality rating; seven (18%) were rated moderate, and 33 (82%) were rated low. Typical study limitations included lack of concealment of treatment allocation, lack of blinding patients and assessors, lack of reporting patient characteristics, and small study populations.

Blinding patients, treating physicians and outcome assessors to treatment increases the internal validity of intervention studies. In a situation where patients are being treated by NPWT systems, blinding the patient and the physician providing care is not feasible. To prevail over these limitations, van den Boogaard et al.(107) recommend overcoming all other potential shortcomings, i.e., wound assessors should be blinded to treatment, patient groups must be comparable, group allocation should be concealed, and full follow-up of a sufficient portion of all included patients should be performed.

None of the studies that we assessed reported that the physicians were blinded to treatment assignment, and only five (12%) of the studies reported blinding of outcome assessors. In only 7% of studies was there concealment of allocation to treatment. Only 14 (35%) studies had similar populations (i.e., wound size, wound severity and comorbidities), and 30% of the studies did not have similar follow-up times. Over 75% of the studies either reported a potential conflict of interest in terms of funding (k = 9) or made no report of their funding source (k =22). Lastly, over 50% of the studies had a study size of fewer than 50 patients, in 85% of the studies there were fewer than 75 patients. Assessments of all included comparison studies can be found in Appendix B.

The seven moderate quality studies evaluated the use of the V.A.C.® system in the treatment of diabetic foot ulcers,(108,109) pressure ulcers,(110) chronic leg ulcers,(111) and wounds with mixed etiologies.(112–114) Two studies evaluated the use of the V.A.C.® system to secure split-thickness skin grafts.(112,115) Comparators included bolster dressings,(112) standard of care,(113) the Healthpoint System of topical gel products,(110) and advanced moist wound therapy (i.e., hydrogels, hydrocolloids, or alginates).(108,109,111,114) Primary endpoints included measures of wound reduction or time to complete wound healing.

Four studies concluded that the V.A.C.® system provided additional benefit when compared to other interventional treatments.(108,110,113,115) Vuerstaek et al.(115) evaluated 60 patients with chronic leg ulcers (venous, atherosclerotic, or mixed etiologies) randomized to treatment by V.A.C.® or alginate/hydrocolloids. Time to complete healing was significantly reduced in the V.A.C.® group: 29 days (95% CI: 25.5 to 32.5) versus 45 days (95% CI: 36.2 to 53.8). Results for secondary outcomes included a greater relapse at one-year followup (52% of all healed V.A.C.® ulcers relapsed compared with 42% in the control group). Both groups reported significant increases in quality of life and similar decreases in pain.

One moderate-quality study of 342 diabetic foot wounds,(108) reported a mean change in wound size in favor of the V.A.C.® system (−4.32 cm^2^ versus −2.53 cm^2^p = 0.021), as well as a higher proportion of V.A.C.®-treated wounds achieving complete closure (43% vs. 28.9%). Data, however, were only reported for day 28 during the “active treatment phase,” whereas both three and nine month follow-up assessments were completed for patients achieving ulcer closure. This study reported the highest attrition rate (over 30%) of any controlled study; 40 patients (13% V.A.C.® due to adverse events).

Ford et al. reported increased rates of pressure ulcer wound healing, superiority in decreasing inflammation at the wound site, and increased number of capillaries (suggesting the promotion of formation of granulation tissue) for the V.A.C.® system compared to the Healthpoint System (HP).(110) The HP system includes three gel products: Accuzyme (papain-urea debridement ointment), Iodosorb (0.9% cadexomer iodine) and Panafil (papain-urea, chlorophyllin, and copper ointment). However, in this interim report of the six-week study, complete wound healing was reported for only four wounds: two (10%) with V.A.C.® and two (13%) with the HP products. In a similar length study, Joseph et al.(113) studied 24 patients with 36 chronic non-healing wounds (79% pressure ulcers). Average initial wound volume was larger for V.A.C.® wounds (38 cubic centimeters (cc) vs 24 cc), however, a significant reduction in wound volume was still demonstrated (78% vs 30% control). A significantly greater reduction in wound depth (66% vs. 20% control; p = 0.00001) and width was reported; however, improvement in width, depth, and volume did not extrapolate to wound length (p = 0.38).

Three studies concluded a comparable benefit in comparisons of the V.A.C.® to control treatments.(109,112,114) Moisidis et al.(112) enrolled 22 patients (used as their own controls) with wounds clinically ready for skin graft. At two weeks, a quantitative assessment by a clinician blinded to treatment reported no significant difference in degree of epithelialization. A greater degree of epithelialization was reported in six cases (30%), the same degree in nine cases (45%), and less epithelialization in five cases (25%) of V.A.C.® versus control-treated wounds.

Armstrong et al.(109) reported results of a post hoc analysis of their 16-week study of 164 diabetic foot amputation wounds. Results for this evaluation of the impact of wound chronicity indicated no significant difference for proportion of acute (<30 days, 75% of study patients) and chronic (>30 days, 25% of the study population) wounds achieving complete wound closure (acute p = 0.072, chronic p = 0.320) between NPWT and control groups. However, the authors found improved time to complete healing with NPWT compared to control treatments for both acute and chronic wounds.

Braakenburg et al.(114) evaluated 65 patients with chronic and acute wounds. Similar results were reported for overall change in wound area (0.1 cm^2^/day), time to satisfactory healing (median 16 days (V.A.C.® vs. 20 days [control]) and overall change in the amount of granulation.

For further information on comparison studies evaluating V.AC.® to other treatments for acute and chronic wounds, please see Appendix C.

## Key Question 2 Does any component of a NPWT system have a significant therapeutic distinction compared to any other similar component of a NPWT system for the treatment of acute or chronic wounds?

Our searches did not identify any studies comparing one NPWT system component to another NPWT system component (with both groups receiving negative pressure treatment) that addressed this Key Question. No published on unpublished studies of this design were submitted by interested parties. This question was designed to examine studies that compared different dressing sets, tubing, or pumps while maintaining identical components for the other parts of an NPWT system.

We did identify one study that compared the V.A.C.® Therapy system (KCI) to an alternative form of negative pressure using vacuum bottles while using the same foam dressing set. This study is briefly described here.(116) In this study, Wild et al.randomized ten patients with Grade III and Grade IV pressure ulcers to the V.A.C.® Therapy system (KCI) or the Redon drain/vacuum group (P.J. Dahlhausen & Co. GmbH, Cologne, Germany). All patients were treated with the same GranuFoam®(KCI) dressings. V.A.C.®-treated wounds received negative pressure (−125 mmHg) therapy by a computerized controlled therapy unit. A typical maximum treatment pressure for the NPWT devices currently cleared for marketing in the U.S. is −200 mmHg. Wounds in the control group received uncontrolled negative pressure (-900 mmHg) by a non-powered Redon vacuum bottle.

Primary endpoints for the study included absolute and relative proportion of the wound area consisting of granulation tissue, fibrin deposits and necrosis. Results indicated that V.A.C.® was more effective than the Redon vacuum bottles in terms of change in surface granulation tissue (increase of 54% versus decrease of 7.1%, control; p = 0.001), presence of necrotic tissue (0.3% versus >10%, control), and change in fibrin tissue (decrease of 27% versus increase of 21.8%, control; p = 0.035).The study was terminated at day nine due to the large disparity in outcomes between treatment groups, and the added care needed for the Redon group. The authors concluded that the non-powered vacuum bottle approach to applying negative pressure to a pressure ulcer was not appropriate.

## Key Question 3 What are the reported occurrences of pain, bleeding, infection, other complications, and mortality for NPWT systems?

Adverse events were reported in 37 of 40 (92%) studies comparing NPWT to other treatments. Of the 37 studies reporting events, seven (19%) studies described NPWT as a safe treatment. Fewer complications were reported in the NPWT-treated patients than in those receiving other wound therapies in 19 (51%) studies(1,23,71,72,106, 108, 110, 113, 114, 117–126) and similar complications were reported in 8 (22%) studies.(109,127–133) Most commonly reported adverse events included pain (k = 8), bleeding (k = 6), infection (k = 13), mortality (k = 10), and other complications (k = 17). Reports were similar for bleeding, infection, amputation, and other complications (i.e, fistulae). However, fewer secondary amputations (7 versus 17) were reported in NPWT groups (all studies reported using V.A.C.® system). Reports of adverse events for comparison studies can be found in the tables that follow.

Reports of adverse events described in systematic reviews can be found in Table 42 in Appendix C.

Table 5 Reports of Pain in Comparison Studies of NPWT Devices

Reference | Wound Type | Treatment | Number of Patient Reports (n)
Bickels et al.(134) | Soft tissue defects | V.A.C.® | No patients experienced substantial pain
Bickels et al.(134) | Soft tissue defects | SOC | No patients experienced substantial pain
Braakenburg et al.(114) | Acute and chronic | V.A.C.® | 2 patients discontinued treatment due to pain during dressing change
Braakenburg et al.(114) | Acute and chronic | Conventional | NR
Denzinger et al.(135) | Complex inguinal | V.A.C.® | Not specifically quantified, however patients reported more pain with dressing change in V.A.C.® group
Denzinger et al.(135) | Complex inguinal | SOC | Less pain reported than V.A.C.® group
Genecov et al.(131) | STSG | V.A.C.® | No difference in pain
Genecov et al.(131) | STSG | Control | No difference in pain
McCallon et al.(120) | DFU | V.A.C.® | Due to initial foam collapse and/or with foam removal; Number of patients NR
McCallon et al.(120) | DFU | Saline-moistened gauze | NR
Moues et al.(136) | Full-thickness | V.A.C.® | 1 patient discontinued treatment due to ischaemic pain with increased tissue necrosis
Moues et al.(136) | Full-thickness | Standard moist gauze | NR
Ozturk et al.(117) | Fournier’s gangrene | V.A.C.® | Patients reported less pain when measured by Visual Analogue Scale (0–10, with higher numbers indicating more pain) Mean V.A.S. score: 2.4
Ozturk et al.(117) | Fournier’s gangrene | SOC | Mean V.A.S. score: 6.8
Vuerstaek et al.(115) | Chronic leg ulcers | V.A.C.® | 3 complaints of pain reported as adverse events; mean pain scores decreased over time
Vuerstaek et al.(115) | Chronic leg ulcers | Control | 1 complaint of pain reported as adverse event; mean pain scores decreased over time

DFU Diabetic foot ulcer

NR Not reported

STSG Split thickness skin graft

V.A.S. Visual analogue scale for pain

Table 6 Reports of Bleeding in Comparison Studies of NPWT Devices

Reference | Wound Type | Treatment | Number of Patients Reports (n)
McCallon et al.(120) | DFU | V.A.C.® | Granulation tissue growth into pores of the foam frequently resulted in minor capillary disruption upon V.A.C.® foam dressing removal.
McCallon et al.(120) | DFU | SOC | NR
Simek et al.(123) | Deep sternal | V.A.C.® | Intractable: 2.9%
Simek et al.(123) | Deep sternal | Conventional | Intractable: 3.6%
Segers et al.(122) | PM | V.A.C.® | 4
Segers et al.(122) | PM | Closed drainage | 4
Fuchs et al.(23) | Deep sternal | V.A.C.® | NR
Fuchs et al.(23) | Deep sternal | Conventional | 2 deaths due to bleeding
Bickels et al.(134) | Soft tissue | V.A.C.® | No patients had excessive bleeding
Bickels et al.(134) | Soft tissue | SOC | No patients had excessive bleeding
Vuerstaek et al.(115) | Chronic leg | V.A.C.® | 0
Vuerstaek et al.(115) | Chronic leg | Conventional (hyrocolloids, alginates) | 2

NR Not reported

Table 7 Reports of Infection in Comparison Studies of NPWT Devices

Reference | Wound Type | Treatment | Number of Patient Reports (n)
Armstrong et al.(109) | Diabetic foot amputation | V.A.C.® | NR
Armstrong et al.(109) | Diabetic foot amputation | SWT | 2
Blume et al.(108) | DFU | V.A.C.® | Wound infection: 4 Cellulitis: 4 Osteomyelitis: 1 Staphylococcus: 1 Infected skin ulcer: 1
Blume et al.(108) | DFU | AMWT | Wound infection: 1 Cellulitis: 1 Infected skin ulcer: 2
Ford et al.(110) | Pressure ulcer | V.A.C.® | Osteomyelitis confirmed in 13 wounds (treatment not confirmed)
Ford et al.(110) | Pressure ulcer | Healthpoint System | Osteomyelitis confirmed in 13 wounds (treatment not confirmed)
Joseph et al.(113) | Pressure ulcer | V.A.C.® | Osteomyelitis - 1
Joseph et al.(113) | Pressure ulcer | Saline wet-to-moist | Osteomyelitis – 2 Wound infection – 6
Labler et al.(71) | Soft tissue | V.A.C.® | Infections resulting in non-union: 2 Infections: 1
Labler et al.(71) | Soft tissue | Epigard® dressing | Infections resulting in non-union: 2
Moues et al.(136) | Full-thickness | V.A.C.® | 4
Moues et al.(136) | Full-thickness | Standard moist gauze | 1
Rinker et al.(121) | Open tibia fracture | V.A.C.® | 6% infectious complications
Rinker et al.(121) | Open tibia fracture | SOC | 18% infectious complications
Song et al.(124) | Surgical | V.A.C.® | Mediastinitis - 1
Song et al.(124) | Surgical | SOC | Recurrent mediastinitis - 1
Segers et al.(122) | PM | V.A.C.® | Mortality caused by surgical site infection: 4 (13.8%)
Segers et al.(122) | PM | Closed drainage | Mortality caused by surgical site infection: 7 (20.6%
Stannard et al.(125) | Hematoma | V.A.C.® | NR
Stannard et al.(125) | Hematoma | Pressure dressing | 1 - late infection at site of hematoma
Stannard et al.(125) | Fracture | V.A.C.® | 3
Stannard et al.(125) | Fracture | Post-operative dressing | 3
Timmers et al.(106) | Post-traumatic osteomyelitis | NPIT | Recurrence of osteomyelitis – 3 (10%)
Timmers et al.(106) | Post-traumatic osteomyelitis | SOC | Recurrence of osteomyelitis – 55 (58.5%)
Vuerstaek et al.(115) | Chronic leg | V.A.C.® | 0
Vuerstaek et al.(115) | Chronic leg | Conventional (hyrocolloids, alginates) | 1
Yang et al.(72) | Fasciotomy | V.A.C.® | None
Yang et al.(72) | Fasciotomy | Saline wet-to-moist | Wound Infection – 1

AMWT Advanced moist wound therapy

DFU Diabetic foot ulcer

NPIT Negative pressure instillation therapy

NR Not reported

PM Post-sternotomy mediastinitis

SOC Standard of care

SWT Standard wound therapy

Table 8 Reports of Mortality in Comparison Studies of NPWT Devices

Reference | Wound Type | Treatment | Number of Patient Reports (n)
Blume et al.(108) | DFU | V.A.C.® | 3
Blume et al.(108) | DFU | AMWT | 3
Braakenburg et al.(114) | Chronic and acute | V.A.C.® | 3
Braakenburg et al.(114) | Chronic and acute | Hydrocolloid dressings, alginate, acetic acid or Eusol (sodium hypochlorite) | 5
Catarino et al.(137) | Post-sternotomy mediastinitis | V.A.C.® | Due to pneumonia 5 months postoperative: 1
Catarino et al.(137) | Post-sternotomy mediastinitis | Closed drainage and irrigation | 0
Doss et al.(128) | Post-sternotomy osteomyelitis | V.A.C.® | Hospital mortality: 1
Doss et al.(128) | Post-sternotomy osteomyelitis | SOC | Hospital mortality: 1
Fuchs et al.(23) | Deep sternal | V.A.C.® | Death due to vacuum-related perforation: 1
Fuchs et al.(23) | Deep sternal | Conventional | Death due to bleeding: 2 Death due to septic shock: 2
Huang et al.(127) | Limb | V.A.C.® | 1
Huang et al.(127) | Limb | SOC | 1
Immer et al.(130) | Deep sternal wound infection | V.A.C.® | Multiorgan failure: 1
Immer et al.(130) | Deep sternal wound infection | V.A.C.® plus excision plus musculocutaneous flap | NR
Immer et al.(130) | Deep sternal wound infection | Excision plus musculocutaneous flap | Multiorgan failure: 1 Uncontrollable septicemia: 1
Segers et al.(122) | PM | V.A.C.® | 9
Segers et al.(122) | PM | Closed drainage | 9
Song et al.(124) | Surgical | V.A.C.® | Death from aspiration pneumonia: 2 Death from multisystem organ failure: 1
Song et al.(124) | Surgical | SOC | Death from aspiration pneumonia: 1
Vuerstaek et al.(115) | Chronic leg | V.A.C.® | 4
Vuerstaek et al.(115) | Chronic leg | Conventional (hydrocolloids, alginates) | 2

AMWT Advanced moist wound therapy

DFU Diabetic foot ulcer

NR Not reported

SOC Standard of care

Table 9 Reports of Other Complications in Comparison Studies of NPWT Devices

Reference | Wound Type | Treatment | Number of Patient Reports (n)
Armstrong et al.(109) | Diabetic foot amputation | V.A.C.® | Serious complication: 1
Armstrong et al.(109) | Diabetic foot amputation | SWT | NR
Blume et al.(108) | DFU | V.A.C.® | Secondary amputations: 7 Edema: 5
Blume et al.(108) | DFU | AMWT | Secondary amputations: 17 Edema: 7
Braakenburg et al.(114) | Acute and chronic | V.A.C.® | Early dismissal: 2 Refusal to cooperate: 1
Braakenburg et al.(114) | Acute and chronic | Conventional | Amputation: 1 Early dismissal: 6
Domkowski et al.(129) | Post-sternotomy mediastinitis | V.A.C.® | Multisystem organ failure: 2 Overwhelming sepsis: 2
Domkowski et al.(129) | Post-sternotomy mediastinitis | Standard of care | NR
Huang et al.(127) | Limb | V.A.C.® | Above-knee amputation: 1 Below-knee amputation: 1
Huang et al.(127) | Limb | SOC | Above-knee amputation: 2
Joseph et al.(113) | Pressure ulcer | V.A.C.® | Calcaneal fracture: 2 Amputation: 2
Joseph et al.(113) | Pressure ulcer | Saline wet-to-moist | Fistulae: 2
Labler et al.(71) | Soft tissue | V.A.C.® | Amputation:1
Labler et al.(71) | Soft tissue | Epigard® dressing | Amputation: 2 (1 patient died 2 days later due to cardiovascular instability) Non-union without infection: 1
Moisidis et al.(112) | Clinically ready for skin graft | V.A.C.® | Difficulty in maintaining pressure: 3
Moisidis et al.(112) | Clinically ready for skin graft | Bolster dressing | NR
Moues et al.(136) | Full thickness | V.A.C.® | Erosion of adjacent tissue due to increased local pressure: 1 Maceration/eczema: 2 Sudden increase in body temperature: 1 Postoperative complications after surgical closure: 32% Most notable postoperative complications: Abscess: 2 Fistula: 1 Total skin graft failure: 1
Moues et al.(136) | Full thickness | Standard moist gauze | Allergic reaction to Furacine®: 2 Wound surface area increase: 3 Postoperative complications after surgical closure: 43% Most serious postoperative complications: Abscess: 1 Fistula: 1 Skin graft failure of 40%: 1
Rinker et al.(121) | Open tibia fracture | V.A.C.® | Overall complication rate: 35% Flap related complications: 12% Amputation: 1 (6%)
Rinker et al.(121) | Open tibia fracture | SOC | Overall complication rate: 53% Flap related complications: 21% Amputation: 2 (5%)
Schwein et al.(126) | Pressure Ulcer | V.A.C.® | Hospitalization for a wound-related problem: 3 (5%)
Schwein et al.(126) | Pressure Ulcer | Any other wound care modality | Hospitalization for a wound-related problem: 310 (14%)
Shilt et al.(138) | Traumatic | V.A.C.® | Patients requiring home nursing after discharge: 4
Shilt et al.(138) | Traumatic | Standard of care | NR
Siegel et al.(119) | Radiation-associated | V.A.C.® | Amputation:1 Mild discomfort: 3 Skin rash: 2 Itching: 3
Siegel et al.(119) | Radiation-associated | SOC | Above-knee amputation: 3 Hip disarticulation: 1
Simek et al.(123) | Deep sternal | V.A.C.® | Fistula: 14.7%
Simek et al.(123) | Deep sterna | Conventional | Fistula: 10.7%
Sjogren et al.(139) | Post-sternotomy mediastinitis | V.A.C.® | Recurrent sternal fistulae: 4 (6.6%)
Sjogren et al.(139) | Post-sternotomy mediastinitis | Conventional | Recurrent sternal fistulae: 2 (5%)
Song et al.(124) | Surgical | V.A.C.® | Chronically draining wound: 1
Song et al.(124) | Surgical | SOC | Chronically draining wound: 1 Omental flap losses: 2 Intestinal evisceration: 1 Hernia: 1
Stannard et al.(125) | Hematoma | V.A.C.® | NR
Stannard et al.(125) | Hematoma | Pressure dressing | NR
Stannard et al.(125) | Fracture | V.A.C.® | Delayed wound breakdown: 1
Stannard et al.(125) | Fracture | Post-operative dressing | Delayed wound breakdown: 1

AMWT Advanced moist wound therapy

DFU Diabetic foot ulcer

SOC Standard of care

SWT Standard wound therapy

For additional information on adverse events we identified 103 case series (studies with no control group) of NPWT. 24 of these studies had not been identified in our literature searches. Studies included chronic wounds (k = 48), acute wounds (k = 35) or mixed wounds (e.g., chronic and acute) (k = 20). We prepared four tables that summarize the data reported in these studies: patient characteristics, treatment details, outcomes reported, and adverse events (see Appendix C). The tables are organized by year (the most recent is first) and then by author, alphabetically. Ninety-five studies specified using the vacuum-assisted closure device manufactured by KCI.

The adverse events reported in these studies include pain (k = 12);(78,88,91,140–148) bleeding (k = 7);(79,142,147,149–152) infection or bacterial colonization (k = 15);(37,77,85,86,96,148–150, 153-159) mortality (k = 4);(149–151,153) and other complications (k = 18).(95)

Table 10 lists the 18 studies that mentioned other complications, such as fistulae and skin blisters. Case series may report adverse events inconsistently. Some case series report all adverse events, while others report events the authors consider “serious.” If a study does not report a particular adverse event it still may have occurred unless the publication specifically states that the specific adverse event did not occur. Based on the inconsistencies of reporting for case series, we have not pooled the results to determine a rate of adverse event occurrence.

Table 10 Other Complications Reported in Case Studies

Reference | Other Complications
Chen et al. 2008(160) | Right ventricular rupture while a patient was being treated with vacuum-assisted closure dressing. The patient coughed excessively during early postoperative period, possibly resulting in sternal shear force being applied directly over the right ventricular wall^1^
Ha et al. 2008(140) | Dryness, sloughy wounds, and excoriation as reasons for discontinuing the use of the vacuum-assisted closure therapy^1^
Wondberg et al. 2008(161) | Fistulae, fascial edge necroses, skin blister, prolapses of small bowel between fascia and foam^1^
Baharestani et al. 2007(162) | Development of an enterocutaneous fistula during vacuum-assisted closure therapy^1^
Bendewald et al. 2007(82) | Significant skin irritation from the negative pressure wound therapy dressing material^1^
McCord et al. 2007(142) | Dermatitis or skin maceration from adhesive dressing^1^
Rao et al. 2007(163) | Intestinal fistulation during vacuum-assisted closure therapy^1^
Morgan et al. 2006(164) | Flap failure in a patient treated with vacuum-assisted closure therapy^1^. The system was set at 125 mmHg; authors stated that this pressure was probably too high for a flap
Butter et al. 2005(144) | Failure of wound closure after use of vacuum-assisted closure therapy and recurrent pilonidal sinuses
Caniano et al. 2005(165) | Retained sponge and device malfunction^1^
Heller et al. 2005(87) | Low-output small bowel enterocutaneous fistula^1^
Perez et al. 2007(95) | High-output enterocutaneous fistula^1^
Stone et al. 2004(90) | Abdominal abscesses and enterocutaneous fistula^1^
Gustafsson et al. 2003(146) | Minor air leakage requiring complementary draping^1^
Suliburk et al. 2003(166) | Vacuum assisted closure therapy^1^ was discontinued as a result of fistulae that developed or as a result of poor fascia
Armstrong et al. 2002(85) | Periwound maceration, periwound cellulitis, and deep space infection^1^
De Lange et al. 2000(167) | Retention development, some developed septicemia, fistulae, local necrosis, chest wall dehiscence possibly caused by local air leakage^1^.
Argenta and Morykwas 1997(148) | Fistula development when a foam dressing was placed directly over compromised intestine in a debilitated patient who had eviscerated^1^.

1 Device manufactured by KCI

## Key Question 4 Do patients being treated with one NPWT system have a significant therapeutic distinction in terms of less pain, bleeding, infection, other complications, or mortality than other NPWT systems?

Our searches, as well as material provided by interested parties, did not identify any studies comparing one NPWT system to another NPWT system. Consequently, we were not able to answer this Key Question and we were not able to determine the severity of adverse events for one NPWT system compared to another.