# Ongoing Clinical Trials

To locate recently conducted and ongoing clinical trials of negative pressure wound therapy, we searched two databases: http://clinicaltrials.gov and http://www.controlled-trials.com. Our searches identified 27 clinical trials with the following status: completed (5), recruiting outside of the U.S. (8); not yet open (4); and ongoing but not recruiting (2). See Table 12 for additional information regarding these trials.

ECRI Institute contacted the sponsors of two trials comparing NPWT devices (NCT00583141; NCT00590369); however, we were unable to obtain any further study information at this time.

Table 12 Clinical Trials

Clinicaltrials.gov Identifier or Other Identifier | Sponsor | Study Design | Purpose | Start Date | Expected Completion Date | Estimated Enrollment | Relevance to Key Questions
NCT00583141^a^ | The Cleveland Clinic in collaboration with Smith & Nephew, Inc. | Treatment, randomized, open label, factorial assignment – Versatile One (EZCare) versus KCI VAC negative pressure/vacuum systems | Investigate whether differences can be found in selected outcomes related to wound care, using Versatile One (EZCare) versus KCI VAC negative pressure/vacuum systems. | July 2005 | August 2008 | 50 adults, ages 18 years and older | KQ1
NCT00590369^a^ | The Cleveland Clinic in collaboration with Smith & Nephew, Inc. | Treatment, randomized, open label, factorial assignment – Versatile One (EZCare) versus KCI VAC negative pressure/vacuum systems | Investigate whether differences can be found in selected outcomes related to wound care, using Versatile One (EZCare) versus KCI VAC negative pressure/vacuum systems. | July 2005 | August 2008 | 50 adults, ages 18 years and older | KQ1
NCT00754156^d^ | University of Kentucky | Treatment, non-randomized, open label, parallel assignment, safety/efficacy study – ABRA Abdominal Closure System plus V.A.C. vs. V.A.C. Therapy alone | Compare the efficacy of utilization of the Canica ABRA system combined with the KCI VAC system for closure of open abdomen, versus the utilization of the KCI VAC system alone. | September 2008 | July 2010 | 30 adults, ages 18 years and older | KQ1
NCT00834314 | University Hospital Manheim in collaboration with DFG (German Research Foundation), KCI International and Medela Healthcare | Treatment, randomized, open label, active control, parallel assignment, safety/efficacy study – Vacuum-Pack-technique for temporary abdominal closure vs. negative pressure wound therapy for temporary abdominal closure with V.A.C.® Abdominal Dressing System) | Determine whether two vacuum-wound-dressing techniques (the so called “abdominal dressing” versus “vacuum-pack technique”) are equally effective in the treatment of open abdomen. | March 2009 | June 2010 | 20 adults, ages 18 years and older | KQ2
NCT00876551 | Hannover Medical School, Hannover, Germany | Treatment, non-randomized, open label, uncontrolled, single group assignment, safety/efficacy study – treatment will include a polyurethane foam (KCI) and CNP -125 mmHg using KCI V.A.C.® | Determine the short and long term outcome of endoscopic vacuum assisted closure of intrathoracic postsurgical leaks. | January 2008 | December 2012 | 30 adults ages 18 years and older | KQ3
NCT00847730 | KCI USA, Inc. | Supportive care, open label, single group assignment – V.A.C.® GranuFoam®™ | Evaluate the ease of use of the V.A.C.® GranuFoam® ™ Bridge dressing on diabetic foot ulcers receiving VAC Negative Pressure Therapy. | February 2009 | March 2009 | 75 adults, ages 18 years and older | KQ3
ISRCTN69032034 | University of York, York, UK, in collaboration with the Medical Research Council | RCT – Participants will be randomized to receive NPWT therapy or the comparator treatment (spun hydrocolloid, alginate or foam dressings). | Determine if topical negative pressure therapy is a clinically and cost-effective treatment for grade III/IV pressure ulcers | July 1, 2008 | August 31, 2009 | 50 | KQ3
NCT00582179^c^ | University of Alabama at Birmingham | Treatment, randomized, open label, parallel assignment, efficacy study – patients will be treated with a pressure dressing and observation or with a Vacuum-Assisted Closure device (VAC) | Evaluate the use of a negative pressure vacuum device in treating draining hematomas following traumatic injury. | September 2001 | December 2008 | 100 adults, ages 19 years and older | KQ3
NCT00829621 | University of Missouri-Columbia in collaboration with Medtronic | Treatment, randomized, open label, active control, parallel assignment – IVAC suction 75 mmHg vs. 125 mmHg | Determine whether or not the negative pressure associated with an IVAC is sufficient to remove BMP-2 from a surgical wound. | December 2008 | December 2010 | 20 adults, ages 18 years and older | KQ3
NCT00582998^e^ | University of Alabama at Birmingham in collaboration with KCI USA, Inc. | Treatment, randomized, open label, parallel assignment, efficacy study – Standard post-operative wound dressing vs. Vacuum-Assisted Closure (VAC) device | Evaluate the use of a negative pressure vacuum device in treating soft tissue injuries and the surgical incision following open reduction and internal fixation of calcaneus, tibial plateau, and pilon fractures. | June 2001 | November 2008 | 189 adults, ages 19 years and older | KQ3
NCT00432965^b^ | KCI USA, Inc. | Treatment, randomized, open label, active control, parallel assignment, safety/efficacy study – Optimized moist wound therapy including physicians use of alginates, hydrogels, hydrocolloids, collagens, etc. vs. VAC therapy | Determine if topical negative pressure therapy delivered by the V.A.C.® device is clinically efficacious and cost effective in the treatment of diabetic foot ulcers. | May 2002 | Not provided | 338 adults, ages 18 years and older | KQ3
NCT00654641 | West Virginia University in collaboration with CAMC Health System | Prevention, randomized, open label, active control, parallel assignment, efficacy study – Negative Pressure wound closure for 72 hours post-operatively vs. Suture closure of subcutaneous tissue and skin stapling and sterile bandage placement | Assess whether applying a source of vacuum (suction) to wounds following Cesarean delivery can reduce the risk of wound complications. | September 2007 | November 2010 | 220 women, ages 18 years and older | KQ3
NCT00582361^e^ | University of Alabama at Birmingham in collaboration with KCI USA, Inc. | Treatment, randomized, open label, parallel assignment, efficacy study – patients will have a standard dressing applied following initial treatment of their open fracture or will have a Vacuum-Assisted Closure (VAC) device applied following initial treatment of their open fracture | Evaluate the use of a negative pressure vacuum device in treating traumatic wounds sustained as a result of an open fracture that requires surgery. | June 2001 | March 2008 | 63 adults, ages 19 years and older | KQ3
NCT00773981 | Hvidovre University Hospital in collaboration with Braun Aesculap | Treatment, randomized, open label, parallel assignment, safety/efficacy study – patients treated with a catheter with daily rinsing for a minimum of 7 days or Endoluminal vacuum therapy | Investigate the effects of transrectal vacuum treatment on the healing of anastomotic leakage after rectum resection. | October 2008 | October 2011 | 60 adults, ages 18 years and older | KQ3
NCT00789659^d^ | University of Mississippi Medical Center in collaboration with the Orthopaedic Trauma Association | Prevention, randomized, open label, parallel assignment – postoperative wounds will be dressed with a negative pressure (V.A.C.) dressing or a completely occlusive dressing that is attached to a device that allows a constant negative pressure of 125 mmHg to be generated | Assess the efficacy of VAC therapy on morbidly obese orthopedic trauma patients, specifically those with pelvic ring, acetabular or proximal femur fractures that would require surgery. | January 2009 | December 2009 | 60 adults, ages 18 to 64 years | KQ3
NCT00724750^b^ | University of Chicago | Treatment, randomized, open label, parallel assignment, efficacy study – Gauze suction (G-SUC) Negative Pressure Wound Therapy vs. Vacuum-Assisted Closure Device (VAC) Negative Pressure Wound Therapy | 1. Compare the effectiveness of G-SUC and standard VAC therapy with regards to change in wound size over 1-2 weeks and number of patients who are able to clear infection by 4 days.; 2. Compare the failure of each method of therapy by documenting the number of dressing that cannot be maintained because of fluid or suction.; 3. Measure and compare the cost of the two wound treatments | July 2006 | December 2008 | 120 adults, ages 18 years and older | Studies comparing NPWT to a comparator treatment
NCT00691821^d^ | St. Joseph’s Healthcare in collaboration with Ontario Ministry of Health and Long term Care, St. Michael’s Hospital, Toronto, Women’s College Hospital, Hamilton-Niagara-Haldimand-Brant Community Care Access Centre, Toronto Central Community Care Access Centre | Treatment, randomized, open label, active control, parallel assignment, safety/efficacy study – Participants will receive standard dressings changes as needed. Different dressing types (e.g., silver, simple gauze, hydrogel, foam, creams, gels) will be used dependent on the type of the wound (e.g., dry, wet, and intermediate) vs. Negative Pressure Wound Therapy (Vacuum-Assisted Closure System [V.A.C.® Therapy™]) | Assess the difference in the percent reduction in wound surface area, without surgery, of chronic pressure ulcers of the pelvic region for Negative Pressure Wound Therapy (NPWT) at 12 weeks compared to standard dressing. Efficacy, cost-effectiveness, safety and quality of life will also be evaluated for standard wound dressing versus NPWT. | July 2008 | March 2011 | 184 adults, ages 18 years and older | Studies comparing NPWT to a comparator treatment
NCT00243620 | Maastricht University Medical Center in collaboration with KCI medical B.V. | Treatment, randomized, open label, active control, parallel assignment, efficacy study – VAC vs. standard wound care according to the SIGN guideline and a multiple-layer compression bandage until complete healing. Four basic types of commercially available wound dressings will be used in this study including hydrogels, alginates, hydrocolloids, and films. The choice of dressing most depended on the ulcer type, the amount of exudate and the physician’s preference. | Measure the efficacy of vacuum-assisted closure versus modern wound dressings in the treatment of chronic leg ulcers. Primary focus will be on time-to-complete-healing. | May 2001 | May 2004 | 60 adults up to 85 years of age | Studies comparing NPWT to a comparator treatment
NCT00121537 | The University of Texas Health Science Center at San Antonio | Treatment, randomized, open label, active control, single group assignment – Vacuum-assisted closure versus standard wet to dry dressing | Measure the efficacy of vacuum-assisted closure versus standard wet to dry dressing in treating lower leg fasciotomy. Primary focus will be on rate of wound healing. | July 2005 | Not provided | 30 adults, ages 18 years and older | Studies comparing NPWT to a comparator treatment
NCT00635479 | University of Missouri-Columbia | Treatment, randomized, open label, parallel assignment, efficacy study – Vacuum-Assisted Closure (VAC) device for surgical incision vs. Gauze dressing for surgical incision | Examine the efficacy and cost effectiveness of the VAC device in comparison to traditional gauze wound dressing in pelvic fractures and acetabular fractures. Specific focus will be on potential reductions in the incidence of post-operative surgical wound drainage, infections, and hospital stay. | March 2008 | December 2008 | 50 adults, ages 18 years and older | Studies comparing NPWT to a comparator treatment
NCT00224796^b^ | KCI USA, Inc. | Treatment, randomized, open label, active control, parallel assignment, safety/efficacy study – Vacuum-Assisted Closure (V.A.C.®) Therapy vs. moist wound therapy | Compare the effectiveness of Vacuum Assisted Closure (V.A.C.®) Therapy to moist wound therapy of amputation wounds of the diabetic foot. | May 2002 | October 2005 | 146 adults, ages 18 years and older | Studies comparing NPWT to a comparator treatment
NCT00234559 | KCI USA, Inc. | Treatment, randomized, open label, active control, parallel assignment – vacuum-assisted closure (VAC®) therapy compared to moist wound therapy | Determine:; 1. If vacuum-assisted closure therapy results in altered proteomic expression of angiogenic markers compared to moist wound therapy.; 2. If vacuum-assisted closure therapy results in increased angiogenesis compared to moist wound therapy. | September 2005 | Not provided | 20 adults, ages 18 years and older | Studies comparing NPWT to a comparator treatment
NCT00548314 | Association of Dutch Burn Centres | Treatment, randomized, open label, parallel assignment, efficacy study – dermal substitute Matriderm, split skin graft and VAC therapy vs. dermal substitute Matriderm, and split skin graft vs. split skin graft and VAC therapy vs. split skin graft | Determine whether a treatment of full thickness wounds by the dermal substitute Matriderm, split skin graft and VAC treatment will improve scar quality. Additional areas of focus include: increase on the take of graft, improvement of scar assessment scale, scar color/pigmentation and time to complete healing. | October 2007 | Not provided | 72 adults, ages 18 years and older | Studies comparing NPWT to a comparator treatment
NCT00605189 | KCI USA, Inc. | Basic science, randomized, open label, parallel assignment – Powered Suction Pump (VAC Freedom) continuous suction vs. Powered Suction Pump continuous suction vs. Moist Wound Therapy (Allevyn, Tielle, SoloSite, Curagel) Foam Dressings, Hydrogel Impregnated Gauze, Hydrogel Sheet Dressings | Examine how cellular energies and oxygenation levels are related to various wound treatment therapies in patients with diabetic foot ulcers. | July 2007 | August 2008 | 39 adults with Type II diabetes and chronic diabetic foot ulcers | Studies comparing NPWT to a comparator treatment
NCT00494793 | Malmö University Hospital in collaboration with Gävle Hospital, Falu Hospital, Kinetic Concepts, Inc., and The Swedish Research Council | Treatment, open label, uncontrolled, single group assignment, efficacy study – vacuum-assisted wound closure (VAWC) and mesh mediated fascial traction for closure of open abdomens | Prospectively evaluate a combination of vacuum-assisted wound closure and mesh mediated fascial traction for closure of open abdomens. | February 2006 | February 2012 | 10 adult open abdomen patients | Studies comparing NPWT to a comparator treatment
ISRCTN67751142^b^ | Department of Health, London, UK, in collaboration with Hillingdon Hospital NHS Trust | RCT - compression pump and suction therapy versus standard 4-layer bandages | Determine if the use of compression pump and V.A.C. suction therapy provide better management for venous ulcers than standard 4-layer bandages | February 2005 | March 2007 | NR | Studies comparing NPWT to a comparator treatment
ISRCTN86386707^b^ | VU University Medical Center; funded by NOW-Biopartner First Stage Grant | RCT - 5 day prior wound bed preparation with Vacuum-Assisted Closure therapy (VAC) vs. 5 day prior wound bed preparation with VAC followed by application of Tiscover | Determine if ulcers treated with Tiscover (cultured, autologous skin) will significantly decrease in size resulting in most cases in full healing, compared to the control group (VAC), which is not treated with Tiscover | October 2005 | October 2007 | 100 | Studies comparing NPWT to a comparator treatment

a Device comparison

b Completed

c Suspended

d Not yet open

e Ongoing, but not recruiting