# Discussion and Conclusions

Based on our defined search strategies and the materials provided by interested parties, no studies directly comparing one NPWT system to another NPWT system were identified that addressed Key Question 1, 2, or 4. Thus, we were not able to identify a significant therapeutic distinction of one NPWT system or component over another through the use of head-to-head comparisons.

In the absence of head-to-head comparison studies, we searched the clinical literature to identify comparison studies of NPWT systems versus a common comparator. We attempted to assess the relative efficacy and/or safety of different NPWT systems using adjusted indirect comparisons. Our review of 40 comparison studies found that all of the controlled trials involved the evaluation of one NPWT device, the V.A.C.® manufactured by KCI. Furthermore, to be considered for inclusion in an indirect comparison, studies must be RCTs and must provide sufficient information to determine their comparability in terms of patient characteristics, patient exclusion/inclusion criteria, methodology, outcome definitions, outcome measures, and application of the comparison treatment. Only nine of the KCI VAC® comparison studies were RCTs and none of these RCTs met the requirements necessary for the indirect comparison option had there been studies of more than one NPWT system. Consequently, at this time the available evidence cannot be used to determine a significant therapeutic distinction of a NPWT system.

None of the 40 comparison studies met the design and conduct requirements to be considered high quality, only seven studies could be considered moderate quality, and the majority of studies (82%) were rated low quality. A low quality study rating calls into question the internal validity of study results and reduces our confidence in the relationship between the interventions and the outcomes. Our conclusions about study quality are also in agreement with the systematic reviews examined in this report. These reviews indicated that the majority of evidence on NPWT was of poor quality.

In their systematic review of clinical studies of NPWT, Peinemann et al.(189) sought to identify unpublished completed or discontinued RCTs to gain a broader knowledge of the NPWT evidence. The authors were concerned that previous systematic review conclusions on efficacy and safety based on published data alone may no longer hold after consideration of unpublished data. The authors invited two NPWT device manufacturers Kinetic Concepts Inc. (V.A.C.®) and BlueSky Medical Group Inc.(BSM)(Versatile 1 Wound Vacuum System) and authors of conference abstracts to provide information on study status and publication status of sponsored trials. Responses were received from 10 of 17 (59%) authors and both manufacturers. BSM, however did not sponsor relevant RCTs and only provided information on case reports. Peienemann et al. concluded that the “lack of access to unpublished study results data raises doubts about the completeness of the evidence base on NPWT.”(189)

Our searches did not identify any studies comparing one NPWT system component to another NPWT system component that addressed Key Question 2. No studies of this design were submitted by interested parties. This question was designed to examine studies that compared different dressing sets, tubing, or pumps while maintaining identical components for the other parts of an NPWT system. In particular we were looking for studies that evaluated gauze versus foam dressing sets in various wound types. This would help determine which dressing approach may provide the best potential for wound healing in a variety of wound care situations. The clinical trials now in development or nearing completion examine many different wound types (see Table 12) but do not address the merits of gauze versus foam within NPWT systems. The recently completed studies from the Cleveland Clinic (NCT00583141; NCT00590369) may address this question but the details of the study design are presently unavailable. The investigators did not wish to disclose any details of the study design prior to publication.

We did identify one high-quality study(116) that compared an electrical pump to a Redon set as vacuum sources while using the same foam dressing set. The findings of this study indicate that the vacuum bottle approach to applying negative pressure to a pressure ulcer is not appropriate. However this study does not directly address any of the questions posed in this report.

Our assessment of adverse events in the evidence base used to address Key Question 3 indicates that the most commonly reported adverse events associated with NPWT are pain, bleeding, and infection. While reports were similar for complications such as bleeding or infection, fewer reports of serious harms (i.e., secondary amputations, graft failure) have been reported when using NPWT compared to patients treated by comparator treatments. Of the 37 studies reporting events, seven (19%) studies described NPWT as a safe treatment. Fewer complications were reported in the NPWT-treated patients than in those receiving other wound therapies in 19 (51%) studies and similar complications were reported in 8 (22%) studies. Due to the lack of studies comparing one NPWT system to another NPWT system, we were unable to determine the severity of adverse events for one NPWT system compared to another (Key Question 4).

Clinical research on NPWT capable of indicating if any one NPWT system or component provides a significant therapeutic distinction requires study design and conduct that will minimize the possibilities for bias. Important study design features that were not typically reported such as concealment of allocation, reporting of randomization methods, use of power analysis to ensure adequate study size, blinding patients and especially wound assessors, and reporting of complete wound healing data will insure the internal validity of study results. None of the studies included in the present review reported that the physicians were blinded to treatment assignment, and only 12% of the studies reported blinding of outcome assessors. In only 7% of studies was there concealment of allocation to treatment, one of the most crucial elements of any randomized controlled trial with failure typically resulting in selection bias.(183,190) Selection bias refers to the presence of systematic differences between the treatment group and the control group at the onset of a study. If the patient groups differ substantially in any way, this may contribute to systematic differences in outcomes that are unrelated to the intervention of interest. The most effective way of guarding against selection bias is to randomly assign patients to treatment groups and fully concealing the treatment allocation process during the randomization.

Findings from one wound type cannot be transferred to another so determining if any one NPWT system or component provides a significant therapeutic distinction relies on numerous high quality studies of several different wound types. In conclusion, the strongest evidence of efficacy will come from properly designed and conducted randomized controlled trials that have been replicated by independent research units.