# Stakeholder Submissions

Figure 5 Disposition of Documents Submitted by Interested Stakeholders

Note: Language has been corrected to reflect screening of meeting abstracts, poster presentations and other documents in addition to abstracts and full articles.

Figure 5 is an attrition diagram that depicts the status of documents that Interested Stakeholders submitted for possible inclusion in the report. The diagram begins with a box outlining the total submission of 1435 documents. Several boxes ensue which are connected by arrows going from top to bottom which follow the submissions as they are being screened for possible inclusion in the report. In the first frame, we remove duplicate submissions made by all interested stakeholders. 638 duplicate submissions were identified. An arrow leads from the 797 Unique Submissions to the Initial Screening Phase where documents may be excluded, used in our Background Section or passed to the next level. In this instance, 269 documents were identified for exclusion. 147 were case reports, abstracts, or poster presentations; two were product information; 28 were personal communications; and 92 were other documents not relevant to the report. 29 documents were identified for inclusion in our Background Section and included 510(k) clearance information from the FDA and information from product labels and brochures. The path then follows the 499 full articles remaining. During this phase of screening we do a more extensive screening of the full articles which is based on our pre-determined inclusion/exclusion criteria. See our Methods Section for additional information on the criteria. 354 articles were excluded during this evaluation phase. 39 were animal studies; four were cost analyses; ten were duplicate studies; 30 included fewer than 5 patients; 13 were guidelines; five were homemade devices; four were in vitro studies; 152 were narrative reviews; ten did not include relevant outcomes; five were not clinical studies; 11 did not include a NPWT device; 28 were not a NPWT study and 43 were excluded for Other Reasons which may include “inclusion of healthy subjects”, “lack of reporting wound healing outcomes” or “patients treated with dual therapies.” Of the 144 full articles remaining for possible inclusion in the report; 117 were already identified in our literature searches. Of the 27 articles that ultimately met the inclusion criteria but were not identified in the literature searches; three studies addressed Key Question 1; 23 studies were relevant to Key Question 3; and one was included as a systematic review of NPWT. In addition, we included one unpublished study in Key Question 3 due to relevancy of the article bringing a total of 24 studies that addressed Key Question 3. Note: Language has been corrected to reflect screening of meeting abstracts, poster presentations and other documents in addition to abstracts of full articles.

Figure 6 Disposition of Submission by American Association for the Advancement of Wound Care

Note: Language has been corrected to reflect screening of meeting abstracts, poster presentations and other documents in addition to abstracts and full articles.

Figure 6 is an attrition diagram that depicts the status of documents that the American Association for the Advancement of Wound Care submitted for possible inclusion in the report. The diagram begins with a box outlining the total submission of 582 documents. Several boxes ensue which are connected by arrows going from top to bottom which follow the submissions as they are being screened for possible inclusion in the report. In the first frame, we compare AAWC’s submission to submissions by other interested stakeholders and remove any duplicates. AAWC had 582 duplicate submissions. Due to the exclusion of all 582 submissions, zero submissions remained for possible inclusion in the report. Note: Language has been corrected to reflect screening of meeting abstracts, poster presentations and other documents in addition to abstracts of full articles.

Table 43 Status of Submissions by American Association for the Advancement of Wound Care

Reference Number | Reference | Included | Placement in Report | Excluded | Reason for Exclusion | Included but Not Identified in ECRI Search
(390) | Abai B, Zickler RW, Pappas PJ, Lal BK, Padberg FT Jr. Lymphorrhea responds to negative pressure wound therapy. J Vasc Surg 2007 Mar;45(3):610-3. | | | ✓ | Fewer than five patients
(152) | Adamkova M, Tymonova J, Zamecnikova I, Kadlcik M, Klosova H. First experience with the use of vacuum assisted closure in the treatment of skin defects at the Burn Center. Acta Chir Plast 2005;47(1):24-7. | ✓ | KQ3
(372) | Agarwal JP, Ogilvie M, Wu LC, Lohman RF, Gottlieb LJ, Franczyk M, Song DH. Vacuum-assisted closure for sternal wounds: A first-line therapeutic management approach. Plast Reconstr Surg 2005 Sep 15;116(4):1035-40. | ✓ | KQ3
(391) | Agrawal S, Hayhurst C, Joseph T, Prinsloo D, Morgan RH, Pherwani AD. Successful salvage of infected and exposed non-absorbable mesh following decompressing laparostomy after emergency repair of ruptured abdominal aortic aneurysm using vacuum-assisted closure system. Eur J Vasc Endovasc Surg 2008 Jan;15(1):1-2. | | | ✓ | Narrative
(392) | Aguinaga S, Welber A, Stephens S. Positive steps towards negative pressure wound therapy. Medsurg Nurs 2007 Jun;16(3):181-2, 189. | | | ✓ | Narrative
(393) | Alvarez AA, Maxwell GL, Rodriguez GC. Vacuum-assisted closure for cutaneous gastrointestinal fistula management. Gynecol Oncol 2001 Mar;80(3):413-6. | | | ✓ | Case report
(394) | Andrabi SI, Ahmad J, Rathore MA, Yousaf M. Vacuum assisted closure of laparostomy wounds "a novel technique". J Ayub Med Coll Abbottabad 2007 Jul–Sep;19(3):89-92. | | | ✓ | Case report
(395) | Andrabi SI, Ahmad J. Negative pressure therapy for laparotomy wounds--a word of caution. J Wound Ostomy Continence Nurs 2007 Jul–Aug;34(4):425-7. | | | ✓ | Case report
(396) | Andrews BT, Smith RB, Chang KE, Scharpf J, Goldstein DP, Funk GF. Management of the radial forearm free flap donor site with the vacuum-assisted closure (VAC) system. Laryngoscope 2006 Oct;116(10):1918-22. | | | ✓ | No relevant outcomes
(88) | Andrews BT, Smith RB, Goldstein DP, Funk GF. Management of complicated head and neck wounds with vacuum-assisted closure system. Head Neck 2006 Nov;28(11):974-81. | ✓ | KQ3 | | | ✓
(397) | Andrews BT, Smith RB, Hoffman HT, Funk GF. Orocutaneous and pharyngocutaneous fistula closure using a vacuum-assisted closure system. Ann Otol Rhinol Laryngol 2008 Apr;117(4):298-302. | | | ✓ | Fewer than five patients
(398) | Andros G, Armstrong DG, Attinger C, Boutlon AJ, Frykberg RG, Joseph WS, Lavery LA, Morbach S, Niezgoda JA, Toursarkissian B. Consensus statement on negative pressure wound therapy (VAC Therapy) for the management of diabetic foot wounds. Wounds 2006 Jun;52(6 Suppl):1-32. | | | ✓ | Guideline
(385) | Antony S, Terrazas S. A retrospective study: Clinical experience using vacuum-assisted closure in the treatment of wounds. J Natl Med Assoc 2004;96(8):1073-7. | ✓ | KQ3
(192) | Apelqvist J, Armstrong DG, Lavery LA, Boulton AJ. Resource utilization and economic costs of care based on a randomized trial of vacuum-assisted closure therapy in the treatment of diabetic foot wounds. Am J Surg 2008 Jun;195(6):782-8. | | | ✓ | Cost analysis
(399) | Arca MJ, Somers KK, Derks TE, Goldin AB, Aiken JJ, Sato TT, Shilyansky J, Winthrop A, Oldham KT. Use of vacuum-assisted closure system in the management of complex wounds in the neonate. Pediatr Surg Int 2005 Jul;21(7):532-5. Epub 2005 Jun 17. | | | ✓ | Fewer than five patients
(400) | Archdeacon MT, Messerschmitt P. Modern papineau technique with vacuum-assisted closure. J Orthop Trauma 2006 Feb;20(2):134-7. | | | ✓ | Case report
(401) | Argenta LC, Morykwas MJ, Marks MW, DeFranzo AJ, Molnar JA, David LR. Vacuum-assisted closure: state of clinic art. Plast Reconstr Surg 2006 Jun;117(7 Suppl):127S-142S. | | | ✓ | Narrative
(148) | Argenta LC, Morykwas MJ. Vacuum-assisted closure: a new method for wound control and treatment: clinical experience. Ann Plast Surg 1997 Jun;38(6):563-76; discussion 577. | ✓ | KQ3 | | | ✓
(402) | Argenta PA, Rahaman J, Gretz HF 3rd, Nezhat F, Cohen CJ. Vacuum-assisted closure in the treatment of complex gynecologic wound failures. Obstet Gynecol 2002 Mar;99(3):497--501. | | | ✓ | Fewer than five patients
(403) | Armstrong DG, Attinger CE, Boulton AJ, Frykberg RG, Kirsner RS, Lavery LA, Mills JL. Guidelines regarding negative wound therapy (NPWT) in the diabetic foot. Ostomy Wound Manage 2004 Apr;50(4B Suppl):3S-27S. | | | ✓ | Guideline
(404) | Armstrong DG, Boulton AJ, Banwell P. Negative pressure wound therapy in treatment of diabetic foot wounds: a marriage of modalities. Ostomy Wound Manage 2004 Apr;50(4A Suppl):9-12. | | | ✓ | Narrative
(194) | Armstrong DG, Kunze K, Martin BR, Kimbriel HR, Nixon BP, Boulton AJ. Plantar pressure changes using a novel negative pressure wound therapy technique. J Am Podiatr Med Assoc 2004 Sep–Oct;94(5):456-60. | | | ✓ | Not a NPWT study
(85) | Armstrong DG, Lavery LA, Abu-Rumman P, Espensen EH, Vazquez JR, Nixon BP, Boulton AJ. Outcomes of subatmospheric pressure dressing therapy on wounds of the diabetic foot. Ostomy Wound Manage 2002 Apr;48(4):64-8. | ✓ | KQ3 | | | ✓
(109) | Armstrong DG, Lavery LA, Boulton AJ. Negative pressure wound therapy via vacuum-assisted closure following partial foot amputation: what is the role of wound chronicity?. Int Wound J 2007 Mar;4(1):79-86. | ✓ | KQ1, KQ3
(195) | Armstrong DG, Lavery LA, Diabetic Foot Study Consortium. Negative pressure wound therapy after partial diabetic foot amputation: a multicentre, randomised controlled trial. Lancet 2005 Nov 12;366(9498):1704-10. | | | ✓ | Study population reported in(109)
(405) | Armstrong DG, Lavery LA. Decreasing foot pressures while implementing topical negative pressure (vacuum-assisted closure) therapy. Int J Low Extrem Wounds 2004 Mar;3(1):12-5. | | | ✓ | Narrative
(406) | Attar KH, Imran D, Iyer S. Vacuum-assisted closure (VAC) therapy in the management of digital pulp defects. Acta Chir Plast 2007;49(3):75–6. | | | ✓ | Case report
(92) | Avery C, Pereira J, Moody A, Gargiulo M, Whitworth I. Negative pressure wound dressing of the radial forearm donor site. Int J Oral Maxillofac Surg 2000 Jun;29(3):198-200. | ✓ | KQ3
(407) | Aydin U, Ozgenel Y. A simple solution for preventing air leakage in VAC therapy for sacral pressure sores. J Plast Reconstr Aesthet Surg 2008 Oct;61(10):1267-9. | | | ✓ | Narrative
(408) | Ayello EA, Baranoski S, Morey J. VAC heals complex wounds. Nurs Spectrum (Phila Tri- State) 2003 Dec;15(24):16-17. | | | ✓ | Narrative
(409) | Azad SM, Allison K, Khwaja N, Moiemen N. Frostbite of the gluteal region. Burns 2003 Nov;29(7):739-44. | | | ✓ | No abstract available
(410) | Baharestani M, de Leon J, Mendez-Eastman S, Powell G, Weir D, Niezgoda J, Payne W, Nanney LB, Pelham F, Gupta S. Consensus statement: a practical guide for managing pressure ulcers with negative pressure wound therapy utilizing vacuum-assisted closure. Understanding the treatment algorithm. Adv Skin Wound Care 2008 Jan;21(Suppl 1):1-20. | | | ✓ | Guideline
(411) | Baharestani MM, Driver VR, de Leon JM, Gabriel A, Kaplan M, Lantis J, Lavery L, Pelham F, Powell G, Webb L. Optimizing clinical and cost effectiveness with early intervention of V.A.C. therapy. Ostomy Wound Manage 2008;54(11 Suppl):1-15. | | | ✓ | Narrative
(199) | Baharestani MM, Houliston-Otto DB, Barnes S. Early versus late initiation of negative pressure wound therapy: examining the impact on home care length of stay. Ostomy Wound Manage 2008 Nov;54(11):48-53. | | | ✓ | No relevant outcomes
(93) | Baharestani MM. Negative pressure wound therapy in the adjunctive management of necrotizing fascitis: examining clinical outcomes. Ostomy Wound Manage 2008 Apr;54(4):44-50. | ✓ | KQ3
(412) | Baharestani MM. Negative pressure wound therapy: an examination of cost-effectiveness. Ostomy Wound Manage 2004 Nov;50(11A Suppl):29S-33S. | | | ✓ | Cost analysis
(162) | Baharestani MM. Use of negative pressure wound therapy in the treatment of neonatal and pediatric wounds: a retrospective examination of clinical outcomes. Ostomy Wound Manage 2007 Jun;53(6):75-85. | ✓ | KQ3
(413) | Ballard K, McGregor F. Use of vacuum-assisted closure therapy following foot amputation. Br J Nurs 2001 Aug;10(15 Suppl):S6-12. | | | ✓ | Case report
(344) | Bannasch H, Iblher N, Penna V, Torio N, Felmerer G, Stark GB, Momeni A. A critical evaluation of the concomitant use of the implantable Doppler probe and the Vacuum Assisted Closure system in free tissue transfer. Microsurgery 2008;28(6):412-6. | ✓ | KQ3
(414) | Banwell PE, Ahmed S, Teot L. Topical negative pressure versus closed surgical wound drainage: a difference in philosophy. J Wound Care 2005 Oct;14(9):445-7. | | | ✓ | Narrative
(415) | Banwell PE, Musgrave M. Topical negative pressure therapy: mechanisms and indications. Int Wound J 2004 Jun;1(2):95-106. | | | ✓ | Narrative
(416) | Banwell PE, Teot L. Topical negative pressure (TNP): the evolution of a novel wound therapy. J Wound Care 2003 Jan;12(1):22-8. | | | ✓ | Narrative
(417) | Banwell PE. Topical negative pressure therapy in wound care. J Wound Care 1999 Feb;8(2):79-84. | | | ✓ | Narrative
(418) | Banwell PE. Topical negative pressure therapy: advances in burn wound management. Ostomy Wound Manage 2004 Nov;50(11A-Suppl):9S-14S. | | | ✓ | Narrative
(153) | Bapat V, El-Muttardi N, Young C, Venn G, Roxburgh J. Experience with vacuum-assisted closure of sternal wound infections following cardiac surgery and evaluation of chronic complications associated with its use. J Card Surg 2008 May;23(3):227-33. | ✓ | KQ3
(200) | Barker DE, Kaufman HJ, Smith LA, Ciraulo DL, Richart CL, Burns RP. Vacuum pack technique of temporary abdominal closure: a 7-year experience with 112 patients. J Trauma 2000 Feb;48(2):201-6; discussion 206-7. | | | ✓ | Homemade device
(202) | Barringer CB, Gorse SJ, Burge TS. The VAC dressing— a cautionary tale. Br J Plast Surg 2004 Jul;57(5):482. | | | ✓ | No abstract available
(419) | Baxandall T. Tissue viability. Healing cavity wounds with negative pressure. Nurs Stand 1996 Oct 30;11(6):49-51. | | | ✓ | Narrative
(420) | Baynham SA, Kohlman P, Katner HP. Treating stage IV pressure ulcers with negative pressure therapy: a case report. Ostomy Wound Manage 1999 Apr;45(4):28-32, 34-5. | | | ✓ | Case report
(421) | Benbow M, Beldon P, Butcher M, Newton H, Hampton S, Baxter H. Topical negative pressure: a systemic review of the available evidence. J Community Nurs 2007 Jun;21(6) | | | ✓ | Not relevant – focus on access and usage of total negative pressure
(422) | Benbow M. Update on VAC therapy.Journal of Community Nursing-Online; 2006 Apr [accessed 2006 Nov 15]. Available: http://www.jcn.com.uk/. | | | ✓ | Narrative
(82) | Bendewald FP, Cima RR, Metcalf DR, Hassan I. Using negative pressure wound therapy following surgery for complex pilonidal disease: a case series. Ostomy Wound Manage 2007 May;53(5):40-6. | ✓ | KQ3 | | | ✓
(76) | Bendo JA, Quirno M, Pelham F, Barone JA, Awad J. Posterior lumbar wound drainage management with vacuum-assisted closure. World Spine J 2007 Sep;2(4):187-90. | ✓ | KQ3 | | | ✓
(423) | Bennett W. Novel use of VAC therapy in a patient with lymphocele after varicose surgery. Wounds UK 2007 Dec;3(4):129-32. | | | ✓ | Case report
(424) | Bernstein BH, Tam H. Combination of subatmospheric pressure dressing and gravity feed antibiotic instillation in the treatment of post-surgical diabetic foot wound: a case series. Wounds 2005 Feb;17(2):37-48. | | | ✓ | Narrative
(425) | Bertelsen CA, Wille-Jorgensen P. Use of topical negative pressure to manage a complex wound with a vesicocutaneous fistula. J Wound Care 2006 Apr;15(4):172-3. | | | ✓ | Case report
(350) | Bhattacharyya T, Mehta P, Smith M, Pomahac B. Routine use of wound vacuum-assisted closure does not allow coverage delay for open tibia fractures. Plast Reconstr Surg 2008 Apr;121(4):1263-6. | ✓ | KQ3
(134) | Bickels J, Kollender Y, Wittig JC, Cohen N, Meller I, Malawer MM. Vacuum-assisted wound closure after resection of musculoskeletal tumors. Clin Orthop Relat Res 2005 Dec;441:346-50. | ✓ | KQ1, KQ3
(426) | Birchall L, Street L, Clift H. Developing a trust-wide centralized approach to the use of TNP. J Wound Care 2002 Sep;11(8):311-4. | | | ✓ | Narrative
(427) | Blackburn JH 2d, Boemi L, Hall WW, Jeffords K, Hauck RM, Banducci DR, Graham WP 3d. Negative-pressure dressings as a bolster for skin grafts. Ann Plast Surg 1998 May;40(5):453-7. | | | ✓ | Narrative
(108) | Blume PA, Walters J, Payne W, Ayala J, Lantis J. Comparison of negative pressure wound therapy using vacuum-assisted closure with advanced moist wound therapy in the treatment of diabetic foot ulcers: a multicenter randomized controlled trial. Diabetes Care 2008 Apr;31(4):631-6. | ✓ | KQ1, KQ3
(141) | Bollero D, Carnino R, Risso D, Gangemi EN, Stella M. Acute complex traumas of the lower limbs: A modern reconstructive approach with negative pressure therapy. Wound Repair Regen 2007 Jul;15(4):589-94. | ✓ | KQ3
(428) | Bolton LL. Negative pressure wound therapy. Wounds 2005 Apr;17(4):A29-A32. | | | ✓ | Narrative
(429) | Bonnet F, Pavy B, Beaudoin S, Dubousset J, Mitrofanoff M. Treatment of a large defect of the chest wall in a child using a negative pressure wound dressing. Scand J Plast Reconstr Surg Hand Surg 2007;41(3):143-5. | | | ✓ | Case report
(430) | Bookout K, McCord S, McLane K. Case studies of an infant, a toddler, and an adolescent treated with a negative pressure wound treatment system. J Wound Ostomy Continence Nurs 2004 Jul–Aug;31(4):184-92. | | | ✓ | Fewer than five patients
(207) | Bovill E, Banwell PE, Teot L, Eriksson E, Song C, Mahoney J, Gustafsson R, Horch R, Deva A, Whitworth I, International Advisory Panel on Topical Negative Pressure. Topical negative pressure wound therapy: a review of its role and guidelines for its use in the management of acute wounds. Int Wound J 2008 Oct;5(4):511-29. | | | ✓ | Narrative
(114) | Braakenburg A, Obdeijn MC, Feitz R, van Rooij IA, van Griethuysen AJ, Klinkenbijl JH. The clinical efficacy and cost effectiveness of the vacuum-assisted closure technique in the management of acute and chronic wounds: a randomized controlled trial. Plast Reconstr Surg 2006 Aug;118(2):390-7; discussion 398-400. | ✓ | KQ1, KQ3
(431) | Brace JA. Negative pressure wound therapy for abdominal wounds. J Wound Ostomy Continence Nurs 2007 Jul–Aug;34(4):428-30. | | | ✓ | Narrative
(345) | Brandi C, Grimaldi L, Nisi G, Silvestri A, Brafa A, Calabro M, D’Aniello C. Treatment with vacuum-assisted closure and cryo-preserved homologous de-epidermalised dermis of complex traumas to the lower limbs with loss of substance, and bones and tendons exposure. J Plast Reconstr Aesthet Surg 2008 Dec;61(12):1507-11. | ✓ | KQ3
(432) | Brogna L. Home care management of an ostomy within a dehisced abdominal wound. J Wound Ostomy Continence Nurs 2005 May–Jun;32(3):200-2; discussion 202-4. | | | ✓ | Case reports
(433) | Bronchard R, de Vaumas C, Lasocki S, Jabbour K, Geffroy A, Kermarrec N, Montravers P. Vacuum-assisted closure in the treatment of perineal necrotizing skin and soft tissue infections. Intensive Care Med 2008 Jul;34(7):1345-7. | | | ✓ | No abstract available
(434) | Bronson N, Menon R, Butler J, Gordon I. Parathyroidectomy, excision and skin grafting with topical negative pressure for calciphylactic ulcers. J Wound Care 2007 Jul;16(7):295-7. | | | ✓ | Case report
(435) | Brown KM, Harper FV, Aston WJ, O’Keefe PA, Cameron CR. Vacuum-assisted closure in the treatment of a 9-year-old child with severe and multiple dog bite injuries of the thorax. Ann Thorac Surg 2001 Oct;72(4):1409-10. | | | ✓ | Case report
(436) | Burton L. Nonhealing foot ulcer. Ostomy Wound Manage 1999 Sep;45(9):20-1. | | | ✓ | Case report
(144) | Butter A, Emran M, Al-Jazaeri A, Ouimet A. Vacuum-assisted closure for wound management in the pediatric population. J Pediatr Surg 2006 May;41(5):940-2. | ✓ | KQ3
(437) | Canavese F, Gupta S, Krajbich JI, Emara KM. Vacuum-assisted closure for deep infection after spinal instrumentation for scoliosis. J Bone Joint Surg Br 2008 Mar;90(3):377-81. | ✓ | KQ3
(165) | Caniano DA, Ruth B, Teich S. Wound management with vacuum-assisted closure: experience in 51 pediatric patients. J Pediatr Surg 2005 Jan;40(1):128-32; discussion 132. | ✓ | KQ3
(438) | Canter HI, Isci E, Erk Y. Vacuum-assisted wound closure for the management of a foot ulcer due to Buerger’s disease. J Plast Reconstr Aesthet Surg 2007 Nov 1;Epub ahead of print. | | | ✓ | Case report
(439) | Carson SN, Overall K, Lee-Jahshan S, Travis E. Vacuum-assisted closure used for healing chronic wounds and skin grafts in the lower extremities. Ostomy Wound Manage 2004 Mar;50(3):52-8. | | | ✓ | Narrative
(137) | Catarino PA, Chamberlain MH, Wright NC, Black E, Campbell K, Robson D, Pillai RG. High-pressure suction drainage via a polyurethane foam in the management of poststernotomy mediastinitis. Ann Thorac Surg 2000 Dec;70(6):1891-5. | | | ✓ | Not relevant (suction drainage)
(440) | Chandawarkar RY, Piorkowski J, Amjad I, Deckers PJ. Combination therapy of a large, recurrent keloid. Dermatol Surg 2007 Feb;33(2):229-35. | | | ✓ | Case report
(441) | Chaouat M, Bonnet F, Seroussi D, Smarrito S, Mimoun M. Topical negative pressure for the treatment of complex cavity wounds associated with osteitis. J Wound Care 2006 Jul;15(7):292-4. | | | ✓ | Fewer than five patients
(442) | Chariker ME, Jeter KF, Tintle TE, Bottsford JE. Effective management of incisional and cutaneous fistulae with close suction wound drainage. Contemp Surg 1989 Jun;34:59-63. | | | ✓ | Homemade device
(443) | Chave H, Ahmed S, Fu B, Webber J, Banwell P, Tiernan E. Salvage of infected dermal collagen implants with topical negative pressure therapy. J Wound Care 2006 Apr;15(4):156-8. | | | ✓ | Case report
(444) | Chen SZ, Li J, Li XY, Xu LS. Effects of Vacuum-assisted Closure on Wound Microcirculation: An Experimental Study. Asian J Surg 2005 Jul;28(3):211-7. | | | ✓ | Animal study
(160) | Chen Y, Almeida AA, Mitnovetski S, Goldstein J, Lowe C, Smith JA. Managing deep sternal wound infections with vacuum-assisted closure. ANZ J Surg 2008 May;78(5):333-6. | ✓ | KQ3
(445) | Chesher E. Use of vacuum-assisted closure in the community. Prim Intent 1998 Feb;6(1):12-15. | | | ✓ | Case report
(446) | Chester DL, Waters R. Adverse alteration of wound flora with topical negative-pressure therapy: a case report. Br J Plast Surg 2002 Sep;55(6):510-1. | | | ✓ | Case report
(447) | Childress B, Stechmiller JK, Schultz GS. Arginine metabolites in wound fluids from pressure ulcers: a pilot study. Biol Res Nurs 2008 Oct;10(2):87-92. | | | ✓ | No relevant outcomes
(448) | Chung CJ, David LR, Morykwas M, Argenta L. Case review: management of life-threatening sepsis and wound healing in a Klippel-Trenaunay patient using serial surgical debridements and vaccum-assisted closure. Eur J Plastic Surg 2003 Jul;26(4):214-16. | | | ✓ | Case report
(379) | Clare MP, Fitzgibbons TC, McMullen ST, Stice RC, Hayes DF, Henkel L. Experience with the Vacuum Assisted Closure negative pressure technique in the treatment of non-healing diabetic and dysvascular wounds. Foot Ankle Int 2002 Oct1;23(10):896-901. | ✓ | KQ3
(449) | Coggrave M, West H, Leonard B. Topical negative pressure for pressure ulcer management. Br J Nurs 2002 Mar;11(6 Suppl):S29-36. | | | ✓ | Case reports
(450) | Colwell AS, Donaldson MC, Belkin M, Orgill DP. Management of Early Groin Vascular Bypass Graft Infections with Sartorius and Rectus Femoris Flaps. Ann Plast Surg 2004;52(1):49-53. | | | ✓ | Not relevant – focus on effectiveness of muscle flaps
(185) | Contractor D, Amling J, Brandoli C, Tosi LL. Negative pressure wound therapy with reticulated open cell foam in children: an overview. J Orthop Trauma 2008 Nov–Dec;22(10 Suppl):S167-76. | ✓ | Previous Systematic Reviews
(451) | Copson D. Topical negative pressure and necrotising fasciitis. Nurs Stand 2003 Oct 22-28;18(6):71-4, 76, 78 passim. | | | ✓ | Case report
(356) | Cothren CC, Moore EE, Johnson JL, Moore JB, Burch JM. One hundred percent fascial approximation with sequential abdominal closure of the open abdomen. Am J Surg 2006 Aug;192(2):238-42. | ✓ | KQ3
(373) | Cowan KN, Teague L, Sue SC, Mahoney JL. Vacuum-assisted wound closure of deep sternal infections in high-risk patients after cardiac surgery. Ann Thorac Surg 2005 Dec;80(6):2205-12. | ✓ | KQ3
(452) | Cravero L, Taveggia A, Boriani F, Bruschi S, Boriani F. Osteomyelitis: A possible diagnostic mistake after vacuum-assisted therapy. J Plast Reconstr Aesthet Surg 2006;59(11):1250-1. | | | ✓ | Case report
(453) | Cresti S, Ouaissi M, Sielezneff I, Chaix JB, Pirro N, Berthet B, Consentino B, Sastre B. Advantage of vacuum assisted closure on healing of wound associated with omentoplasty after abdominoperineal excision: a case report. World J Surg Oncol 2008 Dec 23;6(1):136. | | | ✓ | Case reports
(454) | Cro C, George KJ, Donnelly J, Irwin ST, Gardiner KR. Vacuum assisted closure system in the management of enterocutaneous fistulae. Postgrad Med J 2002 Jun;78(920):364-5. | | | ✓ | Fewer than five patients
(455) | Crumbley DR, Perciballi JA. Negative pressure wound therapy in a contaminated soft-tissue wound. J Wound Ostomy Continence Nurs 2007 Sep–Oct;34(5):507-12. | | | ✓ | No abstract available
(456) | Culliford AT 4th, Spector JA, Levine JP. A novel technique for vacuum assisted closure device application in noncontiguous wounds. J Plast Reconstr Aesthet Surg 2007;60(1):99-100. | | | ✓ | Case report
(457) | Dakin J, Thompson S. Use of topical negative pressure therapy with an abdominal dressing in management of a laparostomy. J Wound Care 2006 Oct;15(9):386-8. | | | ✓ | Case report
(458) | Datiashvili RO, Knox KR. Negative pressure dressing: an alternative to free tissue transfers?. Wounds 2005 Aug;17(8):206-12. | | | ✓ | Narrative
(459) | Davis L, Barker A. Coordination and management of TNP from acute to primary care: overcoming the issues. J Wound Care 2006 Apr;15(4):169-71. | | | ✓ | Narrative
(460) | Davydov IuA, Malafeeva EV, Smirnov AP, Flegontov VB. Vacuum therapy in the treatment of suppurative lactation mastitis. Vestn Khir Im I I Grek 1986 Nov;137(11):66-70. | | | ✓ | Not a NPWT device
(461) | Davydov YA, Larichev AB, Abramov AY, Menkov KG. Concepts for clinical biological management of the wound process in the treatment of purulent wounds using vacuum therapy] translated from Russian. Vestnik Khirurgii 1991 Feb;132-5. (Rus). | | | ✓ | Not a NPWT device
(462) | Davydov YA, Larichev AB, Menlov KG. The bacteriological and cytological assessment of vacuum therapy of purulent wounds] translated from Russian. Vestnik Khirurgii 1988 Oct;48-52. | | | ✓ | Not a NPWT device
(460) | Davydov YA, Malafeeva EV, Smirnov AP, Flegontov VB. [Vacuum therapy in the treatment of purulent lactation mastitis] translated from Russian. Vestnik Khirurgii 1986 Sep;66-70. (Rus). | | | ✓ | Not a NPWT device
(463) | de Geus HR, van der Klooster JM. Vacuum-assisted closure in the treatment of large skin defects due to necrotizing fasciitis. Intensive Care Med 2005 Apr;31(4):601. | | | ✓ | Case report
(464) | de la Torre JI, Martin SA, Oberheu AM, Vasconez LO. Healing a wound with an exposed Herrington rod: a case study. Ostomy Wound Manage 2002 May;48(5):18-9. | | | ✓ | Case report
(167) | De Lange MY, Schasfoort RA, Obdeijn MC, Van Der Werff JFA, Nicolai JPA. Vacuum-assisted closure: Indications and clinical experience. Eur J Plastic Surg 2000 May;23(4):178-82. | ✓ | KQ3
(8) | de Leon J. Negative pressure wound therapy in pressure ulcer management. Ostomy Wound Manage 2005 Feb;51(2A Suppl):3-8. | | | ✓ | Case reports
(465) | de Weerd L, Kjaeve J, Aghajani E, Elvenes OP. The sandwich design: a new method to close a high-output enterocutaneous fistula and an associated abdominal wall defect. Ann Plast Surg 2007 May;58(5):580-3. | | | ✓ | Case report
(27) | Dedmond BT, Kortesis B, Punger K, Simpson J, Argenta J, Kulp B, Morykwas M, Webb LX. The use of negative-pressure wound therapy (NPWT) in the temporary treatment of soft-tissue injuries associated with high-energy open tibial shaft fractures. J Orthop Trauma 2007 Jan;21(1):11-7. | ✓ | KQ3
(222) | Dedmond BT, Kortesis B, Punger K, Simpson J, Argenta J, Kulp B, Morykwas M, Webb LX. Subatmospheric pressure dressings in the temporary treatment of soft tissue injuries associated with type III open tibial shaft fractures in children. J Pediatr Orthop 2006 Nov;26(6):728-32. | | | ✓ | Duplicate study(27)
(466) | Dee A. The successful management of a dehisced surgical wound with TNP following femoropopliteal bypass. J Wound Care 2007 Jan;16(1):42-4. | | | ✓ | Case report
(157) | DeFranzo AJ, Argenta LC, Marks MW, Molnar JA, David LR, Webb LX, Ward WG, Teasdall RG. The use of vacuum-assisted closure therapy for the treatment of lower-extremity wounds with exposed bone. Plast Reconstr Surg 2001 Oct;108(5):1184-91. | ✓ | KQ3
(467) | DeFranzo AJ, Marks MW, Argenta LC, Genecov DG. Vacuum-assisted closure for the treatment of degloving injuries. Plast Reconstr Surg 1999 Dec;104(7):2145-8. | | | ✓ | Fewer than five patients
(156) | DeFranzo AJ, Pitzer K, Molnar JA, Marks MW, Chang MC, Miller PR, Letton RW, Argenta LC. Vacuum-assisted closure for defects of the abdominal wall. Plast Reconstr Surg 2008 Mar;121(3):832-9. | ✓ | KQ3
(468) | Demaria R, Giovannini UM, Teot L, Chaptal PA. Using VAC to treat a vascular bypass site infection. J Wound Care 2001 Feb;10(2):12-3. | | | ✓ | Case report
(145) | Demaria RG, Giovannini U, Teot L, Frapier JM, Albat B. A new technique for the treatment of delayed sternotomy healing: the vacuum therapy. Heart Surg Forum 2003;6(5):434-7. | ✓ | KQ3
(135) | Denzinger S, Lubke L, Roessler W, Wieland WF, Kessler S, Burger M. Vacuum-assisted closure versus conventional wound care in the treatment of wound failures following inguinal lymphadenectomy for penile cancer: a retrospective study. Eur Urol 2007 May;51(5):1320-5. | ✓ | KQ1, KQ3
(135) | Denzinger S, Lubke L, Roessler W, Wieland WF, Kessler S, Burger M. Vacuum-assisted closure versus conventional wound care in the treatment of wound failures following inguinal lymphadenectomy for penile cancer: a retrospective study. Eur Urol 2007 May;51(5):1320-5. | ✓ | KQ1, KQ3
(469) | Derrick KL, Norbury K, Kieswetter K, Skaf J, McNulty AK. Comparative analysis of global gene expression profiles between diabetic rat wounds treated with vacuum-assisted closure therapy, moist wound healing or gauze under suction. Int Wound J 2008 Dec;5(5):615-24. | | | ✓ | Animal study
(382) | Deva AK, Buckland GH, Fisher E, Liew SC, Merten S, McGlynn M, Gianoutsos MP, Baldwin MA, Lendvay PG. Topical negative pressure in wound management. Med J Aust 2000 Aug 7;173(3):128-31. | ✓ | KQ3
(470) | Deva AK, Siu C, Nettle WJ. Vacuum-assisted closure of a sacral pressure sore. J Wound Care 1997 Jul;6(7):311-2. | | | ✓ | Case report
(471) | Dickie SR, Dorafshar AH, Song DH. Definitive closure of the infected median sternotomy wound: a treatment algorithm utilizing vacuum-assisted closure followed by rigid plate fixation. Ann Plast Surg 2006 Jun;56(6):680-5. | | | ✓ | Algorithm
(472) | Dieu T, Leung M, Leong J, Morrison W, Cleland H, Archer B, Oppy A. Too much vacuum-assisted closure. ANZ J Surg 2003 Dec;73(12):1057-60. | | | ✓ | Narrative
(473) | Dobke MK, Nguyen D, Trott SA. A novel approach to acute infection of the glenohumeral joint following rotator cuff repair? A case series. Wounds 2005 Jun;17(6):137-40. | | | ✓ | No relevant outcomes
(129) | Domkowski PW, Smith ML, gonyon Jr DL, Drye C, Wooten MK, Levin LS, wolfe WG. Evaluation of vacuum-assisted closure in the treatment of poststernotomy mediastinitis. J Thorac Cardiovasc Surg 2003 Aug 1;126(2):386-90. | ✓ | KQ1, KQ3
(474) | Donovan DJ, Person DA. Giant eccrine adenocarcinoma of the scalp with intracranial invasion: resection and reconstruction using a vacuum-assisted closure device: technical case report. Neurosurgery 2006 Apr;58(4 Suppl 2):ONS-E371; discussion ONS. | | | ✓ | Case report
(475) | Dosluoglu HH, Schimpf DK, Schultz R, Cherr GS. Preservation of infected and exposed vascular grafts using vacuum assisted closure without muscle flap coverage. J Vasc Surg 2005 Nov;42(5):989-92. | | | ✓ | Fewer than five patients
(128) | Doss M, Martens S, Wood JP, Wolff JD, Baier C, Moritz A. Vacuum-assisted suction drainage versus conventional treatment in the management of poststernotomy osteomyelitis. Eur J Cardiothorac Surg 2002 Dec 1;22(6):934-8. | ✓ | KQ1, KQ3
(476) | Dunbar A, Bowers DM, Holderness H Jr. Silicone net dressing as an adjunct with negative pressure wound therapy. Ostomy Wound Manage 2005 Apr;51(4):18, 20. | | | ✓ | Case report
(477) | Durai R, Hoque H, Davies TW. ‘Indirect VAC’: a novel technique of applying vacuum-assisted closure dressing. J Perioper Pract 2008 Oct;18(10):437-9. | | | ✓ | Narrative
(478) | Duxbury MS, Finlay IG, Butcher M, Lambert AW. Use of a vacuum assisted closure device in pilonidal disease. J Wound Care 2003 Oct;12(9):355. | | | ✓ | Case report
(479) | Easterlin B, Bromberg W, Linscott J. A novel technique of vacuum assisted wound closure that functions as a delayed primary closure. Wounds 19(12):331-3. | | | ✓ | Narrative
(480) | Eberlein T, Fendler H. Case studies of Prospera NPWT. Available: http://www.prospera-npwt.com/clincal_references.htm. | | | ✓ | Case reports
(481) | Edwards AR. Vacuum device closes gap in wound care. Biomechanics 2001 Dec;8(12):27-34. | | | ✓ | Narrative
(226) | Eginton MT, Brown KR, Seabrook GR, Towne JB, Cambria RA. A prospective randomized evaluation of negative-pressure wound dressings for diabetic foot wounds. Ann Vasc Surg 2003 Nov;17(6):645-9. | | | ✓ | Fewer than five patients
(482) | Emohare O, Kowal-Vern A, Wiley D, Latenser BA. Vacuum-assisted closure use in calciphylaxis. J Burn Care Rehabil 2004 Mar–Apr;25(2):161-4. | | | ✓ | Fewer than five patients
(483) | Ennis WJ. (President, Association for the Advancement of Wound Care). Personal communication. 2009 Feb 5. 2 p. | | | ✓ | Personal communication
(484) | Erba P, Rieger UM, Pierer G, Kalbermatten DF. Vacuum-assisted closure (VAC) for venous congestion of the nipple-areola complex. J Plast Reconstr Aesthet Surg 2008 Jul;61(7):852-4. | | | ✓ | Case report
(485) | Erdmann D, Drye C, Heller L, Wong MS, Levin SL. Abdominal wall defect and enterocutaneous fistula treatment with the Vacuum-Assisted Closure (V.A.C.) system. Plast Reconstr Surg 2001 Dec;108(7):2066-8. | | | ✓ | Case report
(486) | Espensen EH, Nixon BP, Lavery LA, Armstrong DG. Use of subatmospheric (VAC) therapy to improve bioengineered tissue grafting in diabetic foot wounds. J Am Podiatr Med Assoc 2002 Jul–Aug;92(7):395-7. | | | ✓ | Narrative
(487) | Evans D, Land L. Topical negative pressure for treating chronic wounds: a systematic review. Br J Plast Surg 2001 Apr;54(3):238-42 | | | ✓ | (169) update
(488) | Ferdinando E, Guerin L, Jervis AO, Obidigbo H. Negative-pressure wound therapy and external fixation for infection and hematoma after hallux abducto valgus surgery. J Am Podiatr Med Assoc 2007 Sep–Oct;97(5):410-4. | | | ✓ | Case report
(489) | Ferreira MC, Wada A, Tuma Jr P. The vacuum assisted closure of complex wounds: report of 3 cases. Rev Hosp Clin Fac Med Sao Paulo 2003 Jul–Aug;58(4):227-30. | | | ✓ | Fewer than five patients
(83) | Ferron G, Garrido I, Martel P, Gesson-Paute A, Classe JM, Letourneur B, Querleu D. Combined laparoscopically harvested omental flap with meshed skin grafts and vacuum-assisted closure for reconstruction of complex chest wall defects. Ann Plast Surg 2007 Feb;58(2):150-5. | ✓ | KQ3 | | | ✓
(490) | Fette A. Treatment of pressure ulcers with topical negative pressure versus traditional wound management methods: a research sampler. Plast Surg Nurs 2005 Oct–Dec;25(4):176-80. | | | ✓ | Narrative
(491) | Fife CE, Otto G, Walker D, Turner T, Smith L. Healing dehisced surgical wounds with negative pressure wound therapy. Ostomy Wound Manage 2004 Apr;50(4A Suppl):28-31. | | | ✓ | Narrative
(492) | Fischer JE. A cautionary note: the use of vacuum-assisted closure systems in the treatment of gastrointestinal cutaneous fistula may be associated with higher mortality from subsequent fistula development. Am J Surg 2008 Jul;196(1):1-2. | | | ✓ | Narrative
(168) | Fisher A, Brady B. Vacuum assisted wound closure therapy. Issues Emerg Health Technol 2003 Mar;(44):1-6. | ✓ | Previous Systematic Reviews
(493) | Fitzmaurice M, Lawson D, Friedman H. A novel approach for the application of the vacuum assisted closure device to the difficult anatomy. J Plast Reconstr Aesthet Surg 2006;59(11):1249-50. | | | ✓ | Case report
(494) | Flack S, Apelqvist J, Keith M, Trueman P, Williams D. An economic evaluation of VAC therapy compared with wound dressings in the treatment of diabetic foot ulcers. J Wound Care 2008 Feb;17(2):71-8. | | | ✓ | Cost analysis
(495) | Fleck T, Gustafsson R, Harding K, Ingemansson R, Lirtzman MD, Meites HL, Moidl R, Price P, Ritchie A, Salazar J, Sjogren J, Song DH, Sumpio BE, Toursarkissian B, Waldenberger F, Wetzel-Roth W. The management of deep sternal wound infections using vacuum assisted closure (V.A.C.) therapy. Int Wound J 2006 Dec;3(4):273-80. | | | ✓ | Narrative
(362) | Fleck T, Kickinger B, Moidl R, Waldenberger F, Wolner E, Grabenwoger M, Wisser W. Management of open chest and delayed sternal closure with the vacuum assisted closure system: Preliminary experience. Interact Cardiovasc Thorac Surg 2008 Oct;7(5):801-4. | ✓ | KQ3
(496) | Fleck T, Moidl R, Giovanoli P, Aszmann O, Bartunek A, Blacky A, Grabenwoger M, Wolner E. A conclusion from the first 125 patients treated with the vacuum assisted closure system for postoperative sternal wound infection. Interact Cardiovasc Thorac Surg 2006 Apr;5(2):145-8. | | | ✓ | Not relevant - focus on management of infection
(497) | Fleck T, Simon P, Burda G, Wolner E, Wollenek G. Vacuum assisted closure therapy for the treatment of sternal wound infections in neonates and small infants. Interact Cardiovasc Thorac Surg 2006 Jun;5(3):285-8. | | | ✓ | Fewer than 5 patients
(380) | Fleck TM, Fleck M, Moidl R, Czerny M, Koller R, Giovanoli P, Hiesmayer MJ, Zimpfer D, Wolner E, Grabenwoger M. The vacuum-assisted closure system for the treatment of deep sternal wound infections after cardiac surgery. Ann Thorac Surg 2002 Nov 1;74(5):1596-1600. | ✓ | KQ3
(498) | Fleck TM, Koller R, Giovanoli P, Moidl R, Czerny M, Fleck M, Wolner E, Grabenwoger M. Primary or delayed closure for the treatment of poststernotomy wound infections. Ann Plast Surg 2004 Mar;52(3):310-4. | | | ✓ | Not relevant
(499) | Fleischmann W, Strecker W, Bombelli M, Kinzl L. [Vacuum sealing as treatment of soft tissue damage in open fractures]. Unfallchirurgie 1993;96(9):488-92. | | | ✓ | Narrative
(232) | Foo A, Kin-Sze Chong A, Shenthilkumar N. The ‘hand-in-gloves’ technique: vacuum-assisted closure dressing for multiple finger wounds. J Plast Reconstr Aesthet Surg 2008 Sep 5;Epub ahead of print. | | | ✓ | Case report
(110) | Ford CN, Reinhard ER, Yeh D, Syrek D, De Las Morenas A, Bergman SB, Williams S, Hamori CA. Interim analysis of a prospective, randomized trial of vacuum-assisted closure versus the Healthpoint system in the management of pressure ulcers. Ann Plast Surg 2002 Jul;49(1):55-61; discussion 61. | ✓ | KQ1,KQ3
(500) | Ford SJ, Rathinam S, King JE, Vaughan R. Tuberculous osteomyelitis of the sternum: successful management with debridement and vacuum assisted closure. Eur J Cardiothorac Surg 2005 Oct;28(4):645-7. | | | ✓ | Case report
(501) | Ford-Dunn S. Use of vacuum assisted closure therapy in the palliation of a malignant wound. Palliat Med 2006 Jun;20(4):477-8. | | | ✓ | Case report
(502) | Fox A, Tadros A, Perks AG. An unusual complication of Vacuum Assisted Closure in the treatment of a pressure ulcer. J Wound Care 2004 Sep;13(8):344-5. | | | ✓ | Case report
(503) | Fox MP, Fazal MA, Ware HE. Vacuum assisted wound closure. A new method for control of wound problems in total knee arthroplasty. J Bone Joint Surg Br 2000 Jan;82-B(Suppl 1):19. | | | ✓ | Fewer than 5 patients
(504) | Fredeking AE, Silverman RA. Successful treatment of trigeminal trophic syndrome in a 6-year-old boy with negative pressure wound therapy. Arch Dermatol 2008 Aug;144(8):984-6. | | | ✓ | Case report
(505) | Friedman T, Westreich M, Shalom A. Vacuum-assisted closure treatment complicated by anasarca. Ann Plast Surg 2005 Oct;55(4):420-1. | | | ✓ | Case report
(506) | Froiland KG. Nursing interventions in oncology complex wound care: use of negative pressure therapy for wound healing in an ovarian cancer patient. [internet]. [accessed 2001 Oct 23]. Available: http://www.thecancergroup.org/kathrynfroiland.htm. | | | ✓ | Case report
(507) | Frykberg F. When is NPWT appropriate for amputation wounds?. APMA News 2005 May;26(5 Suppl):20-3. | | | ✓ | Narrative
(508) | Frykberg RG, Williams DV. Negative-pressure wound therapy and diabetic foot amputations: a retrospective study of payer claims data. J Am Podiatr Med Assoc 2007 Sep-Oct;97(5):351-9. | | | ✓ | Cost analysis
(23) | Fuchs U, Zittermann A, Stuettgen B, Groening A, Minami K, Koerfer R. Clinical outcome of patients with deep sternal wound infection managed by vacuum-assisted closure compared to conventional therapy with open packing: a retrospective analysis. Ann Thorac Surg 2005 Feb;79(2):526-31. | ✓ | KQ1,KQ3
(509) | Gabriel A, Gollin G. Management of complicated gastroschisis with porcine small intestinal submucosa and negative pressure wound therapy. J Pediatr Surg 2006 Nov;41(11):1836-40. | | | ✓ | Animal study
(510) | Gabriel A, Heinrich C, Shores JT, Baqui WK, Rogers FR, Gupta S. Reducing bacterial bioburden in infected wounds with vacuum assisted closure and a new silver dressing - a pilot study. Wounds 2006 Sep;18(9):245-55. | | | ✓ | Duplicate study(383)
(339) | Gabriel A, Shores J, Heinrich C, Baqai W, Kalina S, Sogioka N, Gupta S. Negative pressure wound therapy with instillation: A pilot study describing a new method for treating infected wounds. Int Wound J 2008 Jun;5(3):399-413. | ✓ | KQ1, KQ3
(86) | Garner GB, Ware DN, Cocanour CS, Duke JH, McKinley BA, Kozar RA, Moore FA. Vacuum-assisted wound closure provides early fascial reapproximation in trauma patients with open abdomens. Am J Surg 2001 Dec;182(6):630-8. | ✓ | KQ3 | | | ✓
(154) | Gdalevitch P, Afilalo J, Lee C. Predictors of vacuum-assisted closure failure of sternotomy wounds. J Plast Reconstr Aesthet Surg 2008 Nov 21;Epub ahead of print. | ✓ | KQ3
(511) | Geller S. A closer look at NPWT in the wound care clinic setting. APMA News 2005 May;26(5 Suppl):43-5. | | | ✓ | Narrative
(512) | Geller S. How to use NPWT successfully in the home care setting. APMA News 2005 May;26(5 Suppl):33-4. | | | ✓ | Narrative
(513) | Geller SM, Longton JA. Ulceration of pyoderma gangrenosum treated with negative pressure wound therapy. J Am Podiatr Med Assoc 2005 Mar-Apr;95(2):171-4. | | | ✓ | Case report
(131) | Genecov DG, Schneider AM, Morykwas MJ, Parker D, White WL, Argenta LC. A controlled subatmospheric pressure dressing increases the rate of skin graft donor site reepithelialization. Ann Plast Surg 1998 Mar;40(3):219-25. | ✓ | KQ1, KQ3, Previous Systematic Reviews
(514) | Gerry R, Kwei S, Bayer L, Breuing KH. Silver-impregnated vacuum-assisted closure in the treatment of recalcitrant venous stasis ulcers. Ann Plast Surg 2007 Jul;59(1):58-62. | | | ✓ | Fewer than 5 patients
(515) | Ghersi MM, Ricotti C, Nousari CH, Newman MI. Negative pressure dressing in the management of pyoderma gangrenosum ulcer. Arch Dermatol 2007 Oct;143(10):1249-51. | | | ✓ | Case report
(516) | Gomoll AH, Lin A, Harris MB. Incisional vacuum-assisted closure therapy. J Orthop Trauma 2006 Nov-Dec;20(10):705-9. | | | ✓ | Narrative
(517) | Goverman J, Yelon JA, Platz JJ, Singson RC, Turcinovic M. The "Fistula VAC," a technique for management of enterocutaneous fistulae arising within the open abdomen: report of 5 cases. J Trauma 2006 Feb;60(2):428-31; discussion 431. | | | ✓ | Not relevant
(177) | Gray M, Peirce B. Is negative pressure wound therapy effective for the management of chronic wounds. J Wound Ostomy Continence Nurs 2004 May/June;31(3):101-5. | ✓ | Previous Systematic Reviews
(518) | Greene AK, Puder M, Roy R, Arsenault D, Kwei S, Moses MA, Orgill DP. Microdeformational wound therapy: effects on angiogenesis and matrix metalloproteinases in chronic wounds of 3 debilitated patients. Ann Plast Surg 2006 Apr;56(4):418-22. | | | ✓ | Fewer than 5 patients
(519) | Greer S, Sims CD, Borud L, Thorne C, Kasabian A. The use of a subatmospheric pressure dressing to salvage a septic ankle with concomitant osteomyelitis and avert a free flap. Foot Ankle Int 1997 Sep;18(3):151-6. | | | ✓ | Case report
(520) | Greer SE, Adelman M, Kasabian A, Galiano RD, Scott R, Longaker MT. The use of subatmospheric pressure dressing therapy to close lymphocutaneous fistulae of the groin. Br J Plast Surg 2000 Sep;53(6):484-7. | | | ✓ | Narrative
(521) | Greer SE, Duthie E, Cartolano B, Koehler KM, Maydick-Youngberg D, Longaker MT. Techniques for applying subatmospheric pressure dressing to wounds in difficult regions of anatomy. J Wound Ostomy Continence Nurs 1999 Sep;26(5):250-3. | | | ✓ | Narrative
(522) | Greer SE, Longaker MT, Margiotta M, Mathews AJ, Kasabian A. The use of subatmospheric pressure dressing for the coverage of radial forearm free flap donor-site exposed tendon complications. Ann Plast Surg 1999 Nov;43(5):551-4. | | | ✓ | Narrative
(173) | Gregor S, Maegele M, Sauerland S, Krahn JF, Peinemann F, Lange S. Negative pressure wound therapy: a vacuum of evidence?. Arch Surg 2008 Feb;143(2):189-96. | ✓ | Previous Systematic Reviews
(523) | Grimm A, Dimmler A, Stange S, Labanaris A, Sauer R, Grabenbauer G, Horch RE. Expression of HIF-1 alpha in irradiated tissue is altered by topical negative-pressure therapy. Strahlenther Onkol 2007 Mar;183(3):144-9. | | | ✓ | No relevant outcomes
(524) | Gudbjartsson T, Sigurdsson HK, Sigurdsson E, Kjartansson J. Vacuum-assisted closure for successful treatment of a major contaminated gunshot chest-wound: A case report. Eur J Trauma Emerg Surg 2008 July 25;Epub | | | ✓ | Case report
(525) | Gunn LA, Follmar KE, Wong MS, Lettieri SC, Levin LS, Erdmann D. Management of enterocutaneous fistulae using negative-pressure dressings. Ann Plast Surg 2006 Dec;57(6):621-5. | | | ✓ | Not relevant
(10) | Gupta S, Baharestani M, Baranoski S, de Leon J, Engel SJ, Mendez-Eastman S, Niezgoda JA, Pompeo MQ. Guidelines for managing pressure ulcers with negative pressure wound therapy. Adv Skin Wound Care 2004 Nov-Dec;17(Suppl 2):1-16. | | | ✓ | Guideline
(236) | Gupta S, Cho T. A literature review of negative pressure wound therapy. Ostomy Wound Manage 2004 Apr;50(4A Suppl):6-8. | | | ✓ | Duplicate study(188)
(526) | Gupta S, Gabriel A, Shores J. The perioperative use of negative pressure wound therapy in skin grafting. Ostomy Wound Manage 2004 Apr;50(4A Suppl):32-4. | | | ✓ | Narrative
(381) | Gustafsson R, Johnsson P, Algotsson L, Blomquist S, Ingemansson R. Vacuum-assisted closure therapy guided by C-reactive protein level in patients with deep sternal wound infection. J Thorac Cardiovasc Surg 2002 May;123(5):895-900. | ✓ | KQ3
(146) | Gustafsson RI, Sjogren J, Ingemansson R. Deep Sternal Wound Infection: A Sternal-Sparing Technique with Vacuum-Assisted Closure Therapy. Ann Thorac Surg 2003;76(6):2048-2053. | ✓ | KQ3
(527) | Guzzo J, Bluman EM. Technique tip: easing subatmospheric wound dressing application and increasing sponge conformity. Foot Ankle Int 2007 May;28(5):638-9. | | | ✓ | Narrative
(528) | Gwan-Nulla DN, Casal RS. Toxic shock syndrome associated with the use of the vacuum-assisted closure device. Ann Plast Surg 2001 Nov;47(5):552-4. | | | ✓ | Case report
(140) | Ha J, Phillips M. A retrospective review of the outcomes of vacuum-assisted closure therapy in a vascular surgery unit. Wounds 2008 Aug;20(8):221-9. | ✓ | KQ3
(529) | Hallock GG, Cipolle MD, Bradow BP. Enterocutaneous fistula associated with an unrecognized retained vacuum-assisted closure sponge. Plast Reconstr Surg 2008 Aug;122(2):84e-5e. | | | ✓ | Case report
(363) | Hamed O, Muck PE, Smith JM, Krallman K, Griffith NM. Use of vacuum-assisted closure (VAC) therapy in treating lymphatic complications after vascular procedures: new approach for lymphoceles. J Vasc Surg 2008 Dec;48(6):1520-3, 1523.e1‒4. | ✓ | KQ3
(530) | Hanasono MM, Skoracki RJ. Securing skin grafts to microvascular free flaps using the vacuum-assisted closure (VAC) device. Ann Plast Surg 2007 May;58(5):573-6. | | | ✓ | Narrative
(531) | Hardcastle MR. The application of negative pressure in wound healing. Prim Intent 1998 Feb;5-10 | | | ✓ | Narrative
(532) | Hardwicke J, Paterson P. A role for vacuum-assisted closure in lower limb trauma: a proposed algorithm. Int J Low Extrem Wounds 2006 Jun;5(2):101-4. | | | ✓ | Narrative
(533) | Harlan JW. Treatment of open sternal wounds with the vacuum-assisted closure system: a safe, reliable method. Plast Reconstr Surg 2002 Feb;109(2):710-2. | | | ✓ | Narrative
(534) | Hartnett JM. Use of vacuum-assisted wound closure in three chronic wounds. J Wound Ostomy Continence Nurs 1998 Nov;25(6):281-90. | | | ✓ | Fewer than five patients
(351) | Helgeson MD, Potter BK, Evans KN, Shawen SB. Bioartificial dermal substitute: A preliminary report on its use for the management of complex combat-related soft tissue wounds. J Orthop Trauma 2007 Jul;21(6):394-9. | ✓ | KQ3
(87) | Heller L, Levin SL, Butler CE. Management of abdominal wound dehiscence using vacuum assisted closure in patients with compromised healing. Am J Surg 2006 Feb;191(2):165-72. | ✓ | KQ3 | | | ✓
(360) | Herscovici Jr D, Sanders RW, Scaduto JM, Infante A, DiPasquale T. Vacuum-assisted wound closure (VAC therapy) for the management of patients with high-energy soft tissue injuries. J Orthop Trauma 2003;17(10):683-8. | ✓ | KQ3
(94) | Hersh RE, Jack JM, Dahman MI, Morgan RF, Drake DB. The vacuum-assisted closure device as a bridge to sternal wound closure. Ann Plast Surg 2001 Mar;46(3):250-4. | ✓ | KQ3 | | | ✓
(535) | Hersh RE, Kaza AK, Long SM, Fiser SM, Drake DB, Tribble CG. A technique for the treatment of sternal infections using the Vacuum Assisted Closure device. Heart Surg Forum 2001;4(3):211-5. | | | ✓ | Narrative
(536) | Heugel JR, Parks KS, Christie SS, Pulito JF, Zegzula DH, Kemalyan NA. Treatment of the exposed achilles tendon using negative pressure wound therapy: a case report. J Burn Care Rehabil 2002 May-Jun;23(3):167-71. | | | ✓ | Case report
(537) | Heuser M, Laabs SO, Plothe KD. Extraperitoneal bladder leakage after provision of topical negative therapy: a case report. J Wound Care 2005 Oct;14(9):406. | | | ✓ | Case report
(538) | Hopf HW, Ueno C, Aslam R, Burnand K, Fife C, Grant L, Holloway A, Iafrati MD, Mani R, Misare B, Rosen N, Shapshak D, Benjamin Slade J Jr, West J, Barbul A. Guidelines for the treatment of arterial insufficiency ulcers. Wound Repair Regen 2006 Nov-Dec;14(6):693‒710. | | | ✓ | Guideline
(78) | Horn PL, Ruth B, Kean JR. Use of wound V.A.C. therapy in pediatric patients with infected spinal wounds: a retrospective review. Orthop Nurs 2007 Sep-Oct;26(5):317‒22; quiz 323‒4. | ✓ | KQ3 | | | ✓
(127) | Huang WS, Hsieh SC, Hsieh CS, Schoung JY, Huang T. Use of vacuum-assisted wound closure to manage limb wounds in patients suffering from acute necrotizing fasciitis. Asian J Surg 2006 Jul;29(3):135-9. | ✓ | Previous Systematic Reviews
(539) | Huljev D, Kucisec-Tepes N. Necrotizing fascilitis of the abdominal wall as a post-surgical complication: a case report. Wounds 2005 Jul;17(7):169-77. | | | ✓ | Case report
(540) | Humburg J, Holzgreve W, Hoesli I. Negative pressure wound therapy in post-cesarian superficial wound disruption: a report of 3 cases. Wounds 2006 Jun;18(6):166-9. | | | ✓ | Fewer than five patients
(242) | Hunter JE, Teot L, Horch R, Banwell PE. Evidence-based medicine: Vacuum-assisted closure in wound care management. Int Wound J 2007 Sep;4(3):256-69. | | | ✓ | Narrative
(541) | Hunter S, Langemo D, Hanson D, Anderson J, Thompson P. The use of negative pressure wound therapy. Adv Skin Wound Care 2007 Feb;20(2):90‒5. | | | ✓ | Narrative
(542) | Hutchinson L, Thompson J. Vacuum-assisted closure: a method of facilitating wound healing. World Counc Enteros Ther J 1999 Jul-Sep;19(3):17‒21. | | | ✓ | Case reports
(130) | Immer FF, Durrer M, Muhlemann KS, Erni D, Gahl B, Carrel TP. Deep sternal wound infection after cardiac surgery: modality of treatment and outcome. Ann Thorac Surg 2005 Sep;80(3):957-61. | ✓ | KQ1, KQ3, Previous Systematic Reviews
(543) | Isago T, Nozaki M, Kikuchi Y, Honda T, Nakazawa H. Effects of different negative pressures on reduction of wounds in negative pressure dressings. J Dermatol 2003 Aug;30(8):596‒601. | | | ✓ | Animal study
(91) | Isago T, Nozaki M, Kikuchi Y, Honda T, Nakazawa H. Negative-pressure dressings in the treatment of pressure ulcers. J Dermatol 2003 Apr;30(4):299-305. | ✓ | KQ3 | | | ✓
(544) | Isago T, Nozaki M, Kikuchi Y, Honda T, Nakazawa H. Skin graft fixation with negative-pressure dressings. J Dermatol 2003 Sep;30(9):673-8. | | | ✓ | Narrative
(545) | Iusupov IuN, Epifanov MV. [Active drainage of a wound. Vestn Khir Im I I Grek 1987 Apr;138(4):42-6. | | | ✓ | Animal study
(546) | Jacobs S, Simhaee DA, Marsano A, Fomovsky GM, Niedt G, Wu JK. Efficacy and mechanisms of vacuum-assisted closure (VAC) therapy in promoting wound healing: a rodent model. J Plast Reconstr Aesthet Surg 2008 Jul 8;Epub ahead of print. | | | ✓ | Animal study
(547) | Jehle KS, Rohatgi A. Use of porcine dermal collagen graft and topical negative pressure on infected open abdominal wounds. J Wound Care 2007 Jan;16(1):36-7. | | | ✓ | Case report
(246) | Jeschke MG, Rose C, Angele P, Fuchtmeier B, Nerlich MN, Bolder U. Development of new reconstructive techniques: use of Integra in combination with fibrin glue and negative-pressure therapy for reconstruction of acute and chronic wounds. Plast Reconstr Surg 2004 Feb;113(2):525-30. | | | ✓ | Not relevant – dual therapy
(150) | Jones GA, Butler J, Lieberman I, Schlenk R. Negative-pressure wound therapy in the treatment of complex postoperative spinal wound infections: complications and lessons learned using vacuum-assisted closure. J Neurosurg Spine 2007 May;6(5):407-11. | ✓ | KQ3
(548) | Jones SM, Banwell PE, Shakespeare PG. Advances in wound healing: topical negative pressure therapy. Postgrad Med J 2005 Jun;81(956):353-7. | | | ✓ | Narrative
(247) | Jones SM, Banwell PE, Shakespeare PG. Interface dressings influence the delivery of topical negative-pressure therapy. Plast Reconstr Surg 2005 Sep 15;116(4):1023-8. | | | ✓ | Healthy volunteers
(113) | Joseph E, Hamori CA, Bergman S, Roaf E, Swann NF, Anastasi GW. A prospective, randomized trial of vacuum-assisted closure versus standard therapy of chronic non-healing wounds. Wounds 2000;12(3):60-7. Also available: http://www.medscape.com/viewarticle/407550_print. | ✓ | KQ1, KQ3
(549) | Josty IC, Ramaswamy R, Laing JH. Vaccum assisted closure: an alternative strategy in the management of degloving injuries of the foot. Br J Plast Surg 2001 Jun;54(4):363-5. | | | ✓ | Case report
(550) | Kadohama T, Akasaka N, Nagamine A, Nakanishi K, Kiyokawa K, Goh K, Sasajima T. Vacuum-assisted closure for pediatric post-sternotomy mediastinitis: are low negative pressures sufficient. Ann Thorac Surg 2008 Mar;85(3):1094-6. | | | ✓ | Case reports
(343) | Kamolz LP, Andel H, Haslik W, Winter W, Meissl G, Frey M. Use of subatmospheric pressure therapy to prevent burn wound progression in human: first experiences. Burns 2004 May;30(3):253-8. | ✓ | KQ1, KQ3
(25) | Kanakaris NK, Thanasas C, Keramaris N, Kontakis G, Granick MS, Giannoudis PV. The efficacy of negative pressure wound therapy in the management of lower extremity trauma: Review of clinical evidence. Injury 2007;38:S8-S10,S11-S17. | ✓ | Previous Systematic Reviews
(551) | Kang GC, Yam A. Vacuum-assisted closure of a large palmar defect after debriding a midpalmar tuberculous abscess. Int Wound J 2008 Mar;5(1):45-8. | | | ✓ | Case report
(552) | Kaplan M, Banwell P, Orgill DP, Ivatury RR, Demetriades D, Moore FA, Miller P, Nicholas J, Henry S. Guidelines for the management of the open abdomen. Wounds 2005 Oct;17(Suppl 1):S1-S24. | | | ✓ | Guideline
(553) | Kaplan M. Abdominal compartment syndrome. Ostomy Wound Manage 2004 Apr;50(4A Suppl):20-1. | | | ✓ | Case report
(554) | Kaplan M. Managing the open abdomen. Ostomy Wound Manage 2004 Jan;50(1A Suppl):C2, 1-8, quiz. | | | ✓ | Narrative
(555) | Kaplan M. Negative pressure wound therapy in the management of abdominal compartment syndrome. Ostomy Wound Manage 2004 Nov;50(11A Suppl):20S-25S. | | | ✓ | Case reports
(556) | Kaplan M. Negative pressure wound therapy in the management of abdominal compartment syndrome. Ostomy Wound Manage 2005 Feb;51(2A Suppl):29-35. | | | ✓ | Narrative
(557) | Kaufman MW, Pahl DW. Vacuum-assisted closure therapy: wound care and nursing implications. Dermatol Nurs 2003 Aug;15(4):317-20, 323-5; quiz 326. | | | ✓ | Narrative
(558) | Kendrick AS, Chase CW. Salvage of an infected breast tissue expander with an implant sizer and negative pressure wound management. Plast Reconstr Surg 2008 Mar;121(3):138e-139e. | | | ✓ | Case report
(559) | Kennedy A, Van Zant RS. Diverse applications of negative pressure wound therapy: a multiple case report. Physiother Theory Pract 2006 Apr;22(2):83-90. | | | ✓ | Case reports
(560) | Kilbride KE, Cooney DR, Custer MD. Vacuum-assisted closure: A new method for treating patients with giant omphalocele. J Pediatr Surg 2006 Jan;41(1):212-5. | | | ✓ | Fewer than five patients
(561) | Kilpadi D, Stechmiller J, Childress B, Cowan L, Comerio M, Kieswetter K, Schultz G. Composition of wound fluid from pressure ulcers treated with negative pressure wound therapy using VAC therapy in home health or extend care patients: a pilot study. Wounds 2006;18(5):119-26. | | | ✓ | No relevant outcomes
(562) | Kilpadi DV, Feeley TD, Kiel JW. V.A.C. Therapy normalizes vascular response of injured tissue in full-thickness wounds in rabbits. Ann Plast Surg 2007 May;58(5):555-60. | | | ✓ | Animal study
(251) | Kim EK, Hong JP. Efficacy of negative pressure therapy to enhance take of 1-stage allodermis and a split-thickness graft. Ann Plast Surg 2007 May;58(5):536-40. | | | ✓ | Homemade device
(563) | Kirby JP, Fantus RJ, Ward S, Sanchez O, Walker E, Mellett MM, Maltz SB, Lerner TT. Novel uses of a negative-pressure wound care system. J Trauma 2002 Jul;53(1):117-21. | | | ✓ | Narrative
(564) | Klayman MH, Trowbridge CC, Stammers AH, Wolfgang GL, Zijerdi DA, Bitterly TJ. Autologous platelet concentrate and vacuum-assisted closure device use in a nonhealing total knee replacement. J Extra Corpor Technol 2006 Mar;38(1):44-7. | | | ✓ | Case report
(565) | Kloth LC. 5 questions-and answers-about negative pressure wound therapy. Adv Skin Wound Care 2002 Sep-Oct;15(5):226-9. | | | ✓ | Narrative
(566) | Koehler C, Niederbichler AD, Jung FJ, Scholz T, Labler L, Perez D, Jandali A, Comber M, Kuenzi W, Wedler V. Wound therapy using the vacuum-assisted closure device: clinical experience with novel indications. J Trauma 2008 Sep;65(3):722-31; discussion 731. | | | ✓ | No abstract available
(567) | Kopp J, Kneser U, Bach AD, Horch RE. Buried chip skin grafting in neuropathic diabetic foot ulcers following vacuum-assisted wound bed preparation: enhancing a classic surgical tool with novel technologies. Int J Low Extrem Wounds 2004 Sep;3(3):168-71. | | | ✓ | Narrative
(568) | Kopp J, Strnad V, Bach AD, Sauer R, Horch RE. Vacuum application increases therapeutic safety and allows intensified local radiation treatment of malignant soft-tissue tumors. Strahlenther Onkol 2005 Feb;181(2):124-30. | | | ✓ | Fewer than five patients
(340) | Korber A, Franckson T, Grabbe S, Dissemond J. Vacuum assisted closure device improves the take of mesh grafts in chronic leg ulcer patients. Dermatology 2008;216(3):250-6. | ✓ | KQ1, KQ3
(569) | Kordasiewicz LM, Schultz RO. A paraplegic with stage IV pressure ulcers: risk factors and wound care. J Wound Ostomy Continence Nurs 2003 Mar;30(2):84-9. | | | ✓ | Case report
(570) | Kostiuchenok BM, Kolker II, Karlov VA, Ignatenko SN, Muzykant LI. Vacuum treatment in the surgical management of suppurative wounds. Vestn Khir Im I I Grek 1986 Sep;137(9):18-21. | | | ✓ | Not a NPWT device
(73) | Kotsis T, Lioupis C. Use of vacuum assisted closure in vascular graft infection confined to the groin. Acta Chir Belg 2007 Jan-Feb;107(1):37-44. | ✓ | KQ3 | | | ✓
(571) | Kovacs LH, Kloeppel M, Papadopulos NA, Reeker W, Biemer E. Necrotizing fasciitis. Ann Plast Surg 2001 Dec;47(6):680-2. | | | ✓ | Case report
(253) | Krasner DL. Managing wound pain in patients with vacuum-assisted closure devices. Ostomy Wound Manage 2002 May;48(5):38-43. | | | ✓ | Case report
(572) | Kumar S, O’Donnell ME, Khan K, Dunne G, Carey PD, Lee J. Successful treatment of perineal necrotising fasciitis and associated pubic bone osteomyelitis with the vacuum assisted closure system. World J Surg Oncol 2008;6:67. | | | ✓ | Case report
(364) | Labanaris AP, Polykandriotis E, Horch RE. The effect of vacuum-assisted closure on lymph vessels in chronic wounds. J Plast Reconstr Aesthet Surg 2008 Jun 2;Epub ahead of print. | ✓ | KQ3
(370) | Labler L, Keel M, Trentz O, Heinzelmann M. Wound conditioning by vacuum assisted closure (V.A.C.) in postoperative infections after dorsal spine surgery. Eur Spine J 2006 Sep;15(9):1388-96. | ✓ | KQ3
(71) | Labler L, Keel M, Trentz O. Vacuum-assisted closure (VAC) for temporary coverage of soft-tissue injury in type III open fracture of lower extremities. Eur J Trauma 2004;30(5):305-12. | ✓ | KQ1, KQ3 | | | ✓
(352) | Labler L, Trentz O. The use of vacuum assisted closure (VAC™) in soft tissue injuries after high energy pelvic trauma. Langenbecks Arch Surg 2007 Sep;392(5):601-9. | ✓ | KQ3
(357) | Labler L, Zwingmann J, Mayer D, Stocker R, Trentz O, Keel M. V.A.C. Abdominal Dressing System: A temporary closure for open abdomen. Eur J Trauma 2005 Oct;31(5):488-94. | ✓ | KQ3
(573) | Lam WL, Garrido A, Stanley PR. Use of topical negative pressure in the treatment of chronic osteomyelitis. A case report. J Bone Joint Surg Am 2005 Mar;87(3):622-4. | | | ✓ | Case report
(256) | Lambert KV, Hayes P, McCarthy M. Vacuum assisted closure: a review of development and current applications. Eur J Vasc Endovasc Surg 2005 Mar;29(3):219-26. | | | ✓ | Narrative
(574) | Langley-Hawthorne C. Economics of negative pressure wound therapy. Ostomy Wound Manage 2004 Apr;50(4A Suppl):35-7. | | | ✓ | Narrative
(575) | Laverty D, DeFranzo A. Negative pressure wound therapy in the management of orthopedic wounds. Ostomy Wound Manage 2004 Nov;50(11A Suppl):18S-19S. | | | ✓ | Narrative
(576) | Lavery L. Disease management programs: can they make a difference?. APMA News 2005 May;26(5-Suppl):27-29. | | | ✓ | Narrative
(577) | Lavery L. Treating heel pressure unlcers with NPWT. APMA News 2005 May;26(5-Suppl):13-15. | | | ✓ | Narrative
(257) | Lavery LA, Barnes SA, Keith MS, Seaman JW Jr, Armstrong DG. Prediction of healing for postoperative diabetic foot wounds based on early wound area progression. Diabetes Care 2008 Jan;31(1):26-9. | | | ✓ | Duplicate study(109)
(341) | Lavery LA, Boulton AJ, Niezgoda JA, Sheehan P. A comparison of diabetic foot ulcer outcomes using negative pressure wound therapy versus historical standard of care. Int Wound J 2007 Jun;4(2):103-13. | ✓ | KQ1, KQ3
(578) | Lee AT, Fanton GS, McAdams TR. Acute compartment syndrome of the thigh in a football athlete: a case report and the role of the vacuum-assisted wound closure dressing. J Orthop Trauma 2005 Nov-Dec;19(10):748-50. | | | ✓ | Case report
(374) | Lee SS, Lin SD, Chen HM, Lin TM, Yang CC, Lai CS, Chen YF, Chiu CC. Management of intractable sternal wound infections with topical negative pressure dressing. J Card Surg 2005 May-Jun;20(3):218-22. | ✓ | KQ3
(579) | Leijnen M, Steenvoorde P, van Doorn L, Zeillemaker AM, da Costa SA, Oskam J. Does VAC increase the risk of venous thromboembolism. J Wound Care 2007 May;16(5):211-2. | | | ✓ | No abstract available
(111) | Leininger BE, Rasmussen TE, Smith DL, Jenkins DH, Coppola C. Experience with wound VAC and delayed primary closure of contaminated soft tissue injuries in Iraq. J Trauma 2006 Nov;61(5):1207-11. | ✓ | KQ1, KQ3
(580) | Lemaire V, Brilmaker J, Kerzmann A, Jacquemin D. Treatment of a groin lymphatic fistula with negative pressure wound therapy. Eur J Vasc Endovasc Surg 2008 Oct;36(4):449-51. | | | ✓ | Case report
(581) | Lemmon JA, Ahmad J, Ghavami A, Bidic SM. Vacuum-assisted closure over an external fixation device. Plast Reconstr Surg 2008 Apr;121(4):234e-5e. | | | ✓ | Case report
(582) | Lentz S. Use of the vacuum-assisted closure system in management of the gynecologic surgical wound: a case report. J Pelvic Med Surg 2002 Jan;8(1):53-6. | | | ✓ | Case report
(583) | Levin LS. Principles of definitive soft tissue coverage with flaps. J Orthop Trauma 2008 Nov-Dec;22(10 Suppl):S161-6. | | | ✓ | Narrative
(584) | Liao EC, Breuing KH. Breast mound salvage using vacuum-assisted closure device as bridge to reconstruction with inferolateral AlloDerm hammock. Ann Plast Surg 2007 Aug;59(2):218-24. | | | ✓ | No abstract available
(585) | Lindstedt S, Malmsjo M, Gesslein B, Ingemansson R. Evaluation of continuous and intermittent myocardial topical negative pressure. J Cardiovasc Med (Hagerstown) 2008 Aug;9(8):813-9. | | | ✓ | Animal study
(586) | Lindstedt S, Malmsjo M, Gesslein B, Ingemansson R. Topical negative pressure effects on coronary blood flow in a sternal wound model. Int Wound J 2008 Oct;5(4):503-9. | | | ✓ | Animal study
(587) | Lindstedt S, Malmsjo M, Ingemansson R. Blood flow changes in normal and ischemic myocardium during topically applied negative pressure. Ann Thorac Surg 2007 Aug;84(2):568-73. | | | ✓ | Animal study
(588) | Lindstedt S, Malmsjo M, Ingemansson R. No hypoperfusion is produced in the epicardium during application of myocardial topical negative pressure in a porcine model. J Cardiothorac Surg 2007;2:53. | | | ✓ | Animal study
(589) | Lindstedt S, Malmsjo M, Sjogren J, Gustafsson R, Ingemansson R. Impact of different topical negative pressure levels on myocardial microvascular blood flow. Cardiovasc Revasc Med 2008 Jan-Mar;9(1):29-35. | | | ✓ | Animal study
(590) | Lindstedt S, Paulsson P, Mokhtari A, Gesslein B, Hlebowicz J, Malmsjo M, Ingemansson R. A compare between myocardial topical negative pressure levels of −25 mmHg and −50 mmHg in a porcine model. BMC Cardiovasc Disord 2008;8:14. | | | ✓ | Animal study
(591) | Literature review on Negative pressure wound therapy submission to AHRQ by the Association for the Advancement of Wound Care (AAWC) [unpublished]. 140 p. | | | ✓ | Table of Contents
(259) | Llanos S, Danilla S, Barraza C, Armijo E, Pineros JL, Quintas M, Searle S, Calderon W. Effectiveness of negative pressure closure in the integration of split thickness skin grafts: a randomized, double-masked, controlled trial. Ann Surg 2006 Nov;244(5):700-5. | | | √ | Homemade device
(592) | Loos B, Kopp J, Hohenberger W, Horch RE. Post-malignancy irradiation ulcers with exposed alloplastic materials can be salvaged with topical negative pressure therapy (TNP). Eur J Surg Oncol 2007 Sep;33(7):920-5. | | | ✓ | Fewer than five patients
(593) | Lopez Almodovar LF, Bustos G, Lima P, Canas A, Paredes I, Buendia JA. Transverse plate fixation of sternum: a new sternal-sparing technique. Ann Thorac Surg 2008 Sep;86(3):1016-7. | | | ✓ | Case reports
(365) | Lopez G, Clifton-Koeppel R, Emil S. Vacuum-assisted closure for complicated neonatal abdominal wounds. J Pediatr Surg 2008 Dec;43(12):2202-7. | ✓ | KQ3
(594) | Lynch JB, Laing AJ, Regan PJ. Vacuum-assisted closure therapy: a new treatment option for recurrent pilonidal sinus disease. Report of three cases. Dis Colon Rectum 2004 Jun;47(6):929-32. | | | ✓ | Case reports
(74) | Machen MS. Management of traumatic war wounds using vacuum-assisted closure dressings in an austere environment. Army Med Dept J 2007 Jan-Mar;17-23. | ✓ | KQ3 | | | ✓
(595) | Maguina P, Kalimuthu R. Posterior rectal hernia after vacuum-assisted closure treatment of sacral pressure ulcer. Plast Reconstr Surg 2008 Jul;122(1):46e-47e. | | | ✓ | Case report
(596) | Malli S. Keep a close eye on vacuum-assisted wound closure. Nursing 2005 Jul;35(7):25. | | | ✓ | Case report
(597) | Malmsjo M, Ingemansson R, Sjogren J. Mechanisms governing the effects of vacuum-assisted closure in cardiac surgery. Plast Reconstr Surg 2007 Oct;120(5):1266-75. | | | ✓ | Narrative
(598) | Mandal A, Addison P, Stewart K, Neligan P. Vacuum-assisted closure therapy on pyoderma gangrenosum. J Plast Surg 2006 Apr;28(8):529-31. | | | ✓ | Fewer than five patients
(599) | Mandal A. Role of topical negative pressure in pressure ulcer management. J Wound Care 2007 Jan;16(1):33-5. | | | ✓ | Narrative
(600) | Marathe US, Sniezek JC. Use of the vacuum-assisted closure device in enhancing closure of a massive skull defect. Laryngoscope 2004 Jun;114(6):961-4. | | | ✓ | Case report
(601) | Marsh DJ, Abu-Sitta G, Patel H. The role of vacuum-assisted wound closure in blast injury. Plast Reconstr Surg 2007 May;119(6):1978-9. | | | ✓ | No abstract available
(602) | Matzi V, Lindenmann J, Porubsky C, Neuboeck N, Maier A, Smolle-Juettner FM. Intrathoracic insertion of the VAC device in a case of pleural empyema 20 years after pneumonectomy. Ann Thorac Surg 2007 Nov;84(5):1762-4. | | | ✓ | Not relevant
(120) | McCallon SK, Knight CA, Valiulus JP, Cunningham MW, McCulloch JM, Farinas LP. Vacuum-assisted closure versus saline-moistened gauze in the healing of postoperative diabetic foot wounds. Ostomy Wound Manage 2000 Aug;46(8):28-32, 34. | ✓ | KQ1, KQ3
(142) | McCord SS, Naik-Mathuria BJ, Murphy KM, McLane KM, Gay AN, Bob Basu C, Downey CR, Hollier LH, Olutoye OO. Negative pressure therapy is effective to manage a variety of wounds in infants and children. Wound Repair Regen 2007 May-Jun;15(3):296-301. | ✓ | KQ3
(603) | McEwan W, Brown TL, Mills SM, Muller MJ. Suction dressings to secure a dermal substitute. Burns 2004 May;30(3):259-61. | | | ✓ | Narrative
(604) | McGuinness JG, Winter DC, O’Connell PR. Vacuum-assisted closure of a complex pilonidal sinus. Dis Colon Rectum 2003 Feb 1;46(2):274-6. | | | ✓ | Case report
(605) | McNulty A.K., Schmidt, M., Feeley, Teri, Villaneuva, P., Kieswetter, K. 2009. Effects of negative pressure wound therapy on cellular energetics in fibroblasts grown in a provisional wound (fibrin) matrix [In Press]. Wound Repair Regen | | | ✓ | In vitro
(606) | McNulty AK, Schmidt M, Feeley T, Kieswetter K. Effects of negative pressure wound therapy on fibroblast viability, chemotactic signaling, and proliferation in a provisional wound (fibrin) matrix. Wound Repair Regen 2007 Nov-Dec;15(6):838-46. | | | ✓ | In vitro
(607) | Meara JG, Guo L, Smith JD, Pribaz JJ, Breuing KH, Orgill DP. Vacuum-assisted closure in the treatment of degloving injuries. Ann Plast Surg 1999 Jun;42(6):589-94. | | | ✓ | Narrative
(376) | Mehbod AA, Ogilvie JW, Pinto MR, Schwender JD, Transfeldt EE, Wood KB, Le Huec JC, Dressel T. Postoperative deep wound infections in adults after spinal fusion: Management with vacuum-assisted wound closure. J Spinal Disord Tech 2005;18(1):14-7. | ✓ | KQ3
(608) | Mendez-Eastman S. Give stubborn wounds a helping hand. Nursing Made Incredibly Easy 2007 Sep;5(5):18-20. | | | ✓ | Narrative
(609) | Mendez-Eastman S. Guidelines for using negative pressure wound therapy. Adv Skin Wound Care 2001 Nov-Dec;14(6):314-22; quiz 324-5. | | | ✓ | Guideline
(610) | Mendez-Eastman S. Negative pressure wound therapy. Plast Surg Nurs 1998 Spring;18(1):27-9, 33-7. | | | ✓ | Narrative
(611) | Mendez-Eastman S. New treatment for an old problem: negative-pressure wound therapy. Nursing 2002 May;32(5):58-63; quiz 64. | | | ✓ | Narrative
(612) | Mendez-Eastman S. Use of hyperbaric oxygen and negative pressure therapy in the multidisciplinary care of a patient with nonhealing wounds. J Wound Ostomy Continence Nurs 1999 MAR;26(2):67-76. | | | ✓ | Case report
(375) | Mendonca DA, Cosker T, Makwana NK. Vacuum-assisted closure to aid wound healing in foot and ankle surgery. Foot Ankle Int 2005 Sep;26(9):761-6. | ✓ | KQ3
(143) | Mendonca DA, Drew PJ, Harding KG, Price PE. A pilot study on the effect of topical negative pressure on quality of life. J Wound Care 2007 Feb;16(2):49-53. | ✓ | KQ3
(187) | Mendonca DA, Papini R, Price PE. Negative-pressure wound therapy: a snapshot of the evidence. Int Wound J 2006 Dec;3(4):261-71. | ✓ | Previous Systematic Reviews
(613) | Meyer W, Schmiden, V. Bier’s hyperemic treatment in surgery, medicine and the specialties a manual of it’s practical application. 2nd ed. Philadelphia: W.B. Saunders Company; | | | ✓ | Duplicate(614)
(614) | Meyer W, Schmieden V. Biers hyperemic treatment. Philadelphia: W.B. Saunders Company; 78-153 p. | | | ✓ | Narrative
(281) | Miller PR, Thompson JT, Faler BJ, Meredith JW, Chang MC. Late fascial closure in lieu of ventral hernia: the next step in open abdomen management. J Trauma 2002 Nov;53(5):843-9. | ✓ | | ✓ | Study arms both received V.A.C.®
(281) | Miller PR, Thompson JT, Faler BJ, Meredith JW, Chang MC. Late fascial closure in lieu of ventral hernia: the next step in open abdomen management. J Trauma 2002 Nov;53(5):843-9. | | | ✓ | Case report
(615) | Miller Q, Bird E, Bird K, Meschter C, Moulton MJ. Effect of subatmospheric pressure on the acute healing wound. Curr Surg 2004 Mar-Apr;61(2):205-8. | | | ✓ | Animal study
(112) | Moisidis E, Heath T, Boorer C, Ho K, Deva AK. A prospective, blinded, randomized, controlled clinical trial of topical negative pressure use in skin grafting. Plast Reconstr Surg 2004 Sep 15;114(4):917-22. | ✓ | KQ1,KQ3
(366) | Mokhtari A, Sjogren J, Nilsson J, Gustafsson R, Malmsjo M, Ingemansson R. The cost of vacuum-assisted closure therapy in treatment of deep sternal wound infection. Scand Cardiovasc J 2008;42(1):85-9. | ✓ | KQ3
(388) | Molnar JA, DeFranzo AJ, Hadaegh A, Morykwas MJ, Shen P, Argenta LC. Acceleration of integra incorporation in complex tissue defects with subatmospheric pressure. Plast Reconstr Surg 2004 Apr 15;113(5):1339-46. | ✓ | KQ3
(616) | Molnar JA, DeFranzo AJ, Marks MW. Single-stage approach to skin grafting the exposed skull. Plast Reconstr Surg 2000 Jan;105(1):174-7. | | | ✓ | Fewer than five patients
(617) | Molnar JA, Simpson JL, Voignier DM, Morykwas MJ, Argenta LC. Management of an acute thermal injury with subatmospheric pressure. J Burns Wounds 2005;4:e5. | | | ✓ | Case report
(618) | Molnar JA. Applications of negative pressure wound therapy to thermal injury. Ostomy Wound Manage 2004 Apr;50(4A Suppl):17-9. | | | ✓ | Narrative
(619) | Montecamozzo G, Leopaldi E, Baratti C, Previde P, Ferla F, Pizzi M, Sposato J, Pariani D, Sartani A, Trabucchi E. Incarcerated massive incisional hernia: extensive necrosis of the colon in a very obese patient. Surgical treatment and vacuum-assisted closure therapy: a case report. Hernia 2008 Dec;12(6):641-3. | | | ✓ | Case report
(79) | Mooney JF 3rd, Argenta LC, Marks MW, Morykwas MJ, DeFranzo AJ. Treatment of soft tissue defects in pediatric patients using the V.A.C. system. Clin Orthop Relat Res 2000 Jul;(376):26-31. | ✓ | KQ3 | | | ✓
(620) | Moore K. VAC therapy: interactions in the healing process. Wounds UK 2005 May;1(1):86-90. | | | ✓ | Narrative
(621) | Moran SG, Windham ST, Cross JM, Melton SM, Rue LW 3rd. Vacuum-assisted complex wound closure with elastic vessel loop augmentation: a novel technique. J Wound Care 2003 Jun;12(6):212-3. | | | ✓ | Narrative
(622) | Moreno-Coutino G, Estrada-Chavez G, Dominguez-Cherit J. Hip ulcer secondary to foreign body reaction and vacuum-assisted closure therapy: report of a case. Int Wound J 2005 Mar;2(1):81-3. | | | ✓ | Case report
(623) | Morris GS, Brueilly KE, Hanzelka H. Negative pressure wound therapy achieved by vacuum-assisted closure: Evaluating the assumptions. Ostomy Wound Manage 2007 Jan;53(1):52-7. | | | ✓ | Narrative
(624) | Morton N. Use of topical negative pressure therapy in postoperative dehisced or infected wounds. J Wound Care 2004 Sep;13(8):346-8. | | | ✓ | Narrative
(33) | Morykwas MJ, Argenta LC, Shelton-Brown EI, McGuirt W. Vacuum-assisted closure: a new method for wound control and treatment: animal studies and basic foundation. Ann Plast Surg 1997 Jun;38(6):553-62. | | | ✓ | Animal study
(625) | Morykwas MJ, Argenta LC. Nonsurgical modalities to enhance healing and care of soft tissue wounds. J South Orthop Assoc 1997 Winter;6(4):279-88. | | | ✓ | Narrative
(626) | Morykwas MJ, David LR, Schneider AM, Whang C, Jennings DA, Canty C, Parker D, White WL, Argenta LC. Use of subatmospheric pressure to prevent progression of partial-thickness burns in a swine model. J Burn Care Rehabil 1999 Jan-Feb;20(1 Pt 1):15-21. | | | ✓ | Animal study
(36) | Morykwas MJ, Faler BJ, Pearce DJ, Argenta LC. Effects of varying levels of subatmospheric pressure on the rate of granulation tissue formation in experimental wounds in swine. Ann Plast Surg 2001 Nov;47(5):547-51. | | | ✓ | Animal study
(627) | Morykwas MJ, Howell H, Bleyer AJ, Molnar JA, Argenta LC. The effect of externally applied subatmospheric pressure on serum myoglobin levels after a prolonged crush/ischemia injury. J Trauma 2002 Sep;53(3):537-40. | | | ✓ | Animal study
(628) | Morykwas MJ, Kennedy A, Argenta JP, Argenta LC. Use of subatmospheric pressure to prevent doxorubicin extravasation ulcers in a swine model. J Surg Oncol 1999 SEP;72(1):14-7. | | | ✓ | Animal study
(629) | Morykwas MJ, Simpson J, Punger K, Argenta A, Kremers L, Argenta J. Vacuum-assisted closure: state of basic research and physiologic foundation. Plast Reconstr Surg 2006 Jun;117(7 Suppl):121S-126S. | | | ✓ | Narrative
(630) | Motta GJ, Corbett LQ. Impact of an antimicrobial gauze upon bacterial colonies in wounds that require packing. Ostomy Wound Manage 2004 Aug;50(8):48-62. | | | ✓ | Narrative
(136) | Moues CM, van den Bemd GJ, Heule F, Hovius SE. Comparing conventional gauze therapy to vacuum-assisted closure wound therapy: a prospective randomised trial. J Plast Reconstr Aesthet Surg 2007;60(6):672-81. | ✓ | KQ1, KQ3
(285) | Moues CM, van den Bemd GJ, Meerding WJ, Hovius SE. An economic evaluation of the use of TNP on full-thickness wounds. J Wound Care 2005 May;14(5):224-7. | | | ✓ | Duplicate study(38)
(631) | Moues CM, van Toorenenbergen AW, Heule F, Hop WC, Hovius SE. The role of topical negative pressure in wound repair: expression of biochemical markers in wound fluid during wound healing. Wound Repair Regen 2008 Jul-Aug;16(4):488-94. | | | ✓ | No relevant outcomes
(38) | Moues CM, Vos MC, van den Bemd GJ, Stijnen T, Hovius SE. Bacterial load in relation to vacuum-assisted closure wound therapy: a prospective randomized trial. Wound Repair Regen 2004 Jan-Feb;12(1):11-7. | | | ✓ | Duplicate study(136)
(389) | Mullner T, Mrkonjic L, Kwasny O, Vecsei V. The use of negative pressure to promote the healing of tissue defects: a clinical trial using the vacuum sealing technique. Br J Plast Surg 1997 Apr;50(3):194-9. | ✓ | KQ3
(632) | Nagell CF, Holte K. Treatment of anastomotic leakage after rectal resection with transrectal vacuum-assisted drainage (VAC). A method for rapid control of pelvic sepsis and healing. Int J Colorectal Dis 2006 Oct;21(7):657-60. | | | ✓ | Fewer than five patients in study arm
(633) | Neubauer G, Ujlaky R. The cost-effectiveness of topical negative pressure versus other wound-healing therapies. J Wound Care 2003 Nov;12(10):392-3. | | | ✓ | No abstract available available
(634) | Newton H, Benbow M, Hampton S, Beldon P, Butcher M, Baxter H. TNP therapy in the community: findings of a national survey. Wounds UK 2006 Dec;2(4):31-5. | | | ✓ | Narrative
(635) | Ng R, Sebastin SJ, Tihonovs A, Peng YP. Hand in glove--VAC dressing with active mobilisation. J Plast Reconstr Aesthet Surg 2006;59(9):1011-3. | | | ✓ | Narrative
(636) | Nienhuijs SW, Manupassa R, Strobbe LJ, Rosman C. Can topical negative pressure be used to control complex enterocutaneous fistulae. J Wound Care 2003 Oct;12(9):343-5. | | | ✓ | Not relevant
(637) | Niezgoda JA, Mendez-Eastman S. The effective management of pressure ulcers. Adv Skin Wound Care 2006 Jan-Feb;19 Suppl 1:3-15. | | | ✓ | Narrative
(638) | Niezgoda JA. Combining negative pressure wound therapy with other wound management modalities. Ostomy Wound Manage 2005 Feb;51(2A Suppl):36-8. | | | ✓ | Narrative
(639) | Niezgoda JA. Incorporating negative pressure therapy into the management strategy for pressure ulcers. Ostomy Wound Manage 2004 Nov;50(11A Suppl):26-9. | | | ✓ | Case reports
(640) | Niezgoda JA. The economic value of negative pressure wound therapy. Ostomy Wound Manage 2005 Feb;51(2A Suppl):44-7. | | | ✓ | Narrative
(641) | No Authors. Position Document: Topical negative pressure in wound management. European Wound Management 2007 May;1-17. | | | ✓ | Narrative
(642) | No Authors. Topical negative pressure for chronic wounds? Drugs and Therapeutics Bulletin 2007 Aug;45(8):57-61. | | | ✓ | Narrative
(643) | No Authors. V.A.C. Therapy: Proceedings of the 2nd World Union of Wound Healing Societies Meeting (8-13 July 2004, Paris France). Wounds 2004 Dec;16(12-Suppl A):1-19. | | | ✓ | Narrative
(70) | Noble-Bell G, Forbes A. A systematic review of the effectiveness of negative pressure wound therapy in the management of diabetes foot ulcers. Int Wound J 2008 Jun;5(2):233-42. | ✓ | Previous Systematic Reviews | | | ✓
(644) | Norbury K, Kieswetter K. Vacuum-assisted closure therapy attenuates the inflammatory response in a porcine acute wound healing model. Wounds 2007 Apr;19(4):97-106. | | | ✓ | Animal study
(645) | Norton SE, De Souza B, Marsh D, Moir G. Vacuum-assisted closure (VAC Therapy) and the risk of fluid loss in acute trauma. Ann Plast Surg 2006 Feb;56(2):194-5. | | | ✓ | Case report
(646) | NPWT Info and history of NPWT. St. Petersburg (FL): Smith & Nephew, Inc.; 2009 Feb. 13 p. | | | ✓ | Background information
(647) | Nugent N, Lannon D, O’Donnell M. Vacuum-assisted closure – a management option for the burns patient with exposed bone. Burns 2005 May;31(3):390-3. | | | ✓ | Case reports
(648) | Obdeijn MC, de Lange MY, Lichtendahl DH, de Boer WJ. Vacuum-assisted closure in the treatment of poststernotomy mediastinitis. Ann Thorac Surg 1999 Dec;68(6):2358-60. | | | ✓ | Fewer than five patients
(377) | O’Connor J, Kells A, Henry S, Scalea T. Vacuum-assisted closure for the treatment of complex chest wounds. Ann Thorac Surg 2005 Apr;79(4):1196-200. | ✓ | KQ3
(649) | Oczenski W, Waldenberger F, Nehrer G, Kneifel W, Swoboda H, Schwarz S, Fitzgerald RD. Vacuum-assisted closure for the treatment of cervical and mediastinal necrotizing fasciitis. J Cardiothorac Vasc Anesth 2004 Jun;18(3):336-8. | | | ✓ | Narrative
(10) | Orgill DP, Austen WG Jr, Butler CE, Fine NA, Horvath KA, Mihaljevic T, Song DH, Wolfe WG. Guidelines for the treatment of complex chest wounds with negative pressure wound therapy. Wounds 2004 Dec;(Suppl B):1-23. | | | ✓ | Guideline
(20) | Orgill DP. Advancing the treatment options of chest wounds with negative pressure wound therapy. Ostomy Wound Manage 2005 Feb;51(2A Suppl):39-43. | | | ✓ | Narrative
(650) | Orgill DP. Utilizing negative pressure wound therapy on open chest/sternotomy wounds. Ostomy Wound Manage 2004 Nov;50(11A Suppl):15S-17S. | | | ✓ | Case report
(651) | O’Rourke ME. Vacuum-assisted closure therapy. Clin J Oncol Nurs 2006 Dec;10(6):825-6. | | | ✓ | No abstract available
(652) | Ovington LG. 1,2,3 s-t-r-e-t-c-h; vacuum-enhances wound closure. Adv Wound Care 1999 Jan;(Suppl):125-7. | | | ✓ | Narrative
(653) | Ozer K, Smith W. A simple technique for applying vacuum-assisted closure therapy over the circular type external fixation device. Ann Plast Surg 2006 Jun;56(6):693-4. | | | ✓ | Case report
(1) | Page JC, Newswander B, Schwenke DC, Hansen M, Ferguson J. Retrospective analysis of negative pressure wound therapy in open foot wounds with significant soft tissue defects. Adv Skin Wound Care 2004 Sep;17(7):354-64. | ✓ | KQ1,KQ3
(654) | Page JC. Utilizing NPWT for large soft tissue defects. APMA News 2005 May;26(5 Suppl):30-2. | | | ✓ | Narrative
(655) | Pape HC, Webb LX. History of open wound and fracture treatment. J Orthop Trauma 2008 Nov-Dec;22(10 Suppl):S133-4. | | | ✓ | Narrative
(296) | Parrett BM, Matros E, Pribaz JJ, Orgill DP. Lower extremity trauma: Trends in the management of soft-tissue reconstruction of open tibia-fibula fractures. Plast Reconstr Surg 2006 Apr 1;117(4):1315-22. | | | ✓ | Narrative
(656) | Patane F, Zingarelli E, Sansone F, Cappuccio G, Rinaldi M. Vacuum-assisted sternal closure after a ‘depression induced ischemic test’ in severe mediastinitis. J Cardiovasc Med (Hagerstown) 2008 Jun;9(6):622-4. | | | ✓ | Case report
(657) | Patel CT, Kinsey GC, Koperski-Moen KJ, Bungum LD. Vacuum-assisted wound closure. Am J Nurs 2000 Dec;100(12):45-8. | | | ✓ | Case report
(658) | Pattison PS, Gordon JK, Muto PM, Mallen JK, Hoerner J. Case report: using dual therapies-negative pressure wound therapy and modified silicone gel liner-to treat a limb postamputation and dehiscence. Wounds 2005 Aug;17(8):233-40. | | | ✓ | Case report
(41) | Paul JC. Vacuum assisted closure therapy: a must in plastic surgery. Plast Surg Nurs 2005 April/June;25(2):61-65. | | | ✓ | Case report
(298) | Peinemann F, McGauran N, Sauerland S, Lange S. Disagreement in primary study selection between systematic reviews on negative pressure wound therapy. BMC Med Res Methodol 2008;8:41. | | | ✓ | Methodology paper
(189) | Peinemann F, McGauran N, Sauerland S, Lange S. Negative pressure wound therapy: Potential publication bias caused by lack of access to unpublished study results data. BMC Med Res Methodol 2008;(8):Article Number: 4. | ✓ | Previous Systematic Reviews
(371) | Pelham FR, Kubiak EN, Sathappan SS, Di Cesare PE. Topical negative pressure in the treatment of infected wounds with exposed orthopaedic implants. J Wound Care 2006 Mar;15(3):111-6. | ✓ | KQ3
(659) | Penn E, Rayment S. Management of a dehisced abdominal wound with VAC therapy. Br J Nurs 2004 Feb 26-Mar 10;13(4):194-201. | | | ✓ | Case report
(95) | Perez D, Wildi S, Demartines N, Bramkamp M, Koehler C, Clavien PA. Prospective evaluation of vacuum-assisted closure in abdominal compartment syndrome and severe abdominal sepsis. J Am Coll Surg 2007 Oct;205(4):586-92. | ✓ | KQ3 | | | ✓
(660) | Petersson U, Acosta S, Bjorck M. Vacuum-assisted wound closure and mesh-mediated fascial traction--a novel technique for late closure of the open abdomen. World J Surg 2007 Nov;31(11):2133-7. | | | ✓ | Not relevant
(661) | Petrie N, Potter M, Banwell P. The management of lower extremity wounds using topical negative pressure. Int J Low Extrem Wounds 2003 Dec;2(4):198-206. | | | ✓ | Narrative
(662) | Petzina R, Ugander M, Gustafsson L, Engblom H, Hetzer R, Arheden H, Ingemansson R, Malmsjo M. Topical negative pressure therapy of a sternotomy wound increases sternal fluid content but does not affect internal thoracic artery blood flow: assessment using magnetic resonance imaging. J Thorac Cardiovasc Surg 2008 May;135(5):1007-13. | | | ✓ | Animal study
(663) | Petzina R, Ugander M, Gustafsson L, Engblom H, Sjogren J, Hetzer R, Ingemansson R, Arheden H, Malmsjo M. Hemodynamic effects of vacuum-assisted closure therapy in cardiac surgery: assessment using magnetic resonance imaging. J Thorac Cardiovasc Surg 2007 May;133(5):1154-62. | | | ✓ | Animal study
(176) | Pham CT, Middleton PF, Maddern GJ. The safety and efficacy of topical negative pressure in non-healing wounds: a systematic review. J Wound Care 2006 Jun;15(6):240-50. | ✓ | Previous Systematic Reviews
(664) | Phelps JR, Fagan R, Pirela-Cruz MA. A case study of negative pressure wound therapy to manage acute necrotizing fasciitis. Ostomy Wound Manage 2006 Mar;52(3):54-9. | | | ✓ | Case report
(665) | Philbeck TE Jr, Whittington KT, Millsap MH, Briones RB, Wight DG, Schroeder WJ. The clinical and cost effectiveness of with dual therapies externally applied negative pressure wound therapy in the treatment of wounds in home healthcare Medicare patients. Ostomy Wound Manage 1999 Nov;45(11):41-50. | | | ✓ | Patients treated
(666) | Philbeck TE, Schroeder WJ, Whittington KT. Vacuum-assisted closure therapy for diabetic foot ulcers: clinical and cost analyses. Home Health Care Consult 2001 Mar;8(3):27-34. | | | ✓ | Narrative
(667) | Pirela-Cruz MA, Machen MS, Esquivel D. Management of large soft-tissue wounds with negative pressure therapy-lessons learned from the war zone. J Hand Ther 2008 Apr-Jun;21(2):196-202; quiz 203. | | | ✓ | Narrative
(668) | Plikaitis CM, Molnar JA. Subatmospheric pressure wound therapy and the vacuum-assisted closure device: basic science and current clinical successes. Expert Rev Med Devices 2006 Mar;3(2):175-84. | | | ✓ | Narrative
(80) | Ploumis A, Mehbod AA, Dressel TD, Dykes DC, Transfeldt EE, Lonstein JE. Therapy of spinal wound infections using vacuum-assisted wound closure: risk factors leading to resistance to treatment. J Spinal Disord Tech 2008 Jul;21(5):320-3. | ✓ | KQ3 | | | ✓
(669) | Pollak AN. Use of negative pressure wound therapy with reticulated open cell foam for lower extremity trauma. J Orthop Trauma 2008 Nov-Dec;22(10 Suppl):S142-5. | | | ✓ | Narrative
(670) | Poulakidas S, Cologne K, Kowal-Vern A. Treatment of frostbite with subatmospheric pressure therapy. J Burn Care Res 2008 Nov-Dec;29(6):1012-4. | | | ✓ | Case report
(671) | Poulakidas S, Kowal-Vern A. Facilitating residual wound closure after partial graft loss with vacuum assisted closure therapy. J Burn Care Res 2008 Jul-Aug;29(4):663-5. | | | ✓ | Case report
(672) | Powell ET 4th. The role of negative pressure wound therapy with reticulated open cell foam in the treatment of war wounds. J Orthop Trauma 2008 Nov-Dec;22(10 Suppl):S138-41. | | | ✓ | Narrative
(673) | Principles of best practice: vacuum assisted closure: recommendations for use. A consensus document. [internet]. The Medical Education Partnership (MEP); 2008 Jun [10]. Available: http://www.mepltd.co.uk/oneoffsdetail.html?p=vaccon. | | | ✓ | Guideline
(301) | Pu LL. An alternative approach for soft-tissue coverage of a complex wound in the foot and ankle with vacuum-assisted closure over artificial dermis and subsequent skin graft. J Plast Reconstr Aesthet Surg 2008 Nov 20;Epub ahead of print. | | | ✓ | Narrative
(674) | Quah HM, Maw A, Young T, Hay DJ. Vacuum-assisted closure in the management of the open abdomen: a report of a case and initial experiences. J Tissue Viability 2004 Apr;14(2):59-62. | | | ✓ | Case report
(186) | Raja SG, Berg GA. Should vacuum-assisted closure therapy be routinely used for management of deep sternal wound infection after cardiac surgery. Interact Cardiovasc Thorac Surg 2007 Aug;6(4):523-7. | ✓ | Previous Systematic Reviews
(675) | Ramnarine IR, McLean A, Pollock JC. Vacuum-assisted closure in the paediatric patient with post-cardiotomy mediastinitis. Eur J Cardiothorac Surg 2002 Dec;22(6):1029-31. | | | ✓ | Case report
(163) | Rao M, Burke D, Finan PJ, Sagar PM. The use of vacuum-assisted closure of abdominal wounds: a word of caution. Colorectal Dis 2007 Mar;9(3):266-8. | ✓ | KQ3
(676) | Rapp SM. Negative pressure wound therapy reduces infections in lower extremity fractures. Orthop Today 2008 Feb;28(54) Also available: http://www.orthosupersite.com/print.asp?rID=26142. Accessed on Feb 7, 2008. | | | ✓ | Narrative
(677) | Reed SF, Novosel TJ, Weireter LJ, Collins JN, Britt RC, Alvey C, Merkh K, Britt LD. A novel technique for vacuum assisted closure on injured tissue or in confined spaces. J Trauma 2008 May;64(5):1406-7. | | | ✓ | Narrative
(678) | Reed T, Economon D, Wiersema-Bryant L. Colocutaneous fistula management in a dehisced wound: a case study. Ostomy Wound Manage 2006 Apr;52(4):60-4, 66. | | | ✓ | Case report
(679) | Reid DJ, Linneman P, Lentz CW. Negative pressure dressing to secure skin grafts. Surg Phys Assist 2001 Feb;9-13. | | | ✓ | Case report
(680) | Reisler T. A simple method of securing an interface dressing and vacuum-assisted closure foam pad to difficult wounds. Ann Plast Surg 2007 Aug;59(2):230-1. | | | ✓ | Narrative
(681) | Reitsma AM, Rhodeheaver GT. Effectiveness of a new antimicrobial gauze dressing as a bacterial barrier. [internet]. Charlottesville (VA): University of Virginia Health System; 2001 Sep 1 Available: http://www.kendallhq.com/imageServer.aspx?contentID=7598&contenttype=application/pdf. | | | ✓ | Narrative
(682) | Renner R, Rogalski C, Friedlein H, Simon JC. [Vacuum therapy in dermatology: a review. J Dtsch Dermatol Ges 2006 Jun;4(6):468-76. | | | ✓ | Narrative
(683) | Repta R, Ford R, Hoberman L, Rechner B. The use of negative-pressure therapy and skin grafting in the treatment of soft-tissue defects over the Achilles tendon. Ann Plast Surg 2005 Oct;55(4):367-70. | | | ✓ | Fewer than five patients
(684) | Rhee P, Velmahos GC. Traumatic wounds. Ostomy Wound Manage 2004 Apr;50(4A Suppl):22-5. | | | ✓ | Case report
(121) | Rinker B, Amspacher JC, Wilson PC, Vasconez HC. Subatmospheric pressure dressing as a bridge to free tissue transfer in the treatment of open tibia fractures. Plast Reconstr Surg 2008 May;121(5):1664-73. | ✓ | KQ1, KQ3
(685) | Robson MC, Cooper DM, Aslam R, Gould LJ, Harding KG, Margolis DJ, Ochs DE, Serena TE, Snyder RJ, Steed DL, Thomas DR, Wiersma-Bryant L. Guidelines for the treatment of venous ulcers. Wound Repair Regen 2006 Nov-Dec;14(6):649-62. | | | ✓ | Guideline
(89) | Rosenthal EL, Blackwell KE, McGrew B, Carroll WR, Peters GE. Use of negative pressure dressings in head and neck reconstruction. Head Neck 2005 Nov;27(11):970-5. | ✓ | KQ3 | | | ✓
(686) | Rosser CJ, Morykwas MJ, Argenta LC, Bare RL. A new technique to manage perineal wounds. Infect Urol 2000 Mar/Apr;13(2):45-7. | | | ✓ | Case report
(378) | Routledge T, Saeb-Parsy K, Murphy F, Ritchie AJ. The use of vacuum-assisted closure in the treatment of post-transplant wound infections: A case series. J Heart Lung Transplant 2005;24(9):1444.e15-6. | ✓ | KQ3
(687) | Saad SA, Shakov E, Sebastian V, Saad A. The use of wound vacuum-assisted closure (VAC) system in the treatment of recurrent or complex pilonidal cystDisease: experience in 4 adolescent patients. Internet J Surg 2007 Jan;11(1) | | | ✓ | Fewer than five patients
(688) | Sadat U, Chang G, Noorani A, Walsh SR, Hayes PD, Varty K. Efficacy of TNP on lower limb wounds: a meta-analysis. J Wound Care 2008 Jan;17(1):45-8. | | | ✓ | Narrative
(689) | Saeed MU, Kennedy DJ. A retained sponge is a complication of vacuum-assisted closure therapy. Int J Low Extrem Wounds 2007 Sep;6(3):153-4. | | | ✓ | Case report
(690) | Saiki Y, Hata M, Akasaka J, Saito T, Tabayashi K. Vacuum-assisted closure system for the treatment of mediastinitis after total aortic arch replacement. Jpn J Thorac Cardiovasc Surg 2005 Dec;53(12):638-40. | | | ✓ | Case report
(691) | Salazard B, Niddam J, Ghez O, Metras D, Magalon G. Vacuum-assisted closure in the treatment of poststernotomy mediastinitis in the paediatric patient. J Plast Reconstr Aesthet Surg 2008;61(3):302-5. | | | ✓ | Fewer than five patients
(151) | Sartipy U, Lockowandt U, Gabel J, Jideus L, Dellgren G. Cardiac Rupture During Vacuum-Assisted Closure Therapy. Ann Thorac Surg 2006 Sep;82(3):1110-1. | ✓ | KQ3
(34) | Saxena V, Hwang CW, Huang S, Eichbaum Q, Ingber D, Orgill DP. Vacuum-assisted closure: microdeformations of wounds and cell proliferation. Plast Reconstr Surg 2004 Oct;114(5):1086-96; discussion 1097-. | | | ✓ | Not a clinical study
(692) | Saxena V, Orgill D, Kohane I. A set of genes previously implicated in the hypoxia response might be an important modulator in the rat ear tissue response to mechanical stretch. BMC Genomics 2007;8:430. | | | ✓ | Animal study
(693) | Schaffzin DM, Douglas JM, Stahl TJ, Smith LE. Vacuum-assisted closure of complex perineal wounds. Dis Colon Rectum 2004 Oct;47(10):1745-8. | | | ✓ | Case reports
(132) | Scherer LA, Shiver S, Chang M, Meredith JW, Owings JT, Tominaga GT, Schecter WP, Parks SN, Peck J, Mayberry J. The vacuum assisted closure device: a method of securing skin grafts and improving graft survival. Arch Surg 2002;137(8):930-4. | ✓ | KQ1, KQ3
(35) | Scherer SS, Pietramaggiori G, Mathews JC, Prsa MJ, Huang S, Orgill DP. The mechanism of action of the vacuum-assisted closure device. Plast Reconstr Surg 2008 Sep;122(3):786-97. | | | ✓ | Animal study
(694) | Scheufler O, Peek A, Kania NM, Exner K. Problem-adapted application of vacuum occlusion dressings: case report and clinical experience. Eur J Plastic Surg 2000 Oct;23(7):386-90. | | | ✓ | Case report
(307) | Schimmer C, Sommer SP, Bensch M, Leyh R. Primary treatment of deep sternal wound infection after cardiac surgery: a survey of German heart surgery centers. Interact Cardiovasc Thorac Surg 2007 Dec;6(6):708-11. | | | ✓ | Does not address key question
(147) | Schimp VL, Worley C, Brunello S, Levenback CC, Wolf JK, Sun CC, Bodurka DC, Ramirez PT. Vacuum-assisted closure in the treatment of gynecologic oncology wound failures. Gynecol Oncol 2004 Feb;92(2):586-91. | ✓ | KQ3
(695) | Schintler M, Maier A, Matzi V, Smolle-Juttner FM. Vacuum assisted closure system in the management of cervical anastomotic leakage after gastric pull-up. Interact Cardiovasc Thorac Surg 2004 Mar;3(1):92-4. | | | ✓ | Case report
(696) | Schintler M, Marschitz I, Trop M. The use of topical negative pressure in a paediatric patient with extensive burns. Burns 2005 Dec;31(8):1050-3. | | | ✓ | Case report
(697) | Schipper J, Ridder GJ, Maier W, Teszler CB, Horch RE. Laryngotracheal reconstruction using prefabricated and preconditioned composite radial forearm free flaps. A report of two cases. Auris Nasus Larynx 2007 Jun;34(2):253-8. | | | ✓ | Not relevant
(308) | Schlatterer D, Hirshorn K. Negative pressure wound therapy with reticulated open cell foam-adjunctive treatment in the management of traumatic wounds of the leg: a review of the literature. J Orthop Trauma 2008 Nov-Dec;22(10 Suppl):S152-60. | | | ✓ | Narrative
(698) | Schlatterer D, Webb LX. Orthopedic indications for negative pressure wound therapy. Ostomy Wound Manage 2005 Feb;51(2A Suppl):27-8. | | | ✓ | Case report
(699) | Schneider AM, Morykwas MJ, Argenta LC. A new and reliable method of securing skin grafts to the difficult recipient bed. Plast Reconstr Surg 1998 Sep;102(4):1195-8. | | | ✓ | No abstract available
(700) | Schoemann MB, Lentz CW. Treating surgical wound dehiscence with negative pressure dressings. Ostomy Wound Manage 2005 Feb;51(2A Suppl):15-20. | | | ✓ | Narrative
(81) | Scholl L, Chang E, Reitz B, Chang J. Sternal osteomyelitis: use of vacuum-assisted closure device as an adjunct to definitive closure with sternectomy and muscle flap reconstruction. J Card Surg 2004 Sep-Oct;19(5):453-61. | ✓ | KQ3 | | | ✓
(701) | Schuster R, Moradzadeh A, Waxman K. The use of vacuum-assisted closure therapy for the treatment of a large infected facial wound. Am Surg 2006 Feb;72(2):129-31. | | | ✓ | Case report
(126) | Schwien T, Gilbert J, Lang C. Pressure ulcer prevalence and the role of negative pressure wound therapy in home health quality outcomes. Ostomy Wound Manag 2005;51:47-60. | ✓ | KQ1, KQ3
(311) | Segers P, de Jong AP, Kloek JJ, Spanjaard L, de Mol BA. Risk control of surgical site infection after cardiothoracic surgery. J Hosp Infect 2006 Apr;62(4):437-45. | | | ✓ | Case report
(310) | Segers P, de Jong AP, Kloek JJ, van der Horst CM, Spanjaard L, de Mol BA. Topical negative pressure therapy in wounds after cardiothoracic surgery: successful experience supported by literature. Thorac Cardiovasc Surg 2006 Aug;54(5):289-94. | | | ✓ | Not a clinical study
(354) | Segers P, Kloek JJ, Strackee DS, de Mol BA. Open window thoracostomy: a new therapeutic option using topical negative presure wound therapy. Wounds 2007 Oct;19(10):264-9. | ✓ | KQ3
(702) | Senchenkov A, Knoetgen J, Chrouser KL, Nehra A. Application of vacuum-assisted closure dressing in penile skin graft reconstruction. Urology 2006 Feb;67(2):416-9. | | | ✓ | Narrative
(355) | Senchenkov A, Petty PM, Knoetgen J 3rd, Moran SL, Johnson CH, Clay RP. Outcomes of skin graft reconstructions with the use of Vacuum Assisted Closure (VAC) dressing for irradiated extremity sarcoma defects. World J Surg Oncol 2007;5:138. | ✓ | KQ3
(703) | Sentenac J. Facilitating wound healing with VAC therapy: a pharmacist’s role. European Journal of Hospital Pharmacists 2008 May;14(5):57-8. | | | ✓ | Narrative
(138) | Shilt JS, Yoder JS, Manuck TA, Jacks L, Rushing J, Smith BP. Role of vacuum-assisted closure in the treatment of pediatric lawnmower injuries. J Pediatr Orthop 2004;24(5):482-487. | ✓ | KQ1, KQ3
(704) | Shirakawa M, Isseroff RR. Topical negative pressure devices: Use for enhancement of healing chronic wounds. Arch Dermatol 2005 Nov;141(11):1449-53. | | | ✓ | Narrative
(705) | Short B, Claxton M, Armstrong DG. How to use VAC therapy on chronic wounds. Podiatry Today 2002 Jul;15(7):48-54. | | | ✓ | Narrative
(367) | Shrestha BM, Nathan VC, Delbridge MC, Parker K, Throssell D, McKane WS, Karim MS, Raftery AT. Vacuum-assisted closure (VAC) therapy in the management of wound infection following renal transplantation. Kathmandu Univ Med J (KUMJ) 2007 Jan-Mar;5(1):4-7. | ✓ | KQ3
(706) | Shvartsman HS, Langstein H, Worley C, Malpica A, Ramondetta LM. Use of a vacuum-assisted closure device in the treatment of recurrent Paget’s disease of the vulva. Obstet Gynecol 2003 Nov;102(5 Pt 2):1163-6. | | | ✓ | Case report
(119) | Siegel HJ, Long JL, Watson KM, Fiveash JB. Vacuum-assisted closure for radiation-associated wound complications. J Surg Oncol 2007 Dec 1;96(7):575-82. | ✓ | KQ1, KQ3
(707) | Silberstein J, Grabowski J, Parsons JK. Use of a Vacuum-Assisted Device for Fournier’s Gangrene: A New Paradigm. Rev Urol 2008 Winter;10(1):76-80. | | | ✓ | Case report
(708) | Simek M, Nemec P, Zalesak B, Kalab M, Hajek R, Jecminkova L, Kolar M. Vacuum-assisted closure in the treatment of sterna wound infection after cardiac surgery. Biomed Pap Med Fac Univ Palacky Olomouc Czech Repub 2007 Dec;151(2):295-9. | | | ✓ | Duplicate study(123)
(709) | Simman R, Forte R, Silverberg B, Moriera-Gonzalez A, Williams F. A comparative histological study of skin graft take with tie-over bolster dressing versus negative pressure wound therapy in a pig model: a preliminary study. Wounds 2004 Feb;16(2):76-80. | | | ✓ | Animal study
(710) | Simon DH, Key JJ, Blume PA. Lower extremity wounds respond to negative pressure. Biomechanics 2008 Aug;15(8):53-9. | | | ✓ | Narrative
(711) | Simon S, Hammoudeh J, Low C, Nathan N, Armstrong M, Thaller S. Complex wound management with an artificial dermal regeneration template. Wounds 2008 Nov;20(11):299-302. | | | ✓ | Case reports
(712) | Singh K, Samartzis D, Heller JG, An HS, Vaccaro AR. The management of complex soft-tissue defects after spinal instrumentation. J Bone Joint Surg Br 2006 Jan;88(1):8-15. | | | ✓ | Narrative
(713) | Singh S, Mackey S, Soldin M. VAC it - Some techniques on the application of VAC dressings. Ann R Coll Surg Engl 2008 Mar;90(2):161-2. | | | ✓ | Narrative
(714) | Sjogren J, Gustafsson R, Koul B, Ingemansson R. Selective mediastinal tamponade to control coagulopathic bleeding. Ann Thorac Surg 2003 Apr;75(4):1311-3. | | | ✓ | Case report
(139) | Sjogren J, Gustafsson R, Nilsson J, Malmsjo M, Ingemansson R. Clinical outcome after poststernotomy mediastinitis: Vacuum-assisted closure versus conventional treatment. Ann Thorac Surg 2005;79(6):2049-55. | ✓ | KQ1, KQ3, Previous Systematic Reviews
(715) | Sjogren J, Gustafsson R, Wackenfors A, Malmsjo M, Algotsson L, Ingemansson R. Effects of vacuum-assisted closure on central hemodynamics in a sternotomy wound model. Interact Cardiovasc Thorac Surg 2004 Dec;3(4):666-71. | | | ✓ | Animal study
(716) | Sjogren J, Malmsjo M, Gustafsson R, Ingemansson R. Poststernotomy mediastinitis: a review of conventional surgical treatments, vacuum-assisted closure therapy and presentation of the Lund University Hospital mediastinitis algorithm. Eur J Cardiothorac Surg 2006 Dec;30(6):898-905. | | | ✓ | Narrative
(717) | Sjogren J, Mokhtari A, Gustafsson R, Malmsjo M, Nilsson J, Ingemansson R. Vacuum-assisted closure therapy for deep sternal wound infections: the impact of learning curve on survival and predictors for late mortality. Int Wound J 2008 Jun;5(2):216-23. | | | ✓ | Not relevant
(179) | Sjogren J, Nilsson J, Gustafsson R, Malmsjo M, Ingemansson R. The impact of vacuum-assisted closure on long-term survival after post-sternotomy mediastinitis. Ann Thorac Surg 2005 Oct;80(4):1270-5. | ✓ | Previous Systematic Reviews
(718) | Skillman J, Kirkpatrick N, Coombes A, Coghlan B, Waterhouse N, Joshi N, Kelly M. Vacuum Assisted Closure (VAC) dressing for skin graft application following exenteration of the orbit. Orbit 2003 Mar;22(1):63-5. | | | ✓ | Case report
(719) | Smith APS. A closer look at the potential of hyperbaric oxygen therapy. APMA News 2005 May;26(5–Suppl):39-42. | | | ✓ | Not relevant
(720) | Smith APS. Case study: treating a diabetic puncture wound. APMA News 2005 May;26(5–Suppl):16-18. | | | ✓ | Case report
(315) | Smith N. The benefits of VAC therapy in the management of pressure ulcers. Br J Nurs 2004 Dec 9-2005 Jan 12;13(22):1359-65. | | | ✓ | Reanalysis of already published data
(721) | Snyder N, Gould LJ. Scrotal and penile reconstruction using the vacuum-assisted closure device. Can J Plast Surg 2005 Dec;13(4):205-6. | | | ✓ | No abstract available
(124) | Song DH, Wu LC, Lohman RF, Gottlieb LJ, Franczyk M. Vacuum assisted closure for the treatment of sternal wounds: the bridge between debridement and definitive closure. Plast Reconstr Surg 2003 Jan;111(1):92-7. | ✓ | KQ1,KQ3, Previous Systematic Reviews
(316) | Sposato G, Molea G, Di Caprio G, Scioli M, La Rusca I, Ziccardi P. Ambulant vacuum-assisted closure of skin-graft dressing in the lower limbs using a portable mini-VAC device. Br J Plast Surg 2001 Apr;54(3):235-7. | | | ✓ | Narrative
(125) | Stannard JP, Robinson JT, Anderson ER, McGwin G Jr, Volgas DA, Alonso JE. Negative pressure wound therapy to treat hematomas and surgical incisions following high-energy trauma. J Trauma 2006 Jun;60(6):1301-6. | ✓ | KQ1, KQ3
(722) | Stawicki SP, Grossman M. "Stretching" negative pressure wound therapy: Can dressing change interval be extended in patients with open abdomens. Ostomy Wound Manage 2007 Jan;53(1):26-9. | | | ✓ | Narrative
(723) | Stawicki SP, Schwarz NS, Schrag SP, Lukaszczyk JJ, Schadt ME, Dippolito A. Application of vacuum-assisted therapy in postoperative ascitic fluid leaks: an integral part of multimodality wound management in cirrhotic patients. J Burns Wounds 2007 Apr 16;6:91-9. | | | ✓ | Fewer than five patients
(724) | Steed DL, Attinger C, Colaizzi T, Crossland M, Franz M, Harkless L, Johnson A, Moosa H, Robson M, Serena T, Sheehan P, Veves A, Wiersma-Bryant L. Guidelines for the treatment of diabetic ulcers. Wound Repair Regen 2006 Nov;14(6):680-92. | | | ✓ | Guideline
(725) | Steenvoorde P, de Roo RA, Oskam J, Neijenhuis P. Negative pressure wound therapy to treat peri-prosthetic methicillin-resistant Staphylococcus aureus infection after incisional herniorrhaphy. A case study and literature review. Ostomy Wound Manage 2006 Jan;52(1):52-4. | | | ✓ | Case report
(726) | Steenvoorde P, Rozeboom Al, Melief P, Elzo Kraemer CV, Bonsing BA. Failure of the topical negative pressure abdominal dressing system in the "fat" open abdomen: report of a case and review of literature. Wounds 2006 Feb;18(2):44-50. | | | ✓ | Case report
(727) | Steenvoorde P, Slotema E, Adhin S, Oskam J. Deep infection after ilioinguinal node dissection: vacuum-assisted closure therapy. Int J Low Extrem Wounds 2004 Dec;3(4):223-6. | | | ✓ | Case report
(728) | Steenvoorde P, van Engeland A, Bonsing B, da Costa SA, Oskam J. Combining topical negative pressure and a Bogota bag for managing a difficult laparostomy. J Wound Care 2004 Apr;13(4):142-3. | | | ✓ | Case report
(349) | Steiert AE, Gohritz A, Schreiber TC, Krettek C, Vogt PM. Delayed flap coverage of open extremity fractures after previous vacuum-assisted closure (VAC) therapy - worse or worth. J Plast Reconstr Aesthet Surg 2008 Mar 24;Epub ahead of print. | ✓ | KQ3
(729) | Steinberg JS. Exploring adjunctive combination therapy for wound bed preparation. APMA News 2005 May;26(5 Suppl):24-6. | | | ✓ | Narrative
(730) | Stinson JA, Powell JL. Necrotizing fasciitis in women at a community teaching hospital. J Pelvic Med Surg 2005 Jul-Aug;11(4):209-13. | | | ✓ | Not relevant to topic
(358) | Stoeckel WT, David L, Levine EA, Argenta AE, Perrier ND. Vacuum-assisted closure for the treatment of complex breast wounds. Breast 2006 Nov;15(5):610-3. | ✓ | KQ3
(731) | Stokes TH, Follmar KE, Silverstein AD, Weizer AZ, Donatucci CF, Anderson EE, Erdmann D. Use of negative-pressure dressings and split-thickness skin grafts following penile shaft reduction and reduction scrotoplasty in the management of penoscrotal elephantiasis. Ann Plast Surg 2006 Jun;56(6):649-53. | | | ✓ | Not relevant
(90) | Stone PA, Hass SM, Flaherty SK, DeLuca JA, Lucente FC, Kusminsky RE. Vacuum-assisted fascial closure for patients with abdominal trauma. J Trauma 2004 Nov;57(5):1082-6. | ✓ | KQ3 | | | ✓
(77) | Stonerock CE, Bynoe RP, Yost MJ, Nottingham JM. Use of a vacuum-assisted device to facilitate abdominal closure. Am Surg 2003 Dec;69(12):1030-4; discussion 1034-5. | ✓ | KQ3 | | | ✓
(320) | Suess JJ, Kim PJ, Steinberg JS. Negative pressure wound therapy: evidence-based treatment for complex diabetic foot wounds. Curr Diab Rep 2006 Dec;6(6):446-50. | | | ✓ | Narrative
(166) | Suliburk JW, Ware DN, Balogh Z, McKinley BA, Cocanour CS, Kozar RA, Moore FA. Vacuum-Assisted Wound Closure Achieves Early Fascial Closure of Open Abdomens after Severe Trauma. J Trauma Inj Infect Crit Care 2003;55(6):1155-60. | ✓ | KQ3
(732) | Summaries of current clinical evidence Engenex NPWT system. Skillman (NJ): ConvaTec, Inc.; 2 p. | | | ✓ | Poster presentation
(733) | Sunog T. Closing time. Adv Nurs 2003 Aug;18(34):39. | | | ✓ | No abstract available
(734) | Svedman, et al. A dressing system providing fluid supply and suction drainage used for continuous or intermittent irrigation. Ann Plast Surg 1986 Aug;17(2):125-33. | | | ✓ | Narrative
(149) | Svensson S, Monsen C, Kolbel T, Acosta S. Predictors for Outcome after Vacuum Assisted Closure Therapy of Peri-vascular Surgical Site Infections in the Groin. Eur J Vasc Endovasc Surg 2008 Jul;36(1):84-9. | ✓ | KQ3
(735) | Tan D, Rajanayagam J, Schwarz F. Treatment of long-standing, poor-healing diabetic foot ulcers with topical negative pressure in the Torres Strait. Aust J Rural Health 2007 Aug;15(4):275-6. | | | ✓ | Case report
(736) | Tang AT, Ohri SK, Haw MP. Novel application of vacuum assisted closure technique to the treatment of sternotomy wound infection. Eur J Cardiothorac Surg 2000 Apr;17(4):482-4. | | | ✓ | Narrative
(737) | Tang AT, Okri SK, Haw MP. Vacuum-assisted closure to treat deep sternal wound infection following cardiac surgery. J Wound Care 2000 May;9(5):229-30. | | | ✓ | Case report
(323) | Tanna N, Clary MS, Conrad DE, Lenert J, Sadeghi N. Vacuum-assisted closure for wound dehiscence in head and neck reconstruction. Plast Reconstr Surg 2009 Jan;123(1):19e-21e. | | | ✓ | Case report
(738) | Tarkin IS. The versatility of negative pressure wound therapy with reticulated open cell foam for soft tissue management after severe musculoskeletal trauma. J Orthop Trauma 2008 Nov-Dec;22(10 Suppl):S146-51. | | | ✓ | Narrative
(739) | Taub PJ, Schulman MR, Sett S, Koch RM. Revisiting vascularized muscle flaps for complicated sternal wounds in children. Ann Plast Surg 2005 Nov;55(5):535-7. | | | ✓ | Case report
(229) | Teot L, Lambert L, Ourabah Z, Bey E, Steenman C, Wierzbiecka E, Malikov S, Charles JP, Vives F, Bohbot S. Use of topical negative pressure with a lipidocolloid dressing: results of a clinical evaluation. J Wound Care 2006 Sep;15(8):355-8. | | | ✓ | Homemade device
(740) | Terrazas SG. Adjuvant dressing for negative pressure wound therapy in burns. Ostomy Wound Manage 2006 Jan;52(1):16, 18. | | | ✓ | No abstract available
(741) | Thomas S. An introduction to the use of vacuum assisted closure. In: World Wide Wounds [serial online]. ; 2001 May [accessed 2001 Jun 11]. [25 screens]. Available: http://www.worldwidewounds.com/2001/may/Thomas/Vacuum-Assisted-Closure.htm. | | | ✓ | Narrative
(742) | Thomas T. (Executive Director, Association for the Advancement of Wound Care. Malvern, PA). Personal communication – Full submission packet. 2009 Feb 1. 142 p p. | | | ✓ | Personal communication
(743) | Thompson JT, Marks MW. Negative pressure wound therapy. Clin Plast Surg 2007 Oct;34(4):673-84. | | | ✓ | Narrative
(326) | Timmers MS, Le Cessie S, Banwell P, Jukema GN. The effects of varying degrees of pressure delivered by negative-pressure wound therapy on skin perfusion. Ann Plast Surg 2005 Dec;55(6):665-71. | | | ✓ | No relevant outcomes
(744) | Torbrand C, Ingemansson R, Gustafsson L, Paulsson P, Malmsjo M. Pressure transduction to the thoracic cavity during topical negative pressure therapy of a sternotomy wound. Int Wound J 2008 Oct;5(4):579-84. | | | ✓ | Animal study
(745) | Torbrand C, Wackenfors A, Lindstedt S, Ekman R, Ingemansson R, Malmsjo M. Sympathetic and sensory nerve activation during negative pressure therapy of sternotomy wounds. Interact Cardiovasc Thorac Surg 2008 Dec;7(6):1067-70. | | | ✓ | Animal study
(746) | Trop M, Schintler M, Urban E, Roedl S, Stockenhuber A. Are 1:4 mesh and donor site contraindications for vacuum-assisted closure device. J Trauma 2006 Nov;61(5):1267-70. | | | ✓ | No abstract available
(747) | Trueman P, Flack S, Loonstra A, Hauser T. The feasibility of using V.A.C. Therapy in home care patients with surgical and traumatic wounds in the Netherlands. Int Wound J 2008 Jun;5(2):225-31. | | | ✓ | Not a clinical study
(748) | Trueman P. Cost-effectiveness considerations for home health V.A.C. Therapy in the United States of America and its potential international application. Int Wound J 2008 Jun;5 Suppl 2:23-6. | | | ✓ | Cost effectiveness
(174) | Ubbink DT, Westerbos SJ, Evans D, Land L, Vermeulen H. Topical negative pressure for treating chronic wounds (Review). In: Cochrane Database of Systematic Reviews [internet]. Issue 3. Hoboken (NJ): John Wiley & Sons, Ltd.; 2008 [Art. No.: CD001898]. | ✓ | Previous Systematic Reviews
(183) | Ubbink DT, Westerbos SJ, Nelson EA, Vermeulen H. A systematic review of topical negative pressure therapy for acute and chronic wounds. Br J Surg 2008 Jun;95(6):685-92. | ✓ | Previous Systematic Reviews
(228) | Using topical negative pressure with a lipidocolloid dressing. Ostomy Wound Manage 2008 Jun;54(6):12-4. | | | ✓ | No abstract available
(749) | Uygur F, Duman H, Ulkur E, Ceikoz B. The role of the vacuum-assisted closure therapy in the salvage of venous congestion of the free flap: case report. Int Wound J 2008 Mar;5(1):50-3. | | | ✓ | Case report
(750) | Vallet C, Saucy F, Haller C, Meier P, Rafoul W, Corpataux JM. Vacuum-assisted conservative treatment for the management and salvage of exposed prosthetic hemodialysis access. Eur J Vasc Endovasc Surg 2004 Oct;28(4):397-9. | | | ✓ | Case reports
(107) | van den Boogaard M, de Laat E, Spauwen P, Schoonhoven L. The effectiveness of topical negative pressure in the treatment of pressure ulcers: a literature review. Eur J Plastic Surg 2008 Apr;31(1):1-7. | ✓ | KQ1, KQ3
(368) | van Rhee MA, de Klerk LW, Verhaar JA. Vacuum-assisted wound closure of deep infections after instrumented spinal fusion in six children with neuromuscular scoliosis. Spine J 2007 Sep-Oct;7(5):596-600. | ✓ | KQ3
(751) | Varker KA, Ng T. Management of empyema cavity with the vacuum-assisted closure device. Ann Thorac Surg 2006 Feb;81(2):723-5. | | | ✓ | Case report
(752) | Venturi ML, Attinger CE, Mesbahi AN, Hess CL, Graw KS. Mechanisms and clinical applications of the vacuum-assisted closure (VAC) Device: a review. Am J Clin Dermatol 2005;6(3):185-94. | | | ✓ | Narrative
(753) | Verhaalen Al. Isolation of an entercutaneous fistula within a vacuum-assisted wound closure system. Gen Surg 2006 Aug;33(8) | | | ✓ | Case report
(754) | Verrillo SC. Negative pressure therapy for infected sternal wounds: a literature review. J Wound Ostomy Continence Nurs 2004 Mar-Apr;31(2):72-4. | | | ✓ | Narrative
(342) | Vidrine DM, Kaler S, Rosenthal EL. A comparison of negative-pressure dressings versus Bolster and splinting of the radial forearm donor site. Otolaryngol Head Neck Surg 2005 Sep;133(3):403-6. | | | ✓ | KQ1, KQ3
(178) | Vikatmaa P, Juutilainen V, Kuukasjarvi P, Malmivaara A. Negative Pressure Wound Therapy: a Systematic Review on Effectiveness and Safety. Eur J Vasc Endovasc Surg 2008 Oct;36(4):438-48. | ✓ | Previous Systematic Reviews
(755) | von Gossler CM, Horch RE. Rapid aggressive soft-tissue necrosis after beetle bite can be treated by radical necrectomy and vacuum suction-assisted closure. J Cutan Med Surg 2000 Oct;4(4):219-22. | | | ✓ | Case report
(115) | Vuerstaek JD, Vainas T, Wuite J, Nelemans P, Neumann MH, Veraart JC. State-of-the-art treatment of chronic leg ulcers: A randomized controlled trial comparing vacuum-assisted closure (V.A.C.) with modern wound dressings. J Vasc Surg 2006 Nov;44(5):1029-37; discussion 1038. | | | ✓ | KQ1, KQ3
(756) | Wackenfors A, Gustafsson R, Sjogren J, Algotsson L, Ingemansson R, Malmsjo M. Blood flow responses in the peristernal thoracic wall during vacuum-assisted closure therapy. Ann Thorac Surg 2005 May;79(5):1724-30; discussion 1730-. | | | ✓ | Animal study
(757) | Wackenfors A, Sjogren J, Algotsson L, Gustafsson R, Ingemansson R, Malmsjo M. The effect of vacuum-assisted closure therapy on the pig femoral artery vasomotor responses. Wound Repair Regen 2004 Mar-Apr;12(2):244- | | | ✓ | Animal study
(40) | Wackenfors A, Sjogren J, Gustafsson R, Algotsson L, Ingemansson R, Malmsjo M. Effects of vacuum-assisted closure therapy on inguinal wound edge microvascular blood flow. Wound Repair Regen 2004 Nov-Dec;12(6):600-6. | | | ✓ | Animal study
(384) | Wada A, Ferreira MC, Tuma Junior P, Arrunategui G. Experience with local negative pressure (vacuum method) in the treatment of complex wounds. Sao Paulo Med J 2006 May 4;124(3):150-3. | ✓ | KQ3
(118) | Wanner MB, Schwarzl F, Strub B, Zaech GA, Pierer G. Vacuum-assisted wound closure for cheaper and more comfortable healing of pressure sores: a prospective study. Scand J Plast Reconstr Surg Hand Surg 2003;37(1):28-33. | ✓ | KQ1,KQ3
(172) | Wasiak J, Cleland H. Topical negative pressure (TNP) for partial thickness burns. Cochrane Database Syst Rev 2007;(3):CD006215. | ✓ | Previous Systematic Reviews
(758) | Webb LX, Lavery D, DeFranzo A. Negative pressure wound therapy in the management of orthopedic wounds. Ostomy Wound Manage 2004 Apr;50(4A Suppl):26-7. | | | ✓ | Narrative
(759) | Webb LX, Pape HC. Current thought regarding the mechanism of action of negative pressure wound therapy with reticulated open cell foam. J Orthop Trauma 2008 Nov-Dec;22(10 Suppl):S135-7. | | | ✓ | Narrative
(760) | Webb LX. New techniques in wound management: vacuum-assisted wound closure. J Am Acad Orthop Surg 2002 Sep-Oct;10(5):303-11. | | | ✓ | Narrative
(37) | Weed T, Ratliff C, Drake DB. Quantifying bacterial bioburden during negative pressure wound therapy: does the wound VAC enhance bacterial clearance. Ann Plast Surg 2004 Mar;52(3):276-9; discussion 279-80. | ✓ | KQ3
(761) | Weinfeld AB, Kelley P, Yuksel E, Tiwari P, Hsu P, Choo J, Hollier LH. Circumferential negative-pressure dressing (VAC) to bolster skin grafts in the reconstruction of the penile shaft and scrotum. Ann Plast Surg 2005 Feb;54(2):178-83. | | | ✓ | Case reports
(762) | Wessel LC, Cunningham BL. Patient with compartment syndrome of the lower extremity. J Wound Ostomy Continence Nurs 2002 Jul;29(4):210-5. | | | ✓ | Case report
(763) | Whelan C, Stewart J, Schwartz BF. Mechanics of wound healing and importance of Vacuum Assisted Closure in urology. J Urol 2005 May;173(5):1463-70. | | | ✓ | Narrative
(764) | White RA, Miki RA, Kazmier P, Anglen JO. Vacuum-assisted closure complicated by erosion and hemorrhage of the anterior tibial artery. J Orthop Trauma 2005 Jan;19(1):56-9. | | | ✓ | Case report
(765) | Whitney J, Phillips L, Aslam R, Barbul A, Gottrup F, Gould L, Robson MC, Rodeheaver G, Thomas D, Stotts N. Guidelines for the treatment of pressure ulcers. Wound Repair Regen 2006 Nov-Dec;14(6):663-79. | | | ✓ | Guideline
(116) | Wild T, Stremitzer S, Budzanowski A, Hoelzenbein T, Ludwig C,Ohrenberger G. Definition of efficiency in vacuum therapy – A randomised controlled trial comparing Redon drains with V.A.C. Therapy™. Int Wound J 2008 Dec;5(5):641-7. | ✓ | KQ2
(766) | Wilkes R, Zhao Y, Kieswetter K, Haridas B. Effects of Dressing Type on 3D Tissue Microdeformations During Negative Pressure Wound Therapy: A Computational Study. J Biomech Eng 2009 Mar;131(3):031012. | | | ✓ | Not a clinical study
(767) | Willy C, Voelker HU, Engelhardt M. Literature on the subject of vacuum therapy: review and update 2006. Eur J Trauma Emerg Surg 2007 Feb;33(1):33-9. | | | ✓ | Not relevant - not a systematic review of wound healing data
(768) | Wiseman J, Cullington JR, Schaeferle M 3rd, Beckham PH, Salisbury M, Ersek RA. Aesthetic aspects of neurofibromatosis reconstruction with the vacuum-assisted closure system. Aesthetic Plast Surg 2001 Sep-Oct;25(5):326-31. | | | ✓ | Case Report
(769) | Wolvos T. Wound instillation with negative pressure wound therapy. Ostomy Wound Manage 2005 Feb;51(2A Suppl):21S-6S. | | | ✓ | Narrative
(770) | Wolvos T. Wound instillation--the next step in negative pressure wound therapy. Lessons learned from initial experiences. Ostomy Wound Manage 2004 Nov;50(11):56-66. | | | ✓ | Narrative
(161) | Wondberg D, Larusson HJ, Metzger U, Platz A, Zingg U. Treatment of the open abdomen with the commercially available vacuum-assisted closure system in patients with abdominal sepsis: low primary closure rate. World J Surg 2008 Dec;32(12):2724-9. | ✓ | KQ3
(771) | Wong LK, Nesbit RD, Turner LA, Sargent LA. Management of a circumferential lower extremity degloving injury with the use of vacuum-assisted closure. South Med J 2006 Jun;99(6):628-30. | | | ✓ | Case Report
(75) | Wongworawat MD, Schnall SB, Holtom PD, Moon C, Schiller F. Negative pressure dressings as an alternative technique for the treatment of infected wounds. Clin Orthop Relat Res 2003 Sep;(414):45-8. | ✓ | KQ3 | | | ✓
(772) | Woo KY, Sibbald RG. Vacuum-assisted closure home care training: a process to link education to improved patient outcomes. Int Wound J 2008 Jun;5 Suppl 2:1-9. | | | ✓ | Narrative
(773) | Wound wonder. Middle East Medical 2003 May-Jun;61-5. | | | ✓ | Narrative
(774) | Wu S. Case study: treating a patient with a diabetic neuropathic ulceration. APMA News 2005 May;26(5–Suppl):19. | | | ✓ | Narrative Case Report
(775) | Wu SC, Lavery LA, Armstrong DG. Closing difficult wounds. Podiatry Today 2006 Mar;19(3):44-54. | | | ✓ | Narrative
(776) | Wu Sc, Yoon H, Armstrong DG. Therapy with advanced modalities: can it expedite healing?. Podiatry Today 2005 Sep;18(9):18-24. | | | ✓ | Narrative
(158) | Wu SH, Zecha PJ, Feitz R, Hovius SE. Vacuum therapy as an intermediate phase in wound closure: A clinical experience. Eur J Plastic Surg 2000 May;23(4):174-7. | ✓ | KQ3
(777) | Wustmann O, Ulrich HC. German patent specification. Appliance for the drainage of wounds. No. 847 475 Class 30 K Group 17 04. 1952 | | | ✓ | Not relevant
(72) | Yang CC, Chang DS, Webb LX. Vacuum-assisted closure for fasciotomy wounds following compartment syndrome of the leg. J Surg Orthop Adv 2006 Spring;15(1):19-23. | ✓ | KQ1 | | | ✓
(778) | Yoong S, Dunne G, Cochrane J, Lee B, Lee J. Vacuum-assisted closure for the treatment of parastomal skin necrosis: a novel approach to an unusual complication. Report of a case. Dis Colon Rectum 2008 Oct;51(10):1577-9. | | | ✓ | Case report
(779) | Yousaf M, Witherow A, Gardiner KR, Gilliland R. Use of vacuum-assisted closure for healing of a persistent perineal sinus following panproctocolectomy: report of a case. Dis Colon Rectum 2004 Aug;47(8):1403-7; discussion 1407-8. | | | ✓ | Case report
(780) | Yuan-Innes MJ, Temple CL, Lacey MS. Vacuum-assisted wound closure: a new approach to spinal wounds with exposed hardware. Spine 2001 Feb 1;26(3):E30-3. | | | ✓ | Fewer than five patients
(781) | Yuh DD, Albaugh M, Ullrich S, Conte JV. Treatment of ventricular assist device driveline infection with vacuum-assisted closure system. Ann Thorac Surg 2005 Oct;80(4):1493-5. | | | ✓ | Case report
(782) | Zamierowski D. United States Patent. Wound dressing and treatment method. No. 4969880. 1990. | | | ✓ | Patent
(783) | Zehnder SW, Place HM. Vacuum-assisted wound closure in postoperative spinal wound infection. Orthopedics 2007 Apr;30(4):267-72. | | | ✓ | Narrative
(784) | Zutt M, Haas E, Kruger U, Distler M, Neumann C. Successful use of vacuum-assisted closure therapy for leg ulcers caused by occluding vasculopathy and inflammatory vascular diseases—a case series. Dermatology 2007;214(4):319-24. | | | ✓ | Case reports

KQ Key question

Figure 7 Disposition of Submission by Kinetic Concepts, Inc.

Note: Language has been corrected to reflect screening of meeting abstracts, poster presentations and other documents in addition to abstracts and full articles.

Figure 7 is an attrition diagram that depicts the status of documents that Kinetic Concepts Inc. submitted for possible inclusion in the report. The diagram begins with a box outlining the total submission of 593 documents. Several boxes ensue which are connected by arrows going from top to bottom which follow the submissions as they are being screened for possible inclusion in the report. In the first frame, we compare KCI’s submission to submissions by other interested stakeholders and remove any duplicates. KCI had zero duplicate submissions. An arrow leads from the 593 Unique Submissions to the Initial Screening Phase where documents may be excluded, used in our Background Section or passed to the next level. In this instance, 178 documents were identified for exclusion. 143 were case reports, abstracts, or poster presentations; 1 was product information; 2 were personal communications; and 32 were other documents not relevant to the report. One document was identified for inclusion in our Background Section. The path then follows the 414 full articles remaining. During this phase of screening we do a more extensive screening which is again based on our pre-determined inclusion/exclusion criteria. See our Methods Section for additional information on the criteria. 272 articles were excluded during this evaluation phase. 31 were animal studies; four were cost analyses; 9 were duplicate studies; 30 included fewer than five patients; 13 were guidelines; five were homemade devices; 3 were in vitro studies; 141 were narrative reviews; nine did not include relevant outcomes; four were not clinical studies; five did not include a NPWT device; one was not a NPWT study; and seventeen were excluded for Other Reasons which may include “inclusion of healthy subjects”, “lack of reporting wound healing outcomes” or “patients treated with dual therapies.” Of the 142 full articles remaining for possible inclusion in the report; 117 were already identified in our literature searches. Of the 25 studies that ultimately met the inclusion criteria but were not identified in the literature searches; two studies were included in Key Question 1, 22 studies were relevant to Key Question 3 and one was included as a systematic review of NPWT. Note: Language has been corrected to reflect screening of meeting abstracts, poster presentations and other documents in addition to abstracts of full articles.

Table 44 Status of Submissions by Kinetic Concepts, Inc.

Reference Number | Reference | Included | Placement in Report | Excluded | Reason for Exclusion | Included but Not Identified in ECRI Search
(390) | Abai B, Zickler RW, Pappas PJ, Lal BK, Padberg FT Jr. Lymphorrhea responds to negative pressure wound therapy. J Vasc Surg 2007 Mar;45(3):610-3. | | | ✓ | Fewer than five patients
(152) | Adamkova M, Tymonova J, Zamecnikova I, Kadlcik M, Klosova H. First experience with the use of vacuum assisted closure in the treatment of skin defects at the Burn Center. Acta Chir Plast 2005;47(1):24-7. | ✓ | KQ3
(372) | Agarwal JP, Ogilvie M, Wu LC, Lohman RF, Gottlieb LJ, Franczyk M, Song DH. Vacuum-assisted closure for sternal wounds: A first-line therapeutic management approach. Plast Reconstr Surg 2005 Sep 15;116(4):1035-40. | ✓ | KQ3
(391) | Agrawal S, Hayhurst C, Joseph T, Prinsloo D, Morgan RH, Pherwani AD. Successful salvage of infected and exposed non-absorbable mesh following decompressing laparostomy after emergency repair of ruptured abdominal aortic aneurysm using vacuum-assisted closure system. Eur J Vasc Endovasc Surg 2008 Jan;15(1):1-2. | | | ✓ | Narrative
(392) | Aguinaga S, Welber A, Stephens S. Positive steps towards negative pressure wound therapy. Medsurg Nurs 2007 Jun;16(3):181-2, 189. | | | ✓ | Narrative
(393) | Alvarez AA, Maxwell GL, Rodriguez GC. Vacuum-assisted closure for cutaneous gastrointestinal fistula management. Gynecol Oncol 2001 Mar;80(3):413-6. | | | ✓ | Case report
(394) | Andrabi SI, Ahmad J, Rathore MA, Yousaf M. Vacuum assisted closure of laparostomy wounds "a novel technique". J Ayub Med Coll Abbottabad 2007 Jul-Sep;19(3):89-92. | | | ✓ | Case report
(395) | Andrabi SI, Ahmad J. Negative pressure therapy for laparotomy wounds--a word of caution. J Wound Ostomy Continence Nurs 2007 Jul-Aug;34(4):425-7. | | | ✓ | Case report
(396) | Andrews BT, Smith RB, Chang KE, Scharpf J, Goldstein DP, Funk GF. Management of the radial forearm free flap donor site with the vacuum-assisted closure (VAC) system. Laryngoscope 2006 Oct;116(10):1918-22. | | | ✓ | No relevant outcomes
(88) | Andrews BT, Smith RB, Goldstein DP, Funk GF. Management of complicated head and neck wounds with vacuum-assisted closure system. Head Neck 2006 Nov;28(11):974-81. | ✓ | KQ3 | | | ✓
(397) | Andrews BT, Smith RB, Hoffman HT, Funk GF. Orocutaneous and pharyngocutaneous fistula closure using a vacuum-assisted closure system. Ann Otol Rhinol Laryngol 2008 Apr;117(4):298-302. | | | ✓ | Fewer than five patients
(398) | Andros G, Armstrong DG, Attinger C, Boutlon AJ, Frykberg RG, Joseph WS, Lavery LA, Morbach S, Niezgoda JA, Toursarkissian B. Consensus statement on negative pressure wound therapy (VAC Therapy) for the management of diabetic foot wounds. Wounds 2006 Jun;52(6 Suppl):1-32. | | | ✓ | Guideline
(385) | Antony S, Terrazas S. A retrospective study: Clinical experience using vacuum-assisted closure in the treatment of wounds. J Natl Med Assoc 2004;96(8):1073-7. | ✓ | KQ3
(192) | Apelqvist J, Armstrong DG, Lavery LA, Boulton AJ. Resource utilization and economic costs of care based on a randomized trial of vacuum-assisted closure therapy in the treatment of diabetic foot wounds. Am J Surg 2008 Jun;195(6):782-8. | | | ✓ | Cost analysis
(399) | Arca MJ, Somers KK, Derks TE, Goldin AB, Aiken JJ, Sato TT, Shilyansky J, Winthrop A, Oldham KT. Use of vacuum-assisted closure system in the management of complex wounds in the neonate. Pediatr Surg Int 2005 Jul;21(7):532-5. Epub 2005 Jun 17. | | | ✓ | Fewer than five patients
(400) | Archdeacon MT, Messerschmitt P. Modern papineau technique with vacuum-assisted closure. J Orthop Trauma 2006 Feb;20(2):134-7. | | | ✓ | Case report
(401) | Argenta LC, Morykwas MJ, Marks MW, DeFranzo AJ, Molnar JA, David LR. Vacuum-assisted closure: state of clinic art. Plast Reconstr Surg 2006 Jun;117(7 Suppl):127S-142S. | | | ✓ | Narrative
(148) | Argenta LC, Morykwas MJ. Vacuum-assisted closure: a new method for wound control and treatment: clinical experience. Ann Plast Surg 1997 Jun;38(6):563-76; discussion 577. | ✓ | KQ3 | | | ✓
(402) | Argenta PA, Rahaman J, Gretz HF 3rd, Nezhat F, Cohen CJ. Vacuum-assisted closure in the treatment of complex gynecologic wound failures. Obstet Gynecol 2002 Mar;99(3):497-501. | | | ✓ | Fewer than five patients
(785) | Argenta A, Webb K, Simpson J, Gordon S, Kortesis B, Wanner M, Kremers L, Morykwas M. Deformation of superficial and deep abdominal tissues with application of a controlled vacuum. In: European Tissue Repair Society, Focus group meeting Topical Negative Pressure (TNP) Therapy; 4–6 December 2003; London. | | | ✓ | Focus on cellular and biochemistry measurements
(403) | Armstrong DG, Attinger CE, Boulton AJ, Frykberg RG, Kirsner RS, Lavery LA, Mills JL. Guidelines regarding negative wound therapy (NPWT) in the diabetic foot. Ostomy Wound Manage 2004 Apr;50(4B Suppl):3S-27S. | | | ✓ | Guideline
(404) | Armstrong DG, Boulton AJ, Banwell P. Negative pressure wound therapy in treatment of diabetic foot wounds: a marriage of modalities. Ostomy Wound Manage 2004 Apr;50(4A Suppl):9-12. | | | ✓ | Narrative
(194) | Armstrong DG, Kunze K, Martin BR, Kimbriel HR, Nixon BP, Boulton AJ. Plantar pressure changes using a novel negative pressure wound therapy technique. J Am Podiatr Med Assoc 2004 Sep-Oct;94(5):456-60. | | | ✓ | Not a NPWT study
(85) | Armstrong DG, Lavery LA, Abu-Rumman P, Espensen EH, Vazquez JR, Nixon BP, Boulton AJ. Outcomes of subatmospheric pressure dressing therapy on wounds of the diabetic foot. Ostomy Wound Manage 2002 Apr;48(4):64-8. | ✓ | KQ3 | | | ✓
(109) | Armstrong DG, Lavery LA, Boulton AJ. Negative pressure wound therapy via vacuum-assisted closure following partial foot amputation: what is the role of wound chronicity?. Int Wound J 2007 Mar;4(1):79-86. | ✓ | KQ1, KQ3
(195) | Armstrong DG, Lavery LA, Diabetic Foot Study Consortium. Negative pressure wound therapy after partial diabetic foot amputation: a multicentre, randomised controlled trial. Lancet 2005 Nov 12;366(9498):1704-10. | | | ✓ | Study population reported in(109)
(405) | Armstrong DG, Lavery LA. Decreasing foot pressures while implementing topical negative pressure (vacuum-assisted closure) therapy. Int J Low Extrem Wounds 2004 Mar;3(1):12-5. | | | ✓ | Narrative
(406) | Attar KH, Imran D, Iyer S. Vacuum-assisted closure (VAC) therapy in the management of digital pulp defects. Acta Chir Plast 2007;49(3):75-6. | | | ✓ | Case report
(92) | Avery C, Pereira J, Moody A, Gargiulo M, Whitworth I. Negative pressure wound dressing of the radial forearm donor site. Int J Oral Maxillofac Surg 2000 Jun;29(3):198-200. | ✓ | KQ3 | | | ✓
(407) | Aydin U, Ozgenel Y. A simple solution for preventing air leakage in VAC therapy for sacral pressure sores. J Plast Reconstr Aesthet Surg 2008 Oct;61(10):1267-9. | | | ✓ | Narrative
(408) | Ayello EA, Baranoski S, Morey J. VAC heals complex wounds. Nurs Spectrum (Phila Tri- State) 2003 Dec;15(24):16-17. | | | ✓ | Narrative
(409) | Azad SM, Allison K, Khwaja N, Moiemen N. Frostbite of the gluteal region. Burns 2003 Nov;29(7):739-44. | | | ✓ | No abstract available
(410) | Baharestani M, de Leon J, Mendez-Eastman S, Powell G, Weir D, Niezgoda J, Payne W, Nanney LB, Pelham F, Gupta S. Consensus statement: a practical guide for managing pressure ulcers with negative pressure wound therapy utilizing vacuum-assisted closure. Understanding the treatment algorithm. Adv Skin Wound Care 2008 Jan;21(Suppl 1):1-20. | | | ✓ | Guideline
(411) | Baharestani MM, Driver VR, de Leon JM, Gabriel A, Kaplan M, Lantis J, Lavery L, Pelham F, Powell G, Webb L. Optimizing clinical and cost effectiveness with early intervention of V.A.C. therapy. Ostomy Wound Manage 2008;54(11 Suppl):1-15. | | | ✓ | Narrative
(199) | Baharestani MM, Houliston-Otto DB, Barnes S. Early versus late initiation of negative pressure wound therapy: examining the impact on home care length of stay. Ostomy Wound Manage 2008 Nov;54(11):48-53. | | | ✓ | No relevant outcomes
(93) | Baharestani MM. Negative pressure wound therapy in the adjunctive management of necrotizing fascitis: examining clinical outcomes. Ostomy Wound Manage 2008 Apr;54(4):44-50. | ✓ | KQ3 | | | ✓
(412) | Baharestani MM. Negative pressure wound therapy: an examination of cost-effectiveness. Ostomy Wound Manage 2004 Nov;50(11A Suppl):29S-33S. | | | ✓ | Cost analysis
(162) | Baharestani MM. Use of negative pressure wound therapy in the treatment of neonatal and pediatric wounds: a retrospective examination of clinical outcomes. Ostomy Wound Manage 2007 Jun;53(6):75-85. | ✓ | KQ3
(413) | Ballard K, McGregor F. Use of vacuum-assisted closure therapy following foot amputation. Br J Nurs 2001 Aug;10(15 Suppl):S6-12. | | | ✓ | Case report
(344) | Bannasch H, Iblher N, Penna V, Torio N, Felmerer G, Stark GB, Momeni A. A critical evaluation of the concomitant use of the implantable Doppler probe and the Vacuum Assisted Closure system in free tissue transfer. Microsurgery 2008;28(6):412-6. | ✓ | KQ3
(414) | Banwell PE, Ahmed S, Teot L. Topical negative pressure versus closed surgical wound drainage: a difference in philosophy. J Wound Care 2005 Oct;14(9):445-7. | | | ✓ | Narrative
(415) | Banwell PE, Musgrave M. Topical negative pressure therapy: mechanisms and indications. Int Wound J 2004 Jun;1(2):95-106. | | | ✓ | Narrative
(416) | Banwell PE, Teot L. Topical negative pressure (TNP): the evolution of a novel wound therapy. J Wound Care 2003 Jan;12(1):22-8. | | | ✓ | Narrative
(417) | Banwell PE. Topical negative pressure therapy in wound care. J Wound Care 1999 Feb;8(2):79-84. | | | ✓ | Narrative
(418) | Banwell PE. Topical negative pressure therapy: advances in burn wound management. Ostomy Wound Manage 2004 Nov;50(11A-Suppl):9S-14S. | | | ✓ | Narrative
(153) | Bapat V, El-Muttardi N, Young C, Venn G, Roxburgh J. Experience with vacuum-assisted closure of sternal wound infections following cardiac surgery and evaluation of chronic complications associated with its use. J Card Surg 2008 May;23(3):227-33. | ✓ | KQ3
(200) | Barker DE, Kaufman HJ, Smith LA, Ciraulo DL, Richart CL, Burns RP. Vacuum pack technique of temporary abdominal closure: a 7-year experience with 112 patients. J Trauma 2000 Feb;48(2):201-6; discussion 206-7. | | | ✓ | Homemade device
(202) | Barringer CB, Gorse SJ, Burge TS. The VAC dressing—a cautionary tale. Br J Plast Surg 2004 Jul;57(5):482. | | | ✓ | No abstract available
(419) | Baxandall T. Tissue viability. Healing cavity wounds with negative pressure. Nurs Stand 1996 Oct 30;11(6):49-51. | | | ✓ | Narrative
(420) | Baynham SA, Kohlman P, Katner HP. Treating stage IV pressure ulcers with negative pressure therapy: a case report. Ostomy Wound Manage 1999 Apr;45(4):28-32, 34-5. | | | ✓ | Case report
(421) | Benbow M, Beldon P, Butcher M, Newton H, Hampton S, Baxter H. Topical negative pressure: a systemic review of the available evidence. J Community Nurs 2007 Jun;21(6) | | | ✓ | Not relevant - focus on access and usage of total negative pressure
(422) | Benbow M. Update on VAC therapy.Journal of Community Nursing-Online; 2006 Apr [accessed 2006 Nov 15]. Available: http://www.jcn.com.uk/. | | | ✓ | Narrative
(82) | Bendewald FP, Cima RR, Metcalf DR, Hassan I. Using negative pressure wound therapy following surgery for complex pilonidal disease: a case series. Ostomy Wound Manage 2007 May;53(5):40-6. | ✓ | KQ3 | | | ✓
(76) | Bendo JA, Quirno M, Pelham F, Barone JA, Awad J. Posterior lumbar wound drainage management with vacuum-assisted closure. World Spine J 2007 Sep;2(4):187-90. | ✓ | KQ3 | | | ✓
(423) | Bennett W. Novel use of VAC therapy in a patient with lymphocele after varicose surgery. Wounds UK 2007 Dec;3(4):129-32. | | | ✓ | Case report
(424) | Bernstein BH, Tam H. Combination of subatmospheric pressure dressing and gravity feed antibiotic instillation in the treatment of post-surgical diabetic foot wound: a case series. Wounds 2005 Feb;17(2):37-48. | | | ✓ | Narrative
(425) | Bertelsen CA, Wille-Jorgensen P. Use of topical negative pressure to manage a complex wound with a vesicocutaneous fistula. J Wound Care 2006 Apr;15(4):172-3. | | | ✓ | Case report
(350) | Bhattacharyya T, Mehta P, Smith M, Pomahac B. Routine use of wound vacuum-assisted closure does not allow coverage delay for open tibia fractures. Plast Reconstr Surg 2008 Apr;121(4):1263-6. | ✓ | KQ3
(134) | Bickels J, Kollender Y, Wittig JC, Cohen N, Meller I, Malawer MM. Vacuum-assisted wound closure after resection of musculoskeletal tumors. Clin Orthop Relat Res 2005 Dec;441:346-50. | ✓ | KQ1, KQ3
(386) | Bihariesingh VJ, Stolarczyk EM, Karim RB, van Kooten EO. Plastic solutions for orthopaedic problems. Arch Orthop Trauma Surg 2004;124(2):73-6. | ✓ | KQ3 | | | ✓
(426) | Birchall L, Street L, Clift H. Developing a trust-wide centralised approach to the use of TNP. J Wound Care 2002 Sep;11(8):311-4. | | | ✓ | Narrative
(427) | Blackburn JH 2d, Boemi L, Hall WW, Jeffords K, Hauck RM, Banducci DR, Graham WP 3d. Negative-pressure dressings as a bolster for skin grafts. Ann Plast Surg 1998 May;40(5):453-7. | | | ✓ | Narrative
(108) | Blume PA, Walters J, Payne W, Ayala J, Lantis J. Comparison of negative pressure wound therapy using vacuum-assisted closure with advanced moist wound therapy in the treatment of diabetic foot ulcers: a multicenter randomized controlled trial. Diabetes Care 2008 Apr;31(4):631-6. | ✓ | KQ1, KQ3
(141) | Bollero D, Carnino R, Risso D, Gangemi EN, Stella M. Acute complex traumas of the lower limbs: A modern reconstructive approach with negative pressure therapy. Wound Repair Regen 2007 Jul;15(4):589-94. | ✓ | KQ3
(428) | Bolton LL. Negative pressure wound therapy. Wounds 2005 Apr;17(4):A29-A32. | | | ✓ | Narrative
(429) | Bonnet F, Pavy B, Beaudoin S, Dubousset J, Mitrofanoff M. Treatment of a large defect of the chest wall in a child using a negative pressure wound dressing. Scand J Plast Reconstr Surg Hand Surg 2007;41(3):143-5. | | | ✓ | Case report
(430) | Bookout K, McCord S, McLane K. Case studies of an infant, a toddler, and an adolescent treated with a negative pressure wound treatment system. J Wound Ostomy Continence Nurs 2004 Jul-Aug;31(4):184-92. | | | ✓ | Fewer than five patients
(207) | Bovill E, Banwell PE, Teot L, Eriksson E, Song C, Mahoney J, Gustafsson R, Horch R, Deva A, Whitworth I, International Advisory Panel on Topical Negative Pressure. Topical negative pressure wound therapy: a review of its role and guidelines for its use in the management of acute wounds. Int Wound J 2008 Oct;5(4):511-29. | | | ✓ | Narrative
(114) | Braakenburg A, Obdeijn MC, Feitz R, van Rooij IA, van Griethuysen AJ, Klinkenbijl JH. The clinical efficacy and cost effectiveness of the vacuum-assisted closure technique in the management of acute and chronic wounds: a randomized controlled trial. Plast Reconstr Surg 2006 Aug;118(2):390-7; discussion 398-400. | ✓ | KQ1, KQ3
(431) | Brace JA. Negative pressure wound therapy for abdominal wounds. J Wound Ostomy Continence Nurs 2007 Jul-Aug;34(4):428-30. | | | ✓ | Narrative
(345) | Brandi C, Grimaldi L, Nisi G, Silvestri A, Brafa A, Calabro M, D’Aniello C. Treatment with vacuum-assisted closure and cryo-preserved homologous de-epidermalised dermis of complex traumas to the lower limbs with loss of substance, and bones and tendons exposure. J Plast Reconstr Aesthet Surg 2008 Dec;61(12):1507-11. | ✓ | KQ3
(432) | Brogna L. Home care management of an ostomy within a dehisced abdominal wound. J Wound Ostomy Continence Nurs 2005 May-Jun;32(3):200-2; discussion 202-4. | | | ✓ | Case reports
(433) | Bronchard R, de Vaumas C, Lasocki S, Jabbour K, Geffroy A, Kermarrec N, Montravers P. Vacuum-assisted closure in the treatment of perineal necrotizing skin and soft tissue infections. Intensive Care Med 2008 Jul;34(7):1345-7. | | | ✓ | Abstract not available
(434) | Bronson N, Menon R, Butler J, Gordon I. Parathyroidectomy, excision and skin grafting with topical negative pressure for calciphylactic ulcers. J Wound Care 2007 Jul;16(7):295-7. | | | ✓ | Case report
(435) | Brown KM, Harper FV, Aston WJ, O’Keefe PA, Cameron CR. Vacuum-assisted closure in the treatment of a 9-year-old child with severe and multiple dog bite injuries of the thorax. Ann Thorac Surg 2001 Oct;72(4):1409-10. | | | ✓ | Case report
(436) | Burton L. Nonhealing foot ulcer. Ostomy Wound Manage 1999 Sep;45(9):20-1. | | | ✓ | Case report
(144) | Butter A, Emran M, Al-Jazaeri A, Ouimet A. Vacuum-assisted closure for wound management in the pediatric population. J Pediatr Surg 2006 May;41(5):940-2. | ✓ | KQ3
(437) | Canavese F, Gupta S, Krajbich JI, Emara KM. Vacuum-assisted closure for deep infection after spinal instrumentation for scoliosis. J Bone Joint Surg Br 2008 Mar;90(3):377-81. | ✓ | KQ3
(165) | Caniano DA, Ruth B, Teich S. Wound management with vacuum-assisted closure: experience in 51 pediatric patients. J Pediatr Surg 2005 Jan;40(1):128-32; discussion 132. | ✓ | KQ3
(438) | Canter HI, Isci E, Erk Y. Vacuum-assisted wound closure for the management of a foot ulcer due to Buerger’s disease. J Plast Reconstr Aesthet Surg 2007 Nov 1;Epub ahead of print. | | | ✓ | Case report
(439) | Carson SN, Overall K, Lee-Jahshan S, Travis E. Vacuum-assisted closure used for healing chronic wounds and skin grafts in the lower extremities. Ostomy Wound Manage 2004 Mar;50(3):52-8. | | | ✓ | Narrative
(137) | Catarino PA, Chamberlain MH, Wright NC, Black E, Campbell K, Robson D, Pillai RG. High-pressure suction drainage via a polyurethane foam in the management of poststernotomy mediastinitis. Ann Thorac Surg 2000 Dec;70(6):1891-5. | | | ✓ | Not relevant (suction drainage)
(440) | Chandawarkar RY, Piorkowski J, Amjad I, Deckers PJ. Combination therapy of a large, recurrent keloid. Dermatol Surg 2007 Feb;33(2):229-35. | | | ✓ | Case report
(441) | Chaouat M, Bonnet F, Seroussi D, Smarrito S, Mimoun M. Topical negative pressure for the treatment of complex cavity wounds associated with osteitis. J Wound Care 2006 Jul;15(7):292-4. | | | ✓ | Fewer than five patients
(442) | Chariker ME, Jeter KF, Tintle TE, Bottsford JE. Effective management of incisional and cutaneous fistulae with close suction wound drainage. Contemp Surg 1989 Jun;34:59-63. | | | ✓ | Homemade device
(443) | Chave H, Ahmed S, Fu B, Webber J, Banwell P, Tiernan E. Salvage of infected dermal collagen implants with topical negative pressure therapy. J Wound Care 2006 Apr;15(4):156-8. | | | ✓ | Case report
(444) | Chen SZ, Li J, Li XY, Xu LS. Effects of Vacuum-assisted Closure on Wound Microcirculation: An Experimental Study. Asian J Surg 2005 Jul;28(3):211-7. | | | ✓ | Animal study
(160) | Chen Y, Almeida AA, Mitnovetski S, Goldstein J, Lowe C, Smith JA. Managing deep sternal wound infections with vacuum-assisted closure. ANZ J Surg 2008 May;78(5):333-6. | ✓ | KQ3
(445) | Chesher E. Use of vacuum-assisted closure in the community. Prim Intent 1998 Feb;6(1):12-15. | | | ✓ | Case report
(446) | Chester DL, Waters R. Adverse alteration of wound flora with topical negative-pressure therapy: a case report. Br J Plast Surg 2002 Sep;55(6):510-1. | | | ✓ | Case report
(447) | Childress B, Stechmiller JK, Schultz GS. Arginine metabolites in wound fluids from pressure ulcers: a pilot study. Biol Res Nurs 2008 Oct;10(2):87-92. | | | ✓ | No relevant outcomes
(448) | Chung CJ, David LR, Morykwas M, Argenta L. Case review: management of life-threatening sepsis and wound healing in a Klippel-Trenaunay patient using serial surgical debridements and vaccum-assisted closure. Eur J Plastic Surg 2003 Jul;26(4):214-16. | | | ✓ | Case report
(379) | Clare MP, Fitzgibbons TC, McMullen ST, Stice RC, Hayes DF, Henkel L. Experience with the Vacuum Assisted Closure negative pressure technique in the treatment of non-healing diabetic and dysvascular wounds. Foot Ankle Int 2002 Oct1;23(10):896-901. | ✓ | KQ3
(449) | Coggrave M, West H, Leonard B. Topical negative pressure for pressure ulcer management. Br J Nurs 2002 Mar;11(6 Suppl):S29-36. | | | ✓ | Case reports
(450) | Colwell AS, Donaldson MC, Belkin M, Orgill DP. Management of Early Groin Vascular Bypass Graft Infections with Sartorius and Rectus Femoris Flaps. Ann Plast Surg 2004;52(1):49-53. | | | ✓ | Not relevant - focus on effectiveness of muscle flaps
(185) | Contractor D, Amling J, Brandoli C, Tosi LL. Negative pressure wound therapy with reticulated open cell foam in children: an overview. J Orthop Trauma 2008 Nov-Dec;22(10 Suppl):S167-76. | ✓ | Previous Systematic Reviews
(451) | Copson D. Topical negative pressure and necrotising fasciitis. Nurs Stand 2003 Oct 22-28;18(6):71-4, 76, 78 passim. | | | ✓ | Case report
(356) | Cothren CC, Moore EE, Johnson JL, Moore JB, Burch JM. One hundred percent fascial approximation with sequential abdominal closure of the open abdomen. Am J Surg 2006 Aug;192(2):238-42. | ✓ | KQ3
(373) | Cowan KN, Teague L, Sue SC, Mahoney JL. Vacuum-assisted wound closure of deep sternal infections in high-risk patients after cardiac surgery. Ann Thorac Surg 2005 Dec;80(6):2205-12. | ✓ | KQ3
(452) | Cravero L, Taveggia A, Boriani F, Bruschi S, Boriani F. Osteomyelitis: A possible diagnostic mistake after vacuum-assisted therapy. J Plast Reconstr Aesthet Surg 2006;59(11):1250-1. | | | ✓ | Case report
(453) | Cresti S, Ouaissi M, Sielezneff I, Chaix JB, Pirro N, Berthet B, Consentino B, Sastre B. Advantage of vacuum assisted closure on healing of wound associated with omentoplasty after abdominoperineal excision: a case report. World J Surg Oncol 2008 Dec 23;6(1):136. | | | ✓ | Case reports
(454) | Cro C, George KJ, Donnelly J, Irwin ST, Gardiner KR. Vacuum assisted closure system in the management of enterocutaneous fistulae. Postgrad Med J 2002 Jun;78(920):364-5. | | | ✓ | Fewer than five patients
(455) | Crumbley DR, Perciballi JA. Negative pressure wound therapy in a contaminated soft-tissue wound. J Wound Ostomy Continence Nurs 2007 Sep-Oct;34(5):507-12. | | | ✓ | No abstract available
(456) | Culliford AT 4th, Spector JA, Levine JP. A novel technique for vacuum assisted closure device application in noncontiguous wounds. J Plast Reconstr Aesthet Surg 2007;60(1):99-100. | | | ✓ | Case report
(457) | Dakin J, Thompson S. Use of topical negative pressure therapy with an abdominal dressing in management of a laparostomy. J Wound Care 2006 Oct;15(9):386-8. | | | ✓ | Case report
(458) | Datiashvili RO, Knox KR. Negative pressure dressing: an alternative to free tissue transfers?. Wounds 2005 Aug;17(8):206-12. | | | ✓ | Narrative
(459) | Davis L, Barker A. Coordination and management of TNP from acute to primary care: overcoming the issues. J Wound Care 2006 Apr;15(4):169-71. | | | ✓ | Narrative
(460) | Davydov IuA, Malafeeva EV, Smirnov AP, Flegontov VB. Vacuum therapy in the treatment of suppurative lactation mastitis. Vestn Khir Im I I Grek 1986 Nov;137(11):66-70. | | | ✓ | Not a NPWT device
(461) | Davydov YA, Larichev AB, Abramov AY, Menkov KG. Concepts for clinical biological management of the wound process in the treatment of purulent wounds using vacuum therapy] translated from Russian. Vestnik Khirurgii 1991 Feb;132-5. (Rus). | | | ✓ | Not a NPWT device
(462) | Davydov YA, Larichev AB, Menlov KG. The bacteriological and cytological assessment of vacuum therapy of purulent wounds] translated from Russian. Vestnik Khirurgii 1988 Oct;48-52. | | | ✓ | Not a NPWT device
(460) | Davydov YA, Malafeeva EV, Smirnov AP, Flegontov VB. [Vacuum therapy in the treatment of purulent lactation mastitis] translated from Russian. Vestnik Khirurgii 1986 Sep;66-70. (Rus). | | | ✓ | Not a NPWT device
(463) | de Geus HR, van der Klooster JM. Vacuum-assisted closure in the treatment of large skin defects due to necrotizing fasciitis. Intensive Care Med 2005 Apr;31(4):601. | | | ✓ | Case report
(464) | de la Torre JI, Martin SA, Oberheu AM, Vasconez LO. Healing a wound with an exposed Herrington rod: a case study. Ostomy Wound Manage 2002 May;48(5):18-9. | | | ✓ | Case report
(167) | De Lange MY, Schasfoort RA, Obdeijn MC, Van Der Werff JFA, Nicolai JPA. Vacuum-assisted closure: Indications and clinical experience. Eur J Plastic Surg 2000 May;23(4):178-82. | ✓ | KQ3
(8) | de Leon J. Negative pressure wound therapy in pressure ulcer management. Ostomy Wound Manage 2005 Feb;51(2A Suppl):3-8. | | | ✓ | Case reports
(465) | de Weerd L, Kjaeve J, Aghajani E, Elvenes OP. The sandwich design: a new method to close a high-output enterocutaneous fistula and an associated abdominal wall defect. Ann Plast Surg 2007 May;58(5):580-3. | | | ✓ | Case report
(27) | Dedmond BT, Kortesis B, Punger K, Simpson J, Argenta J, Kulp B, Morykwas M, Webb LX. The use of negative-pressure wound therapy (NPWT) in the temporary treatment of soft-tissue injuries associated with high-energy open tibial shaft fractures. J Orthop Trauma 2007 Jan;21(1):11-7. | ✓ | KQ3
(222) | Dedmond BT, Kortesis B, Punger K, Simpson J, Argenta J, Kulp B, Morykwas M, Webb LX. Subatmospheric pressure dressings in the temporary treatment of soft tissue injuries associated with type III open tibial shaft fractures in children. J Pediatr Orthop 2006 Nov;26(6):728-32. | | | ✓ | Duplicate study(27)
(466) | Dee A. The successful management of a dehisced surgical wound with TNP following femoropopliteal bypass. J Wound Care 2007 Jan;16(1):42-4. | | | ✓ | Case report
(157) | DeFranzo AJ, Argenta LC, Marks MW, Molnar JA, David LR, Webb LX, Ward WG, Teasdall RG. The use of vacuum-assisted closure therapy for the treatment of lower-extremity wounds with exposed bone. Plast Reconstr Surg 2001 Oct;108(5):1184-91. | ✓ | KQ3
(467) | DeFranzo AJ, Marks MW, Argenta LC, Genecov DG. Vacuum-assisted closure for the treatment of degloving injuries. Plast Reconstr Surg 1999 Dec;104(7):2145-8. | | | ✓ | Fewer than five patients
(156) | DeFranzo AJ, Pitzer K, Molnar JA, Marks MW, Chang MC, Miller PR, Letton RW, Argenta LC. Vacuum-assisted closure for defects of the abdominal wall. Plast Reconstr Surg 2008 Mar;121(3):832-9. | ✓ | KQ3
(468) | Demaria R, Giovannini UM, Teot L, Chaptal PA. Using VAC to treat a vascular bypass site infection. J Wound Care 2001 Feb;10(2):12-3. | | | ✓ | Case report
(145) | Demaria RG, Giovannini U, Teot L, Frapier JM, Albat B. A new technique for the treatment of delayed sternotomy healing: the vacuum therapy. Heart Surg Forum 2003;6(5):434-7. | ✓ | KQ3
(135) | Denzinger S, Lubke L, Roessler W, Wieland WF, Kessler S, Burger M. Vacuum-assisted closure versus conventional wound care in the treatment of wound failures following inguinal lymphadenectomy for penile cancer: a retrospective study. Eur Urol 2007 May;51(5):1320-5. | ✓ | KQ1, KQ3
(135) | Denzinger S, Lubke L, Roessler W, Wieland WF, Kessler S, Burger M. Vacuum-assisted closure versus conventional wound care in the treatment of wound failures following inguinal lymphadenectomy for penile cancer: a retrospective study. Eur Urol 2007 May;51(5):1320-5. | ✓ | KQ1, KQ3
(469) | Derrick KL, Norbury K, Kieswetter K, Skaf J, McNulty AK. Comparative analysis of global gene expression profiles between diabetic rat wounds treated with vacuum-assisted closure therapy, moist wound healing or gauze under suction. Int Wound J 2008 Dec;5(5):615-24. | | | ✓ | Animal study
(382) | Deva AK, Buckland GH, Fisher E, Liew SC, Merten S, McGlynn M, Gianoutsos MP, Baldwin MA, Lendvay PG. Topical negative pressure in wound management. Med J Aust 2000 Aug 7;173(3):128-31. | ✓ | KQ3
(470) | Deva AK, Siu C, Nettle WJ. Vacuum-assisted closure of a sacral pressure sore. J Wound Care 1997 Jul;6(7):311-2. | | | ✓ | Case report
(471) | Dickie SR, Dorafshar AH, Song DH. Definitive closure of the infected median sternotomy wound: a treatment algorithm utilizing vacuum-assisted closure followed by rigid plate fixation. Ann Plast Surg 2006 Jun;56(6):680-5. | | | ✓ | Algorithm
(472) | Dieu T, Leung M, Leong J, Morrison W, Cleland H, Archer B, Oppy A. Too much vacuum-assisted closure. ANZ J Surg 2003 Dec;73(12):1057-60. | | | ✓ | Narrative
(473) | Dobke MK, Nguyen D, Trott SA. A novel approach to acute infection of the glenohumeral joint following rotator cuff repair? A case series. Wounds 2005 Jun;17(6):137-40. | | | ✓ | No relevant outcomes
(129) | Domkowski PW, Smith ML, gonyon Jr DL, Drye C, Wooten MK, Levin LS, wolfe WG. Evaluation of vacuum-assisted closure in the treatment of poststernotomy mediastinitis. J Thorac Cardiovasc Surg 2003 Aug 1;126(2):386-90. | ✓ | KQ1, KQ3
(474) | Donovan DJ, Person DA. Giant eccrine adenocarcinoma of the scalp with intracranial invasion: resection and reconstruction using a vacuum-assisted closure device: technical case report. Neurosurgery 2006 Apr;58(4 Suppl 2):ONS-E371; discussion ONS. | | | ✓ | Case report
(475) | Dosluoglu HH, Schimpf DK, Schultz R, Cherr GS. Preservation of infected and exposed vascular grafts using vacuum assisted closure without muscle flap coverage. J Vasc Surg 2005 Nov;42(5):989-92. | | | ✓ | Fewer than five patients
(128) | Doss M, Martens S, Wood JP, Wolff JD, Baier C, Moritz A. Vacuum-assisted suction drainage versus conventional treatment in the management of poststernotomy osteomyelitis. Eur J Cardiothorac Surg 2002 Dec 1;22(6):934-8. | ✓ | KQ1, KQ3
(476) | Dunbar A, Bowers DM, Holderness H Jr. Silicone net dressing as an adjunct with negative pressure wound therapy. Ostomy Wound Manage 2005 Apr;51(4):18, 20. | | | ✓ | Case report
(477) | Durai R, Hoque H, Davies TW. ‘Indirect VAC’: a novel technique of applying vacuum-assisted closure dressing. J Perioper Pract 2008 Oct;18(10):437-9. | | | ✓ | Narrative
(478) | Duxbury MS, Finlay IG, Butcher M, Lambert AW. Use of a vacuum assisted closure device in pilonidal disease. J Wound Care 2003 Oct;12(9):355. | | | ✓ | Case report
(479) | Easterlin B, Bromberg W, Linscott J. A novel technique of vacuum assisted wound closure that functions as a delayed primary closure. Wounds 19(12):331-3. | | | ✓ | Narrative
(480) | Eberlein T, Fendler H. Case studies of Prospera NPWT.Available: http://www.prospera-npwt.com/clincal_references.htm. | | | ✓ | Case reports
(481) | Edwards AR. Vacuum device closes gap in wound care. Biomechanics 2001 Dec;8(12):27-34. | | | ✓ | Narrative
(226) | Eginton MT, Brown KR, Seabrook GR, Towne JB, Cambria RA. A prospective randomized evaluation of negative-pressure wound dressings for diabetic foot wounds. Ann Vasc Surg 2003 Nov;17(6):645-9. | | | ✓ | Fewer than five patients
(482) | Emohare O, Kowal-Vern A, Wiley D, Latenser BA. Vacuum-assisted closure use in calciphylaxis. J Burn Care Rehabil 2004 Mar-Apr;25(2):161-4. | | | ✓ | Fewer than five patients
(483) | Ennis WJ. (President, Association for the Advancement of Wound Care). Personal communication. 2009 Feb 5. 2 p. | | | ✓ | Personal communication
(484) | Erba P, Rieger UM, Pierer G, Kalbermatten DF. Vacuum-assisted closure (VAC) for venous congestion of the nipple-areola complex. J Plast Reconstr Aesthet Surg 2008 Jul;61(7):852-4. | | | ✓ | Case report
(485) | Erdmann D, Drye C, Heller L, Wong MS, Levin SL. Abdominal wall defect and enterocutaneous fistula treatment with the Vacuum-Assisted Closure (V.A.C.) system. Plast Reconstr Surg 2001 Dec;108(7):2066-8. | | | ✓ | Case report
(486) | Espensen EH, Nixon BP, Lavery LA, Armstrong DG. Use of subatmospheric (VAC) therapy to improve bioengineered tissue grafting in diabetic foot wounds. J Am Podiatr Med Assoc 2002 Jul-Aug;92(7):395-7. | | | ✓ | Narrative
(487) | Evans D, Land L. Topical negative pressure for treating chronic wounds: a systematic review. Br J Plast Surg 2001 Apr;54(3):238-42. | | | ✓ | (169)update
(786) | Evidence summary. San Antonio (TX): Kinetic Concepts, Inc.; 19 p. | | | ✓ | Narrative – individual studies captured in bibliography
(488) | Ferdinando E, Guerin L, Jervis AO, Obidigbo H. Negative-pressure wound therapy and external fixation for infection and hematoma after hallux abducto valgus surgery. J Am Podiatr Med Assoc 2007 Sep-Oct;97(5):410-4. | | | ✓ | Case report
(489) | Ferreira MC, Wada A, Tuma Jr P. The vacuum assisted closure of complex wounds: report of 3 cases. Rev Hosp Clin Fac Med Sao Paulo 2003 Jul-Aug;58(4):227-30. | | | ✓ | Fewer than five patients
(83) | Ferron G, Garrido I, Martel P, Gesson-Paute A, Classe JM, Letourneur B, Querleu D. Combined laparoscopically harvested omental flap with meshed skin grafts and vacuum-assisted closure for reconstruction of complex chest wall defects. Ann Plast Surg 2007 Feb;58(2):150-5. | ✓ | KQ3 | | | ✓
(490) | Fette A. Treatment of pressure ulcers with topical negative pressure versus traditional wound management methods: a research sampler. Plast Surg Nurs 2005 Oct-Dec;25(4):176-80. | | | ✓ | Narrative
(491) | Fife CE, Otto G, Walker D, Turner T, Smith L. Healing dehisced surgical wounds with negative pressure wound therapy. Ostomy Wound Manage 2004 Apr;50(4A Suppl):28-31. | | | ✓ | Narrative
(492) | Fischer JE. A cautionary note: the use of vacuum-assisted closure systems in the treatment of gastrointestinal cutaneous fistula may be associated with higher mortality from subsequent fistula development. Am J Surg 2008 Jul;196(1):1-2. | | | ✓ | Narrative
(168) | Fisher A, Brady B. Vacuum assisted wound closure therapy. Issues Emerg Health Technol 2003 Mar;(44):1-6. | ✓ | Previous Systematic Reviews
(493) | Fitzmaurice M, Lawson D, Friedman H. A novel approach for the application of the vacuum assisted closure device to the difficult anatomy. J Plast Reconstr Aesthet Surg 2006;59(11):1249-50. | | | ✓ | Case report
(494) | Flack S, Apelqvist J, Keith M, Trueman P, Williams D. An economic evaluation of VAC therapy compared with wound dressings in the treatment of diabetic foot ulcers. J Wound Care 2008 Feb;17(2):71-8. | | | ✓ | Cost analysis
(495) | Fleck T, Gustafsson R, Harding K, Ingemansson R, Lirtzman MD, Meites HL, Moidl R, Price P, Ritchie A, Salazar J, Sjogren J, Song DH, Sumpio BE, Toursarkissian B, Waldenberger F, Wetzel-Roth W. The management of deep sternal wound infections using vacuum assisted closure (V.A.C.) therapy. Int Wound J 2006 Dec;3(4):273-80. | | | ✓ | Narrative
(362) | Fleck T, Kickinger B, Moidl R, Waldenberger F, Wolner E, Grabenwoger M, Wisser W. Management of open chest and delayed sternal closure with the vacuum assisted closure system: Preliminary experience. Interact Cardiovasc Thorac Surg 2008 Oct;7(5):801-4. | ✓ | KQ3
(496) | Fleck T, Moidl R, Giovanoli P, Aszmann O, Bartunek A, Blacky A, Grabenwoger M, Wolner E. A conclusion from the first 125 patients treated with the vacuum assisted closure system for postoperative sternal wound infection. Interact Cardiovasc Thorac Surg 2006 Apr;5(2):145-8. | | | ✓ | Not relevant -focus on management of infection
(497) | Fleck T, Simon P, Burda G, Wolner E, Wollenek G. Vacuum assisted closure therapy for the treatment of sternal wound infections in neonates and small infants. Interact Cardiovasc Thorac Surg 2006 Jun;5(3):285-8. | | | ✓ | Fewer than 5 patients
(380) | Fleck TM, Fleck M, Moidl R, Czerny M, Koller R, Giovanoli P, Hiesmayer MJ, Zimpfer D, Wolner E, Grabenwoger M. The vacuum-assisted closure system for the treatment of deep sternal wound infections after cardiac surgery. Ann Thorac Surg 2002 Nov 1;74(5):1596-1600. | ✓ | KQ3
(498) | Fleck TM, Koller R, Giovanoli P, Moidl R, Czerny M, Fleck M, Wolner E, Grabenwoger M. Primary or delayed closure for the treatment of poststernotomy wound infections. Ann Plast Surg 2004 Mar;52(3):310-4. | | | ✓ | Not relevant
(499) | Fleischmann W, Strecker W, Bombelli M, Kinzl L. [Vacuum sealing as treatment of soft tissue damage in open fractures]. Unfallchirurgie 1993;96(9):488-92. | | | ✓ | Narrative
(232) | Foo A, Kin-Sze Chong A, Shenthilkumar N. The ‘hand-in-gloves’ technique: vacuum-assisted closure dressing for multiple finger wounds. J Plast Reconstr Aesthet Surg 2008 Sep 5; Epub ahead of print. | | | ✓ | Case report
(110) | Ford CN, Reinhard ER, Yeh D, Syrek D, De Las Morenas A, Bergman SB, Williams S, Hamori CA. Interim analysis of a prospective, randomized trial of vacuum-assisted closure versus the Healthpoint system in the management of pressure ulcers. Ann Plast Surg 2002 Jul;49(1):55-61; discussion 61. | ✓ | KQ1,KQ3
(500) | Ford SJ, Rathinam S, King JE, Vaughan R. Tuberculous osteomyelitis of the sternum: successful management with debridement and vacuum assisted closure. Eur J Cardiothorac Surg 2005 Oct;28(4):645-7. | | | ✓ | Case report
(501) | Ford-Dunn S. Use of vacuum assisted closure therapy in the palliation of a malignant wound. Palliat Med 2006 Jun;20(4):477-8. | | | ✓ | Case report
(502) | Fox A, Tadros A, Perks AG. An unusual complication of Vacuum Assisted Closure in the treatment of a pressure ulcer. J Wound Care 2004 Sep;13(8):344-5. | | | ✓ | Case report
(503) | Fox MP, Fazal MA, Ware HE. Vacuum assisted wound closure. A new method for control of wound problems in total knee arthroplasty. J Bone Joint Surg Br 2000 Jan;82-B(Suppl 1):19. | | | ✓ | Fewer than 5 patients
(504) | Fredeking AE, Silverman RA. Successful treatment of trigeminal trophic syndrome in a 6-year-old boy with negative pressure wound therapy. Arch Dermatol 2008 Aug;144(8):984-6. | | | ✓ | Case report
(505) | Friedman T, Westreich M, Shalom A. Vacuum-assisted closure treatment complicated by anasarca. Ann Plast Surg 2005 Oct;55(4):420-1. | | | ✓ | Case report
(506) | Froiland KG. Nursing interventions in oncology complex wound care: use of negative pressure therapy for wound healing in an ovarian cancer patient. [internet]. [accessed 2001 Oct 23]. Available: http://www.thecancergroup.org/kathrynfroiland.htm. | | | ✓ | Case report
(787) | Fruchterman T. (Senior Vice President, Research & Development & Chief Technology Officer). Kinetic Concepts, Inc. submission of information for use in review of Negative Pressure Wound Therapy (NPWT). 2009 Feb 4. 3 p. | | | ✓ | Cover letter
(507) | Frykberg F. When is NPWT appropriate for amputation wounds?. APMA News 2005 May;26(5 Suppl):20-3. | | | ✓ | Narrative
(508) | Frykberg RG, Williams DV. Negative-pressure wound therapy and diabetic foot amputations: a retrospective study of payer claims data. J Am Podiatr Med Assoc 2007 Sep-Oct;97(5):351-9. | | | ✓ | Cost analysis
(23) | Fuchs U, Zittermann A, Stuettgen B, Groening A, Minami K, Koerfer R. Clinical outcome of patients with deep sternal wound infection managed by vacuum-assisted closure compared to conventional therapy with open packing: a retrospective analysis. Ann Thorac Surg 2005 Feb;79(2):526-31. | ✓ | KQ1,KQ3
(509) | Gabriel A, Gollin G. Management of complicated gastroschisis with porcine small intestinal submucosa and negative pressure wound therapy. J Pediatr Surg 2006 Nov;41(11):1836-40. | | | ✓ | Animal study
(383) | Gabriel A, Heinrich C, Shores J, Cho D, Baqai W, Moores D, Miles D, Gupta S. Outcomes of vacuum-assisted for the treatment of wounds in a paediatric population: case series of 58 patients. J Plast Reconstr Aesthet Surg 2008 Oct 2;Epub ahead of print. | ✓ | KQ3
(510) | Gabriel A, Heinrich C, Shores JT, Baqui WK, Rogers FR, Gupta S. Reducing bacterial bioburden in infected wounds with vacuum assisted closure and a new silver dressing - a pilot study. Wounds 2006 Sep;18(9):245-55. | | | ✓ | Duplicate study(383)
(339) | Gabriel A, Shores J, Heinrich C, Baqai W, Kalina S, Sogioka N, Gupta S. Negative pressure wound therapy with instillation: A pilot study describing a new method for treating infected wounds. Int Wound J 2008 Jun;5(3):399-413. | ✓ | KQ1, KQ3
(86) | Garner GB, Ware DN, Cocanour CS, Duke JH, McKinley BA, Kozar RA, Moore FA. Vacuum-assisted wound closure provides early fascial reapproximation in trauma patients with open abdomens. Am J Surg 2001 Dec;182(6):630-8. | ✓ | KQ3 | | | ✓
(154) | Gdalevitch P, Afilalo J, Lee C. Predictors of vacuum-assisted closure failure of sternotomy wounds. J Plast Reconstr Aesthet Surg 2008 Nov 21;Epub ahead of print. | ✓ | KQ3
(511) | Geller S. A closer look at NPWT in the wound care clinic setting. APMA News 2005 May;26(5 Suppl):43-5. | | | ✓ | Narrative
(512) | Geller S. How to use NPWT successfully in the home care setting. APMA News 2005 May;26(5 Suppl):33-4. | | | ✓ | Narrative
(513) | Geller SM, Longton JA. Ulceration of pyoderma gangrenosum treated with negative pressure wound therapy. J Am Podiatr Med Assoc 2005 Mar-Apr;95(2):171-4. | | | ✓ | Case report
(131) | Genecov DG, Schneider AM, Morykwas MJ, Parker D, White WL, Argenta LC. A controlled subatmospheric pressure dressing increases the rate of skin graft donor site reepithelialization. Ann Plast Surg 1998 Mar;40(3):219-25. | ✓ | KQ1, KQ3, Previous Systematic Reviews
(514) | Gerry R, Kwei S, Bayer L, Breuing KH. Silver-impregnated vacuum-assisted closure in the treatment of recalcitrant venous stasis ulcers. Ann Plast Surg 2007 Jul;59(1):58-62. | | | ✓ | Fewer than 5 patients
(515) | Ghersi MM, Ricotti C, Nousari CH, Newman MI. Negative pressure dressing in the management of pyoderma gangrenosum ulcer. Arch Dermatol 2007 Oct;143(10):1249-51. | | | ✓ | Case report
(516) | Gomoll AH, Lin A, Harris MB. Incisional vacuum-assisted closure therapy. J Orthop Trauma 2006 Nov-Dec;20(10):705-9. | | | ✓ | Narrative
(517) | Goverman J, Yelon JA, Platz JJ, Singson RC, Turcinovic M. The "Fistula VAC," a technique for management of enterocutaneous fistulae arising within the open abdomen: report of 5 cases. J Trauma 2006 Feb;60(2):428-31; discussion 431. | | | ✓ | Not relevant
(177) | Gray M, Peirce B. Is negative pressure wound therapy effective for the management of chronic wounds. J Wound Ostomy Continence Nurs 2004 May/June;31(3):101-5. | ✓ | Previous Systematic Reviews
(518) | Greene AK, Puder M, Roy R, Arsenault D, Kwei S, Moses MA, Orgill DP. Microdeformational wound therapy: effects on angiogenesis and matrix metalloproteinases in chronic wounds of 3 debilitated patients. Ann Plast Surg 2006 Apr;56(4):418-22. | | | ✓ | Fewer than 5 patients
(519) | Greer S, Sims CD, Borud L, Thorne C, Kasabian A. The use of a subatmospheric pressure dressing to salvage a septic ankle with concomitant osteomyelitis and avert a free flap. Foot Ankle Int 1997 Sep;18(3):151-6. | | | ✓ | Case report
(520) | Greer SE, Adelman M, Kasabian A, Galiano RD, Scott R, Longaker MT. The use of subatmospheric pressure dressing therapy to close lymphocutaneous fistulae of the groin. Br J Plast Surg 2000 Sep;53(6):484-7. | | | ✓ | Narrative
(521) | Greer SE, Duthie E, Cartolano B, Koehler KM, Maydick-Youngberg D, Longaker MT. Techniques for applying subatmospheric pressure dressing to wounds in difficult regions of anatomy. J Wound Ostomy Continence Nurs 1999 Sep;26(5):250-3. | | | ✓ | Narrative
(522) | Greer SE, Longaker MT, Margiotta M, Mathews AJ, Kasabian A. The use of subatmospheric pressure dressing for the coverage of radial forearm free flap donor-site exposed tendon complications. Ann Plast Surg 1999 Nov;43(5):551-4. | | | ✓ | Narrative
(173) | Gregor S, Maegele M, Sauerland S, Krahn JF, Peinemann F, Lange S. Negative pressure wound therapy: a vacuum of evidence?. Arch Surg 2008 Feb;143(2):189-96. | ✓ | Previous Systematic Reviews
(523) | Grimm A, Dimmler A, Stange S, Labanaris A, Sauer R, Grabenbauer G, Horch RE. Expression of HIF-1 alpha in irradiated tissue is altered by topical negative-pressure therapy. Strahlenther Onkol 2007 Mar;183(3):144-9. | | | ✓ | No relevant outcomes
(524) | Gudbjartsson T, Sigurdsson HK, Sigurdsson E, Kjartansson J. Vacuum-assisted closure for successful treatment of a major contaminated gunshot chest-wound: A case report. Eur J Trauma Emerg Surg 2008 July 25;Epub | | | ✓ | Case report
(525) | Gunn LA, Follmar KE, Wong MS, Lettieri SC, Levin LS, Erdmann D. Management of enterocutaneous fistulae using negative-pressure dressings. Ann Plast Surg 2006 Dec;57(6):621-5. | | | ✓ | Not relevant
(10) | Gupta S, Baharestani M, Baranoski S, de Leon J, Engel SJ, Mendez-Eastman S, Niezgoda JA, Pompeo MQ. Guidelines for managing pressure ulcers with negative pressure wound therapy. Adv Skin Wound Care 2004 Nov-Dec;17(Suppl 2):1-16. | | | ✓ | Guideline
(236) | Gupta S, Cho T. A literature review of negative pressure wound therapy. Ostomy Wound Manage 2004 Apr;50(4A Suppl):6-8. | | | ✓ | Duplicate study(188)
(526) | Gupta S, Gabriel A, Shores J. The perioperative use of negative pressure wound therapy in skin grafting. Ostomy Wound Manage 2004 Apr;50(4A Suppl):32-4. | | | ✓ | Narrative
(381) | Gustafsson R, Johnsson P, Algotsson L, Blomquist S, Ingemansson R. Vacuum-assisted closure therapy guided by C-reactive protein level in patients with deep sternal wound infection. J Thorac Cardiovasc Surg 2002 May;123(5):895-900. | ✓ | KQ3
(146) | Gustafsson RI, Sjogren J, Ingemansson R. Deep Sternal Wound Infection: A Sternal-Sparing Technique with Vacuum-Assisted Closure Therapy. Ann Thorac Surg 2003;76(6):2048-2053. | ✓ | KQ3
(527) | Guzzo J, Bluman EM. Technique tip: easing subatmospheric wound dressing application and increasing sponge conformity. Foot Ankle Int 2007 May;28(5):638-9. | | | ✓ | Narrative
(528) | Gwan-Nulla DN, Casal RS. Toxic shock syndrome associated with the use of the vacuum-assisted closure device. Ann Plast Surg 2001 Nov;47(5):552-4. | | | ✓ | Case report
(140) | Ha J, Phillips M. A retrospective review of the outcomes of vacuum-assisted closure therapy in a vascular surgery unit. Wounds 2008 Aug;20(8):221-9. | ✓ | KQ3
(529) | Hallock GG, Cipolle MD, Bradow BP. Enterocutaneous fistula associated with an unrecognized retained vacuum-assisted closure sponge. Plast Reconstr Surg 2008 Aug;122(2):84e-5e. | | | ✓ | Case report
(363) | Hamed O, Muck PE, Smith JM, Krallman K, Griffith NM. Use of vacuum-assisted closure (VAC) therapy in treating lymphatic complications after vascular procedures: new approach for lymphoceles. J Vasc Surg 2008 Dec;48(6):1520-3, 1523.e1-4. | ✓ | KQ3
(530) | Hanasono MM, Skoracki RJ. Securing skin grafts to microvascular free flaps using the vacuum-assisted closure (VAC) device. Ann Plast Surg 2007 May;58(5):573-6. | | | ✓ | Narrative
(531) | Hardcastle MR. The application of negative pressure in wound healing. Prim Intent 1998 Feb;5-10 | | | ✓ | Narrative
(532) | Hardwicke J, Paterson P. A role for vacuum-assisted closure in lower limb trauma: a proposed algorithm. Int J Low Extrem Wounds 2006 Jun;5(2):101-4. | | | ✓ | Narrative
(533) | Harlan JW. Treatment of open sternal wounds with the vacuum- assisted closure system: a safe, reliable method. Plast Reconstr Surg 2002 Feb;109(2):710-2. | | | ✓ | Narrative
(534) | Hartnett JM. Use of vacuum-assisted wound closure in three chronic wounds. J Wound Ostomy Continence Nurs 1998 Nov;25(6):281-90. | | | ✓ | Fewer than five patients
(351) | Helgeson MD, Potter BK, Evans KN, Shawen SB. Bioartificial dermal substitute: A preliminary report on its use for the management of complex combat-related soft tissue wounds. J Orthop Trauma 2007 Jul;21(6):394-9. | ✓ | KQ3
(87) | Heller L, Levin SL, Butler CE. Management of abdominal wound dehiscence using vacuum assisted closure in patients with compromised healing. Am J Surg 2006 Feb;191(2):165-72. | ✓ | KQ3 | | | ✓
(360) | Herscovici Jr D, Sanders RW, Scaduto JM, Infante A, DiPasquale T. Vacuum-assisted wound closure (VAC therapy) for the management of patients with high-energy soft tissue injuries. J Orthop Trauma 2003;17(10):683-8. | ✓ | KQ3
(94) | Hersh RE, Jack JM, Dahman MI, Morgan RF, Drake DB. The vacuum-assisted closure device as a bridge to sternal wound closure. Ann Plast Surg 2001 Mar;46(3):250-4. | ✓ | KQ3 | | | ✓
(535) | Hersh RE, Kaza AK, Long SM, Fiser SM, Drake DB, Tribble CG. A technique for the treatment of sternal infections using the Vacuum Assisted Closure device. Heart Surg Forum 2001;4(3):211-5. | | | ✓ | Narrative
(536) | Heugel JR, Parks KS, Christie SS, Pulito JF, Zegzula DH, Kemalyan NA. Treatment of the exposed achilles tendon using negative pressure wound therapy: a case report. J Burn Care Rehabil 2002 May-Jun;23(3):167-71. | | | ✓ | Case report
(537) | Heuser M, Laabs SO, Plothe KD. Extraperitoneal bladder leakage after provision of topical negative therapy: a case report. J Wound Care 2005 Oct;14(9):406. | | | ✓ | Case report
(538) | Hopf HW, Ueno C, Aslam R, Burnand K, Fife C, Grant L, Holloway A, Iafrati MD, Mani R, Misare B, Rosen N, Shapshak D, Benjamin Slade J Jr, West J, Barbul A. Guidelines for the treatment of arterial insufficiency ulcers. Wound Repair Regen 2006 Nov-Dec;14(6):693-710. | | | ✓ | Guideline
(78) | Horn PL, Ruth B, Kean JR. Use of wound V.A.C. therapy in pediatric patients with infected spinal wounds: a retrospective review. Orthop Nurs 2007 Sep-Oct;26(5):317-22; quiz 323-4. | ✓ | KQ3 | | | ✓
(127) | Huang WS, Hsieh SC, Hsieh CS, Schoung JY, Huang T. Use of vacuum-assisted wound closure to manage limb wounds in patients suffering from acute necrotizing fasciitis. Asian J Surg 2006 Jul;29(3):135-9. | ✓ | Previous Systematic Reviews
(539) | Huljev D, Kucisec-Tepes N. Necrotizing fascilitis of the abdominal wall as a post-surgical complication: a case report. Wounds 2005 Jul;17(7):169-77. | | | ✓ | Case report
(540) | Humburg J, Holzgreve W, Hoesli I. Negative pressure wound therapy in post-cesarian superficial wound disruption: a report of 3 cases. Wounds 2006 Jun;18(6):166-9. | | | ✓ | Fewer than five patients
(242) | Hunter JE, Teot L, Horch R, Banwell PE. Evidence-based medicine: Vacuum-assisted closure in wound care management. Int Wound J 2007 Sep;4(3):256-69. | | | ✓ | Narrative
(541) | Hunter S, Langemo D, Hanson D, Anderson J, Thompson P. The use of negative pressure wound therapy. Adv Skin Wound Care 2007 Feb;20(2):90-5. | | | ✓ | Narrative
(542) | Hutchinson L, Thompson J. Vacuum-assisted closure: a method of facilitating wound healing. World Counc Enteros Ther J 1999 Jul-Sep;19(3):17-21. | | | ✓ | Case reports
(130) | Immer FF, Durrer M, Muhlemann KS, Erni D, Gahl B, Carrel TP. Deep sternal wound infection after cardiac surgery: modality of treatment and outcome. Ann Thorac Surg 2005 Sep;80(3):957-61. | ✓ | KQ1, KQ3, Previous Systematic Reviews
(543) | Isago T, Nozaki M, Kikuchi Y, Honda T, Nakazawa H. Effects of different negative pressures on reduction of wounds in negative pressure dressings. J Dermatol 2003 Aug;30(8):596-601. | | | ✓ | Animal study
(91) | Isago T, Nozaki M, Kikuchi Y, Honda T, Nakazawa H. Negative-pressure dressings in the treatment of pressure ulcers. J Dermatol 2003 Apr;30(4):299-305. | ✓ | KQ3 | | | ✓
(544) | Isago T, Nozaki M, Kikuchi Y, Honda T, Nakazawa H. Skin graft fixation with negative-pressure dressings. J Dermatol 2003 Sep;30(9):673-8. | | | ✓ | Narrative
(545) | Iusupov IuN, Epifanov MV. [Active drainage of a wound. Vestn Khir Im I I Grek 1987 Apr;138(4):42-6. | | | ✓ | Animal study
(546) | Jacobs S, Simhaee DA, Marsano A, Fomovsky GM, Niedt G, Wu JK. Efficacy and mechanisms of vacuum-assisted closure (VAC) therapy in promoting wound healing: a rodent model. J Plast Reconstr Aesthet Surg 2008 Jul 8;Epub ahead of print. | | | ✓ | Animal study
(547) | Jehle KS, Rohatgi A. Use of porcine dermal collagen graft and topical negative pressure on infected open abdominal wounds. J Wound Care 2007 Jan;16(1):36-7. | | | ✓ | Case report
(246) | Jeschke MG, Rose C, Angele P, Fuchtmeier B, Nerlich MN, Bolder U. Development of new reconstructive techniques: use of Integra in combination with fibrin glue and negative-pressure therapy for reconstruction of acute and chronic wounds. Plast Reconstr Surg 2004 Feb;113(2):525-30. | | | ✓ | Not relevant – dual therapy
(150) | Jones GA, Butler J, Lieberman I, Schlenk R. Negative-pressure wound therapy in the treatment of complex postoperative spinal wound infections: complications and lessons learned using vacuum-assisted closure. J Neurosurg Spine 2007 May;6(5):407-11. | ✓ | KQ3
(548) | Jones SM, Banwell PE, Shakespeare PG. Advances in wound healing: topical negative pressure therapy. Postgrad Med J 2005 Jun;81(956):353-7. | | | ✓ | Narrative
(247) | Jones SM, Banwell PE, Shakespeare PG. Interface dressings influence the delivery of topical negative-pressure therapy. Plast Reconstr Surg 2005 Sep 15;116(4):1023-8. | | | ✓ | Healthy volunteers
(113) | Joseph E, Hamori CA, Bergman S, Roaf E, Swann NF, Anastasi GW. A prospective, randomized trial of vacuum-assisted closure versus standard therapy of chronic non-healing wounds. Wounds 2000;12(3):60-7. Also available: http://www.medscape.com/viewarticle/407550_print. | ✓ | KQ1, KQ3
(549) | Josty IC, Ramaswamy R, Laing JH. Vaccum assisted closure: an alternative strategy in the management of degloving injuries of the foot. Br J Plast Surg 2001 Jun;54(4):363-5. | | | ✓ | Case report
(550) | Kadohama T, Akasaka N, Nagamine A, Nakanishi K, Kiyokawa K, Goh K, Sasajima T. Vacuum-assisted closure for pediatric post- sternotomy mediastinitis: are low negative pressures sufficient. Ann Thorac Surg 2008 Mar;85(3):1094-6. | | | ✓ | Case reports
(343) | Kamolz LP, Andel H, Haslik W, Winter W, Meissl G, Frey M. Use of subatmospheric pressure therapy to prevent burn wound progression in human: first experiences. Burns 2004 May;30(3):253-8. | ✓ | KQ1, KQ3
(25) | Kanakaris NK, Thanasas C, Keramaris N, Kontakis G, Granick MS, Giannoudis PV. The efficacy of negative pressure wound therapy in the management of lower extremity trauma: Review of clinical evidence. Injury 2007;38:S8-S10,S11-S17. | ✓ | Previous Systematic Reviews
(551) | Kang GC, Yam A. Vacuum-assisted closure of a large palmar defect after debriding a midpalmar tuberculous abscess. Int Wound J 2008 Mar;5(1):45-8. | | | ✓ | Case report
(552) | Kaplan M, Banwell P, Orgill DP, Ivatury RR, Demetriades D, Moore FA, Miller P, Nicholas J, Henry S. Guidelines for the management of the open abdomen. Wounds 2005 Oct;17(Suppl 1):S1-S24. | | | ✓ | Guideline
(553) | Kaplan M. Abdominal compartment syndrome. Ostomy Wound Manage 2004 Apr;50(4A Suppl):20-1. | | | ✓ | Case report
(554) | Kaplan M. Managing the open abdomen. Ostomy Wound Manage 2004 Jan;50(1A Suppl):C2, 1-8, quiz. | | | ✓ | Narrative
(555) | Kaplan M. Negative pressure wound therapy in the management of abdominal compartment syndrome. Ostomy Wound Manage 2004 Nov;50(11A Suppl):20S-25S. | | | ✓ | Case reports
(556) | Kaplan M. Negative pressure wound therapy in the management of abdominal compartment syndrome. Ostomy Wound Manage 2005 Feb;51(2A Suppl):29-35. | | | ✓ | Narrative
(557) | Kaufman MW, Pahl DW. Vacuum-assisted closure therapy: wound care and nursing implications. Dermatol Nurs 2003 Aug;15(4):317-20, 323-5; quiz 326. | | | ✓ | Narrative
(788) | KCI, Inc. ongoing clinical trials. San Antonio (TX): Kinetic Concepts, Inc.; 1 p. | | | ✓ | List of six ongoing trials evaluating protein profiling (k=2), gene expression (k=2), and markers of cellular energetics (k=2)
(789) | KCI, Inc. referenced data on file. San Antonio (TX): Kinetic Concepts, Inc.; 1 p. | | | ✓ | List of two in vitro studies
(790) | KCI, Inc. unpublished clinical trials. San Antonio (TX): Kinetic Concepts, Inc.; 2 p. | | | ✓ | Not relevant - trials discontinued
(558) | Kendrick AS, Chase CW. Salvage of an infected breast tissue expander with an implant sizer and negative pressure wound management. Plast Reconstr Surg 2008 Mar;121(3):138e-139e. | | | ✓ | Case report
(559) | Kennedy A, Van Zant RS. Diverse applications of negative pressure wound therapy: a multiple case report. Physiother Theory Pract 2006 Apr;22(2):83-90. | | | ✓ | Case reports
(560) | Kilbride KE, Cooney DR, Custer MD. Vacuum-assisted closure: A new method for treating patients with giant omphalocele. J Pediatr Surg 2006 Jan;41(1):212-5. | | | ✓ | Fewer than five patients
(561) | Kilpadi D, Stechmiller J, Childress B, Cowan L, Comerio M, Kieswetter K, Schultz G. Composition of wound fluid from pressure ulcers treated with negative pressure wound therapy using VAC therapy in home health or extend care patients: a pilot study. Wounds 2006;18(5):119-26. | | | ✓ | No relevant outcomes
(562) | Kilpadi DV, Feeley TD, Kiel JW. V.A.C. Therapy normalizes vascular response of injured tissue in full-thickness wounds in rabbits. Ann Plast Surg 2007 May;58(5):555-60. | | | ✓ | Animal study
(251) | Kim EK, Hong JP. Efficacy of negative pressure therapy to enhance take of 1-stage allodermis and a split-thickness graft. Ann Plast Surg 2007 May;58(5):536-40. | | | ✓ | Homemade device
(563) | Kirby JP, Fantus RJ, Ward S, Sanchez O, Walker E, Mellett MM, Maltz SB, Lerner TT. Novel uses of a negative-pressure wound care system. J Trauma 2002 Jul;53(1):117-21. | | | ✓ | Narrative
(564) | Klayman MH, Trowbridge CC, Stammers AH, Wolfgang GL, Zijerdi DA, Bitterly TJ. Autologous platelet concentrate and vacuum-assisted closure device use in a nonhealing total knee replacement. J Extra Corpor Technol 2006 Mar;38(1):44-7. | | | ✓ | Case report
(565) | Kloth LC. 5 questions-and answers-about negative pressure wound therapy. Adv Skin Wound Care 2002 Sep-Oct;15(5):226-9. | | | ✓ | Narrative
(566) | Koehler C, Niederbichler AD, Jung FJ, Scholz T, Labler L, Perez D, Jandali A, Comber M, Kuenzi W, Wedler V. Wound therapy using the vacuum-assisted closure device: clinical experience with novel indications. J Trauma 2008 Sep;65(3):722-31; discussion 731. | | | ✓ | No abstract available
(567) | Kopp J, Kneser U, Bach AD, Horch RE. Buried chip skin grafting in neuropathic diabetic foot ulcers following vacuum-assisted wound bed preparation: enhancing a classic surgical tool with novel technologies. Int J Low Extrem Wounds 2004 Sep;3(3):168-71. | | | ✓ | Narrative
(568) | Kopp J, Strnad V, Bach AD, Sauer R, Horch RE. Vacuum application increases therapeutic safety and allows intensified local radiation treatment of malignant soft-tissue tumors. Strahlenther Onkol 2005 Feb;181(2):124-30. | | | ✓ | Fewer than five patients
(340) | Korber A, Franckson T, Grabbe S, Dissemond J. Vacuum assisted closure device improves the take of mesh grafts in chronic leg ulcer patients. Dermatology 2008;216(3):250-6. | ✓ | KQ1, KQ3
(569) | Kordasiewicz LM, Schultz RO. A paraplegic with stage IV pressure ulcers: risk factors and wound care. J Wound Ostomy Continence Nurs 2003 Mar;30(2):84-9. | | | ✓ | Case report
(570) | Kostiuchenok BM, Kolker II, Karlov VA, Ignatenko SN, Muzykant LI. Vacuum treatment in the surgical management of suppurative wounds. Vestn Khir Im I I Grek 1986 Sep;137(9):18-21. | | | ✓ | Not a NPWT device
(73) | Kotsis T, Lioupis C. Use of vacuum assisted closure in vascular graft infection confined to the groin. Acta Chir Belg 2007 Jan- Feb;107(1):37-44. | ✓ | KQ3 | | | ✓
(571) | Kovacs LH, Kloeppel M, Papadopulos NA, Reeker W, Biemer E. Necrotizing fasciitis. Ann Plast Surg 2001 Dec;47(6):680-2. | | | ✓ | Case report
(253) | Krasner DL. Managing wound pain in patients with vacuum-assisted closure devices. Ostomy Wound Manage 2002 May;48(5):38-43. | | | ✓ | Case report
(572) | Kumar S, O’Donnell ME, Khan K, Dunne G, Carey PD, Lee J. Successful treatment of perineal necrotising fasciitis and associated pubic bone osteomyelitis with the vacuum assisted closure system. World J Surg Oncol 2008;6:67. | | | ✓ | Case report
(364) | Labanaris AP, Polykandriotis E, Horch RE. The effect of vacuum-assisted closure on lymph vessels in chronic wounds. J Plast Reconstr Aesthet Surg 2008 Jun 2;Epub ahead of print. | ✓ | KQ3
(370) | Labler L, Keel M, Trentz O, Heinzelmann M. Wound conditioning by vacuum assisted closure (V.A.C.) in postoperative infections after dorsal spine surgery. Eur Spine J 2006 Sep;15(9):1388-96. | ✓ | KQ3
(71) | Labler L, Keel M, Trentz O. Vacuum-assisted closure (VAC) for temporary coverage of soft-tissue injury in type III open fracture of lower extremities. Eur J Trauma 2004;30(5):305-12. | ✓ | KQ1, KQ3 | | | ✓
(352) | Labler L, Trentz O. The use of vacuum assisted closure (VAC™) in soft tissue injuries after high energy pelvic trauma. Langenbecks Arch Surg 2007 Sep;392(5):601-9. | ✓ | KQ3
(357) | Labler L, Zwingmann J, Mayer D, Stocker R, Trentz O, Keel M. V.A.C. Abdominal Dressing System: A temporary closure for open abdomen. Eur J Trauma 2005 Oct;31(5):488-94. | ✓ | KQ3
(573) | Lam WL, Garrido A, Stanley PR. Use of topical negative pressure in the treatment of chronic osteomyelitis. A case report. J Bone Joint Surg Am 2005 Mar;87(3):622-4. | | | ✓ | Case report
(256) | Lambert KV, Hayes P, McCarthy M. Vacuum assisted closure: a review of development and current applications. Eur J Vasc Endovasc Surg 2005 Mar;29(3):219-26. | | | ✓ | Narrative
(574) | Langley-Hawthorne C. Economics of negative pressure wound therapy. Ostomy Wound Manage 2004 Apr;50(4A Suppl):35-7. | | | ✓ | Narrative
(575) | Laverty D, DeFranzo A. Negative pressure wound therapy in the management of orthopedic wounds. Ostomy Wound Manage 2004 Nov;50(11A Suppl):18S-19S. | | | ✓ | Narrative
(576) | Lavery L. Disease management programs: can they make a difference?. APMA News 2005 May;26(5-Suppl):27-29. | | | ✓ | Narrative
(577) | Lavery L. Treating heel pressure unlcers with NPWT. APMA News 2005 May;26(5-Suppl):13-15. | | | ✓ | Narrative
(257) | Lavery LA, Barnes SA, Keith MS, Seaman JW Jr, Armstrong DG. Prediction of healing for postoperative diabetic foot wounds based on early wound area progression. Diabetes Care 2008 Jan;31(1):26-9. | | | ✓ | Duplicate study(109)
(341) | Lavery LA, Boulton AJ, Niezgoda JA, Sheehan P. A comparison of diabetic foot ulcer outcomes using negative pressure wound therapy versus historical standard of care. Int Wound J 2007 Jun;4(2):103-13. | ✓ | KQ1, KQ3
(578) | Lee AT, Fanton GS, McAdams TR. Acute compartment syndrome of the thigh in a football athlete: a case report and the role of the vacuum-assisted wound closure dressing. J Orthop Trauma 2005 Nov-Dec;19(10):748-50. | | | ✓ | Case report
(374) | Lee SS, Lin SD, Chen HM, Lin TM, Yang CC, Lai CS, Chen YF, Chiu CC. Management of intractable sternal wound infections with topical negative pressure dressing. J Card Surg 2005 May-Jun;20(3):218-22. | ✓ | KQ3
(579) | Leijnen M, Steenvoorde P, van Doorn L, Zeillemaker AM, da Costa SA, Oskam J. Does VAC increase the risk of venous thromboembolism. J Wound Care 2007 May;16(5):211-2. | | | ✓ | No abstract available
(111) | Leininger BE, Rasmussen TE, Smith DL, Jenkins DH, Coppola C. Experience with wound VAC and delayed primary closure of contaminated soft tissue injuries in Iraq. J Trauma 2006 Nov;61(5):1207-11. | ✓ | KQ1, KQ3
(580) | Lemaire V, Brilmaker J, Kerzmann A, Jacquemin D. Treatment of a groin lymphatic fistula with negative pressure wound therapy. Eur J Vasc Endovasc Surg 2008 Oct;36(4):449-51. | | | ✓ | Case report
(581) | Lemmon JA, Ahmad J, Ghavami A, Bidic SM. Vacuum-assisted closure over an external fixation device. Plast Reconstr Surg 2008 Apr;121(4):234e-5e. | | | ✓ | Case report
(582) | Lentz S. Use of the vacuum-assisted closure system in management of the gynecologic surgical wound: a case report. J Pelvic Med Surg 2002 Jan;8(1):53-6. | | | ✓ | Case report
(583) | Levin LS. Principles of definitive soft tissue coverage with flaps. J Orthop Trauma 2008 Nov-Dec;22(10 Suppl):S161-6. | | | ✓ | Narrative
(584) | Liao EC, Breuing KH. Breast mound salvage using vacuum- assisted closure device as bridge to reconstruction with inferolateral AlloDerm hammock. Ann Plast Surg 2007 Aug;59(2):218-24. | | | ✓ | No abstract available
(585) | Lindstedt S, Malmsjo M, Gesslein B, Ingemansson R. Evaluation of continuous and intermittent myocardial topical negative pressure. J Cardiovasc Med (Hagerstown) 2008 Aug;9(8):813-9. | | | ✓ | Animal study
(586) | Lindstedt S, Malmsjo M, Gesslein B, Ingemansson R. Topical negative pressure effects on coronary blood flow in a sternal wound model. Int Wound J 2008 Oct;5(4):503-9. | | | ✓ | Animal study
(587) | Lindstedt S, Malmsjo M, Ingemansson R. Blood flow changes in normal and ischemic myocardium during topically applied negative pressure. Ann Thorac Surg 2007 Aug;84(2):568-73. | | | ✓ | Animal study
(588) | Lindstedt S, Malmsjo M, Ingemansson R. No hypoperfusion is produced in the epicardium during application of myocardial topical negative pressure in a porcine model. J Cardiothorac Surg 2007;2:53. | | | ✓ | Animal study
(589) | Lindstedt S, Malmsjo M, Sjogren J, Gustafsson R, Ingemansson R. Impact of different topical negative pressure levels on myocardial microvascular blood flow. Cardiovasc Revasc Med 2008 Jan-Mar;9(1):29-35. | | | ✓ | Animal study
(590) | Lindstedt S, Paulsson P, Mokhtari A, Gesslein B, Hlebowicz J, Malmsjo M, Ingemansson R. A compare between myocardial topical negative pressure levels of −25 mmHg and −50 mmHg in a porcine model. BMC Cardiovasc Disord 2008;8:14. | | | ✓ | Animal study
(591) | Literature review on Negative pressure wound therapy submission to AHRQ by the Association for the Advancement of Wound Care (AAWC) [unpublished]. 140 p. | | | ✓ | Table of Contents
(259) | Llanos S, Danilla S, Barraza C, Armijo E, Pineros JL, Quintas M, Searle S, Calderon W. Effectiveness of negative pressure closure in the integration of split thickness skin grafts: a randomized, double-masked, controlled trial. Ann Surg 2006 Nov;244(5):700-5. | | | √ | Homemade device
(592) | Loos B, Kopp J, Hohenberger W, Horch RE. Post-malignancy irradiation ulcers with exposed alloplastic materials can be salvaged with topical negative pressure therapy (TNP). Eur J Surg Oncol 2007 Sep;33(7):920-5. | | | ✓ | Fewer than five patients
(593) | Lopez Almodovar LF, Bustos G, Lima P, Canas A, Paredes I, Buendia JA. Transverse plate fixation of sternum: a new sternal-sparing technique. Ann Thorac Surg 2008 Sep;86(3):1016-7. | | | ✓ | Case reports
(365) | Lopez G, Clifton-Koeppel R, Emil S. Vacuum-assisted closure for complicated neonatal abdominal wounds. J Pediatr Surg 2008 Dec;43(12):2202-7. | ✓ | KQ3
(594) | Lynch JB, Laing AJ, Regan PJ. Vacuum-assisted closure therapy: a new treatment option for recurrent pilonidal sinus disease. Report of three cases. Dis Colon Rectum 2004 Jun;47(6):929-32. | | | ✓ | Case reports
(74) | Machen MS. Management of traumatic war wounds using vacuum-assisted closure dressings in an austere environment. Army Med Dept J 2007 Jan-Mar;17-23. | ✓ | KQ3 | | | ✓
(595) | Maguina P, Kalimuthu R. Posterior rectal hernia after vacuum-assisted closure treatment of sacral pressure ulcer. Plast Reconstr Surg 2008 Jul;122(1):46e-47e. | | | ✓ | Case report
(596) | Malli S. Keep a close eye on vacuum-assisted wound closure. Nursing 2005 Jul;35(7):25. | | | ✓ | Case report
(597) | Malmsjo M, Ingemansson R, Sjogren J. Mechanisms governing the effects of vacuum-assisted closure in cardiac surgery. Plast Reconstr Surg 2007 Oct;120(5):1266-75. | | | ✓ | Narrative
(598) | Mandal A, Addison P, Stewart K, Neligan P. Vacuum-assisted closure therapy on pyoderma gangrenosum. J Plast Surg 2006 Apr;28(8):529-31. | | | ✓ | Fewer than five patients
(599) | Mandal A. Role of topical negative pressure in pressure ulcer management. J Wound Care 2007 Jan;16(1):33-5. | | | ✓ | Narrative
(600) | Marathe US, Sniezek JC. Use of the vacuum-assisted closure device in enhancing closure of a massive skull defect. Laryngoscope 2004 Jun;114(6):961-4. | | | ✓ | Case report
(601) | Marsh DJ, Abu-Sitta G, Patel H. The role of vacuum-assisted wound closure in blast injury. Plast Reconstr Surg 2007 May;119(6):1978-9. | | | ✓ | No abstract available
(602) | Matzi V, Lindenmann J, Porubsky C, Neuboeck N, Maier A, Smolle-Juettner FM. Intrathoracic insertion of the VAC device in a case of pleural empyema 20 years after pneumonectomy. Ann Thorac Surg 2007 Nov;84(5):1762-4. | | | ✓ | Not relevant
(120) | McCallon SK, Knight CA, Valiulus JP, Cunningham MW, McCulloch JM, Farinas LP. Vacuum-assisted closure versus saline-moistened gauze in the healing of postoperative diabetic foot wounds. Ostomy Wound Manage 2000 Aug;46(8):28-32, 34. | ✓ | KQ1, KQ3
(142) | McCord SS, Naik-Mathuria BJ, Murphy KM, McLane KM, Gay AN, Bob Basu C, Downey CR, Hollier LH, Olutoye OO. Negative pressure therapy is effective to manage a variety of wounds in infants and children. Wound Repair Regen 2007 May-Jun;15(3):296-301. | ✓ | KQ3
(603) | McEwan W, Brown TL, Mills SM, Muller MJ. Suction dressings to secure a dermal substitute. Burns 2004 May;30(3):259-61. | | | ✓ | Narrative
(604) | McGuinness JG, Winter DC, O’Connell PR. Vacuum-assisted closure of a complex pilonidal sinus. Dis Colon Rectum 2003 Feb 1;46(2):274-6. | | | ✓ | Case report
(605) | McNulty A.K., Schmidt, M., Feeley, Teri, Villaneuva, P., Kieswetter, K. 2009. Effects of negative pressure wound therapy on cellular energetics in fibroblasts grown in a provisional wound (fibrin) matrix [In Press]. Wound Repair Regen | | | ✓ | In vitro
(606) | McNulty AK, Schmidt M, Feeley T, Kieswetter K. Effects of negative pressure wound therapy on fibroblast viability, chemotactic signaling, and proliferation in a provisional wound (fibrin) matrix. Wound Repair Regen 2007 Nov-Dec;15(6):838-46. | | | ✓ | In vitro
(607) | Meara JG, Guo L, Smith JD, Pribaz JJ, Breuing KH, Orgill DP. Vacuum-assisted closure in the treatment of degloving injuries. Ann Plast Surg 1999 Jun;42(6):589-94. | | | ✓ | Narrative
(376) | Mehbod AA, Ogilvie JW, Pinto MR, Schwender JD, Transfeldt EE, Wood KB, Le Huec JC, Dressel T. Postoperative deep wound infections in adults after spinal fusion: Management with vacuum-assisted wound closure. J Spinal Disord Tech 2005;18(1):14-7. | ✓ | KQ3
(608) | Mendez-Eastman S. Give stubborn wounds a helping hand. Nursing Made Incredibly Easy 2007 Sep;5(5):18-20. | | | ✓ | Narrative
(609) | Mendez-Eastman S. Guidelines for using negative pressure wound therapy. Adv Skin Wound Care 2001 Nov-Dec;14(6):314-22; quiz 324-5. | | | ✓ | Guideline
(610) | Mendez-Eastman S. Negative pressure wound therapy. Plast Surg Nurs 1998 Spring;18(1):27-9, 33-7. | | | ✓ | Narrative
(611) | Mendez-Eastman S. New treatment for an old problem: negative-pressure wound therapy. Nursing 2002 May;32(5):58-63; quiz 64. | | | ✓ | Narrative
(612) | Mendez-Eastman S. Use of hyperbaric oxygen and negative pressure therapy in the multidisciplinary care of a patient with nonhealing wounds. J Wound Ostomy Continence Nurs 1999 MAR;26(2):67-76. | | | ✓ | Case report
(375) | Mendonca DA, Cosker T, Makwana NK. Vacuum-assisted closure to aid wound healing in foot and ankle surgery. Foot Ankle Int 2005 Sep;26(9):761-6. | ✓ | KQ3
(143) | Mendonca DA, Drew PJ, Harding KG, Price PE. A pilot study on the effect of topical negative pressure on quality of life. J Wound Care 2007 Feb;16(2):49-53. | ✓ | KQ3
(187) | Mendonca DA, Papini R, Price PE. Negative-pressure wound therapy: a snapshot of the evidence. Int Wound J 2006 Dec;3(4):261-71. | ✓ | Previous Systematic Reviews
(613) | Meyer W, Schmiden, V.Bier’s hyperemic treatment in surgery, medicine and the specialties a manual of it’s practical application. 2nd ed. Philadelphia: W.B. Saunders Company; | | | ✓ | Duplicate study(614)
(614) | Meyer W, Schmieden V. Biers hyperemic treatment. Philadelphia: W.B. Saunders Company; 78-153 p. | | | ✓ | Narrative
(281) | Miller PR, Thompson JT, Faler BJ, Meredith JW, Chang MC. Late fascial closure in lieu of ventral hernia: the next step in open abdomen management. J Trauma 2002 Nov;53(5):843-9. | ✓ | KQ1 | | | ✓
(281) | Miller PR, Thompson JT, Faler BJ, Meredith JW, Chang MC. Late fascial closure in lieu of ventral hernia: the next step in open abdomen management. J Trauma 2002 Nov;53(5):843-9. | | | ✓ | Case report
(615) | Miller Q, Bird E, Bird K, Meschter C, Moulton MJ. Effect of subatmospheric pressure on the acute healing wound. Curr Surg 2004 Mar-Apr;61(2):205-8. | | | ✓ | Animal study
(112) | Moisidis E, Heath T, Boorer C, Ho K, Deva AK. A prospective, blinded, randomized, controlled clinical trial of topical negative pressure use in skin grafting. Plast Reconstr Surg 2004 Sep 15;114(4):917-22. | ✓ | KQ1,KQ3
(366) | Mokhtari A, Sjogren J, Nilsson J, Gustafsson R, Malmsjo M, Ingemansson R. The cost of vacuum-assisted closure therapy in treatment of deep sternal wound infection. Scand Cardiovasc J 2008;42(1):85-9. | ✓ | KQ3
(388) | Molnar JA, DeFranzo AJ, Hadaegh A, Morykwas MJ, Shen P, Argenta LC. Acceleration of integra incorporation in complex tissue defects with subatmospheric pressure. Plast Reconstr Surg 2004 Apr 15;113(5):1339-46. | ✓ | KQ3
(616) | Molnar JA, DeFranzo AJ, Marks MW. Single-stage approach to skin grafting the exposed skull. Plast Reconstr Surg 2000 Jan;105(1):174-7. | | | ✓ | Fewer than five patients
(617) | Molnar JA, Simpson JL, Voignier DM, Morykwas MJ, Argenta LC. Management of an acute thermal injury with subatmospheric pressure. J Burns Wounds 2005;4:e5. | | | ✓ | Case report
(618) | Molnar JA. Applications of negative pressure wound therapy to thermal injury. Ostomy Wound Manage 2004 Apr;50(4A Suppl):17-9. | | | ✓ | Narrative
(619) | Montecamozzo G, Leopaldi E, Baratti C, Previde P, Ferla F, Pizzi M, Sposato J, Pariani D, Sartani A, Trabucchi E. Incarcerated massive incisional hernia: extensive necrosis of the colon in a very obese patient. Surgical treatment and vacuum-assisted closure therapy: a case report. Hernia 2008 Dec;12(6):641-3. | | | ✓ | Case report
(79) | Mooney JF 3rd, Argenta LC, Marks MW, Morykwas MJ, DeFranzo AJ. Treatment of soft tissue defects in pediatric patients using the V.A.C. system. Clin Orthop Relat Res 2000 Jul;(376):26-31. | ✓ | KQ3 | | | ✓
(620) | Moore K. VAC therapy: interactions in the healing process. Wounds UK 2005 May;1(1):86-90. | | | ✓ | Narrative
(621) | Moran SG, Windham ST, Cross JM, Melton SM, Rue LW 3rd. Vacuum-assisted complex wound closure with elastic vessel loop augmentation: a novel technique. J Wound Care 2003 Jun;12(6):212-3. | | | ✓ | Narrative
(622) | Moreno-Coutino G, Estrada-Chavez G, Dominguez-Cherit J. Hip ulcer secondary to foreign body reaction and vacuum-assisted closure therapy: report of a case. Int Wound J 2005 Mar;2(1):81-3. | | | ✓ | Case report
(623) | Morris GS, Brueilly KE, Hanzelka H. Negative pressure wound therapy achieved by vacuum-assisted closure: Evaluating the assumptions. Ostomy Wound Manage 2007 Jan;53(1):52-7. | | | ✓ | Narrative
(624) | Morton N. Use of topical negative pressure therapy in postoperative dehisced or infected wounds. J Wound Care 2004 Sep;13(8):346-8. | | | ✓ | Narrative
(33) | Morykwas MJ, Argenta LC, Shelton-Brown EI, McGuirt W. Vacuum-assisted closure: a new method for wound control and treatment: animal studies and basic foundation. Ann Plast Surg 1997 Jun;38(6):553-62. | | | ✓ | Animal study
(625) | Morykwas MJ, Argenta LC. Nonsurgical modalities to enhance healing and care of soft tissue wounds. J South Orthop Assoc 1997 Winter;6(4):279-88. | | | ✓ | Narrative
(626) | Morykwas MJ, David LR, Schneider AM, Whang C, Jennings DA, Canty C, Parker D, White WL, Argenta LC. Use of subatmospheric pressure to prevent progression of partial-thickness burns in a swine model. J Burn Care Rehabil 1999 Jan-Feb;20(1 Pt 1):15-21. | | | ✓ | Animal study
(36) | Morykwas MJ, Faler BJ, Pearce DJ, Argenta LC. Effects of varying levels of subatmospheric pressure on the rate of granulation tissue formation in experimental wounds in swine. Ann Plast Surg 2001 Nov;47(5):547-51. | | | ✓ | Animal study
(627) | Morykwas MJ, Howell H, Bleyer AJ, Molnar JA, Argenta LC. The effect of externally applied subatmospheric pressure on serum myoglobin levels after a prolonged crush/ischemia injury. J Trauma 2002 Sep;53(3):537-40. | | | ✓ | Animal study
(628) | Morykwas MJ, Kennedy A, Argenta JP, Argenta LC. Use of subatmospheric pressure to prevent doxorubicin extravasation ulcers in a swine model. J Surg Oncol 1999 SEP;72(1):14-7. | | | ✓ | Animal study
(629) | Morykwas MJ, Simpson J, Punger K, Argenta A, Kremers L, Argenta J. Vacuum-assisted closure: state of basic research and physiologic foundation. Plast Reconstr Surg 2006 Jun;117(7 Suppl):121S-126S. | | | ✓ | Narrative
(630) | Motta GJ, Corbett LQ. Impact of an antimicrobial gauze upon bacterial colonies in wounds that require packing. Ostomy Wound Manage 2004 Aug;50(8):48-62. | | | ✓ | Narrative
(136) | Moues CM, van den Bemd GJ, Heule F, Hovius SE. Comparing conventional gauze therapy to vacuum-assisted closure wound therapy: a prospective randomised trial. J Plast Reconstr Aesthet Surg 2007;60(6):672-81. | ✓ | KQ1, KQ3
(285) | Moues CM, van den Bemd GJ, Meerding WJ, Hovius SE. An economic evaluation of the use of TNP on full-thickness wounds. J Wound Care 2005 May;14(5):224-7. | | | ✓ | Duplicate study(38)
(631) | Moues CM, van Toorenenbergen AW, Heule F, Hop WC, Hovius SE. The role of topical negative pressure in wound repair: expression of biochemical markers in wound fluid during wound healing. Wound Repair Regen 2008 Jul-Aug;16(4):488-94. | | | ✓ | No relevant outcomes
(38) | Moues CM, Vos MC, van den Bemd GJ, Stijnen T, Hovius SE. Bacterial load in relation to vacuum-assisted closure wound therapy: a prospective randomized trial. Wound Repair Regen 2004 Jan-Feb;12(1):11-7. | | | ✓ | Duplicate study(136)
(389) | Mullner T, Mrkonjic L, Kwasny O, Vecsei V. The use of negative pressure to promote the healing of tissue defects: a clinical trial using the vacuum sealing technique. Br J Plast Surg 1997 Apr;50(3):194-9. | ✓ | KQ3
(632) | Nagell CF, Holte K. Treatment of anastomotic leakage after rectal resection with transrectal vacuum-assisted drainage (VAC). A method for rapid control of pelvic sepsis and healing. Int J Colorectal Dis 2006 Oct;21(7):657-60. | | | ✓ | Fewer than five patients in study arm
(286) | Nelson EA. Vacuum assisted closure for chronic wounds: a review of the evidence. EWMA J 2007 Oct;7(3):5-11. | | | ✓ | Guideline
(633) | Neubauer G, Ujlaky R. The cost-effectiveness of topical negative pressure versus other wound-healing therapies. J Wound Care 2003 Nov;12(10):392-3. | | | ✓ | No abstract available
(634) | Newton H, Benbow M, Hampton S, Beldon P, Butcher M, Baxter H. TNP therapy in the community: findings of a national survey. Wounds UK 2006 Dec;2(4):31-5. | | | ✓ | Narrative
(635) | Ng R, Sebastin SJ, Tihonovs A, Peng YP. Hand in glove—VAC dressing with active mobilisation. J Plast Reconstr Aesthet Surg 2006;59(9):1011-3. | | | ✓ | Narrative
(636) | Nienhuijs SW, Manupassa R, Strobbe LJ, Rosman C. Can topical negative pressure be used to control complex enterocutaneous fistulae. J Wound Care 2003 Oct;12(9):343-5. | | | ✓ | Not relevant
(637) | Niezgoda JA, Mendez-Eastman S. The effective management of pressure ulcers. Adv Skin Wound Care 2006 Jan-Feb;19 Suppl 1:3-15. | | | ✓ | Narrative
(638) | Niezgoda JA. Combining negative pressure wound therapy with other wound management modalities. Ostomy Wound Manage 2005 Feb;51(2A Suppl):36-8. | | | ✓ | Narrative
(639) | Niezgoda JA. Incorporating negative pressure therapy into the management strategy for pressure ulcers. Ostomy Wound Manage 2004 Nov;50(11A Suppl):26-9. | | | ✓ | Case reports
(640) | Niezgoda JA. The economic value of negative pressure wound therapy. Ostomy Wound Manage 2005 Feb;51(2A Suppl):44-7. | | | ✓ | Narrative
(641) | No Authors. Position Document: Topical negative pressure in wound management. European Wound Management 2007 May;1-17. | | | ✓ | Narrative
(642) | No Authors. Topical negative pressure for chronic wounds? Drugs and Therapeutics Bulletin 2007 Aug;45(8):57-61. | | | ✓ | Narrative
(643) | No Authors. V.A.C. Therapy: Proceedings of the 2nd World Union of Wound Healing Societies Meeting (8-13 July 2004, Paris France). Wounds 2004 Dec;16(12-Suppl A):1-19. | | | ✓ | Narrative
(70) | Noble-Bell G, Forbes A. A systematic review of the effectiveness of negative pressure wound therapy in the management of diabetes foot ulcers. Int Wound J 2008 Jun;5(2):233-42. | ✓ | Previous Systematic Reviews | | | ✓
(644) | Norbury K, Kieswetter K. Vacuum-assisted closure therapy attenuates the inflammatory response in a porcine acute wound healing model. Wounds 2007 Apr;19(4):97-106. | | | ✓ | Animal study
(645) | Norton SE, De Souza B, Marsh D, Moir G. Vacuum-assisted closure (VAC Therapy) and the risk of fluid loss in acute trauma. Ann Plast Surg 2006 Feb;56(2):194-5. | | | ✓ | Case report
(646) | NPWT Info and history of NPWT. St. Petersburg (FL): Smith & Nephew, Inc.; 2009 Feb. 13 p. | | | ✓ | Background information
(647) | Nugent N, Lannon D, O’Donnell M. Vacuum-assisted closure –a management option for the burns patient with exposed bone. Burns 2005 May;31(3):390-3. | | | ✓ | Case reports
(648) | Obdeijn MC, de Lange MY, Lichtendahl DH, de Boer WJ. Vacuum-assisted closure in the treatment of poststernotomy mediastinitis. Ann Thorac Surg 1999 Dec;68(6):2358-60. | | | ✓ | Fewer than five patients
(377) | O’Connor J, Kells A, Henry S, Scalea T. Vacuum-assisted closure for the treatment of complex chest wounds. Ann Thorac Surg 2005 Apr;79(4):1196-200. | ✓ | KQ3
(649) | Oczenski W, Waldenberger F, Nehrer G, Kneifel W, Swoboda H, Schwarz S, Fitzgerald RD. Vacuum-assisted closure for the treatment of cervical and mediastinal necrotizing fasciitis. J Cardiothorac Vasc Anesth 2004 Jun;18(3):336-8. | | | ✓ | Narrative
(10) | Orgill DP, Austen WG Jr, Butler CE, Fine NA, Horvath KA, Mihaljevic T, Song DH, Wolfe WG. Guidelines for the treatment of complex chest wounds with negative pressure wound therapy. Wounds 2004 Dec;(Suppl B):1-23. | | | ✓ | Guideline
(20) | Orgill DP. Advancing the treatment options of chest wounds with negative pressure wound therapy. Ostomy Wound Manage 2005 Feb;51(2A Suppl):39-43. | | | ✓ | Narrative
(650) | Orgill DP. Utilizing negative pressure wound therapy on open chest/sternotomy wounds. Ostomy Wound Manage 2004 Nov;50(11A Suppl):15S-17S. | | | ✓ | Case report
(651) | O’Rourke ME. Vacuum-assisted closure therapy. Clin J Oncol Nurs 2006 Dec;10(6):825-6. | | | ✓ | No abstract available
(652) | Ovington LG. 1,2,3 s-t-r-e-t-c-h; vacuum-enhances wound closure. Adv Wound Care 1999 Jan;(Suppl):125-7. | | | ✓ | Narrative
(653) | Ozer K, Smith W. A simple technique for applying vacuum-assisted closure therapy over the circular type external fixation device. Ann Plast Surg 2006 Jun;56(6):693-4. | | | ✓ | Case report
(1) | Page JC, Newswander B, Schwenke DC, Hansen M, Ferguson J. Retrospective analysis of negative pressure wound therapy in open foot wounds with significant soft tissue defects. Adv Skin Wound Care 2004 Sep;17(7):354-64. | ✓ | KQ1,KQ3
(654) | Page JC. Utilizing NPWT for large soft tissue defects. APMA News 2005 May;26(5 Suppl):30-2. | | | ✓ | Narrative
(655) | Pape HC, Webb LX. History of open wound and fracture treatment. J Orthop Trauma 2008 Nov-Dec;22(10 Suppl):S133-4. | | | ✓ | Narrative
(296) | Parrett BM, Matros E, Pribaz JJ, Orgill DP. Lower extremity trauma: Trends in the management of soft-tissue reconstruction of open tibia-fibula fractures. Plast Reconstr Surg 2006 Apr 1;117(4):1315-22. | | | ✓ | Narrative
(656) | Patane F, Zingarelli E, Sansone F, Cappuccio G, Rinaldi M. Vacuum-assisted sternal closure after a ‘depression induced ischemic test’ in severe mediastinitis. J Cardiovasc Med (Hagerstown) 2008 Jun;9(6):622-4. | | | ✓ | Case report
(657) | Patel CT, Kinsey GC, Koperski-Moen KJ, Bungum LD. Vacuum-assisted wound closure. Am J Nurs 2000 Dec;100(12):45-8. | | | ✓ | Case report
(658) | Pattison PS, Gordon JK, Muto PM, Mallen JK, Hoerner J. Case report: using dual therapies-negative pressure wound therapy and modified silicone gel liner-to treat a limb postamputation and dehiscence. Wounds 2005 Aug;17(8):233-40. | | | ✓ | Case report
(41) | Paul JC. Vacuum assisted closure therapy: a must in plastic surgery. Plast Surg Nurs 2005 April/June;25(2):61-65. | | | ✓ | Case report
(298) | Peinemann F, McGauran N, Sauerland S, Lange S. Disagreement in primary study selection between systematic reviews on negative pressure wound therapy. BMC Med Res Methodol 2008;8:41. | | | ✓ | Methodology paper
(189) | Peinemann F, McGauran N, Sauerland S, Lange S. Negative pressure wound therapy: Potential publication bias caused by lack of access to unpublished study results data. BMC Med Res Methodol 2008;(8):Article Number: 4. | ✓ | Previous Systematic Reviews
(371) | Pelham FR, Kubiak EN, Sathappan SS, Di Cesare PE. Topical negative pressure in the treatment of infected wounds with exposed orthopaedic implants. J Wound Care 2006 Mar;15(3):111-6. | ✓ | KQ3
(659) | Penn E, Rayment S. Management of a dehisced abdominal wound with VAC therapy. Br J Nurs 2004 Feb 26-Mar 10;13(4):194-201. | | | ✓ | Case report
(95) | Perez D, Wildi S, Demartines N, Bramkamp M, Koehler C, Clavien PA. Prospective evaluation of vacuum-assisted closure in abdominal compartment syndrome and severe abdominal sepsis. J Am Coll Surg 2007 Oct;205(4):586-92. | ✓ | KQ1 | | | ✓
(660) | Petersson U, Acosta S, Bjorck M. Vacuum-assisted wound closure and mesh-mediated fascial traction--a novel technique for late closure of the open abdomen. World J Surg 2007 Nov;31(11):2133-7. | | | ✓ | Not relevant
(661) | Petrie N, Potter M, Banwell P. The management of lower extremity wounds using topical negative pressure. Int J Low Extrem Wounds 2003 Dec;2(4):198-206. | | | ✓ | Narrative
(662) | Petzina R, Ugander M, Gustafsson L, Engblom H, Hetzer R, Arheden H, Ingemansson R, Malmsjo M. Topical negative pressure therapy of a sternotomy wound increases sternal fluid content but does not affect internal thoracic artery blood flow: assessment using magnetic resonance imaging. J Thorac Cardiovasc Surg 2008 May;135(5):1007-13. | | | ✓ | Animal study
(663) | Petzina R, Ugander M, Gustafsson L, Engblom H, Sjogren J, Hetzer R, Ingemansson R, Arheden H, Malmsjo M. Hemodynamic effects of vacuum-assisted closure therapy in cardiac surgery: assessment using magnetic resonance imaging. J Thorac Cardiovasc Surg 2007 May;133(5):1154-62. | | | ✓ | Animal study
(176) | Pham CT, Middleton PF, Maddern GJ. The safety and efficacy of topical negative pressure in non-healing wounds: a systematic review. J Wound Care 2006 Jun;15(6):240-50. | ✓ | Previous Systematic Reviews
(664) | Phelps JR, Fagan R, Pirela-Cruz MA. A case study of negative pressure wound therapy to manage acute necrotizing fasciitis. Ostomy Wound Manage 2006 Mar;52(3):54-9. | | | ✓ | Case report
(665) | Philbeck TE Jr, Whittington KT, Millsap MH, Briones RB, Wight DG, Schroeder WJ. The clinical and cost effectiveness of externally applied negative pressure wound therapy in the treatment of wounds in home healthcare Medicare patients. Ostomy Wound Manage 1999 Nov;45(11):41-50. | | | ✓ | Patients treated with dual therapies
(666) | Philbeck TE, Schroeder WJ, Whittington KT. Vacuum-assisted closure therapy for diabetic foot ulcers: clinical and cost analyses. Home Health Care Consult 2001 Mar;8(3):27-34. | | | ✓ | Narrative
(667) | Pirela-Cruz MA, Machen MS, Esquivel D. Management of large soft-tissue wounds with negative pressure therapy-lessons learned from the war zone. J Hand Ther 2008 Apr-Jun;21(2):196-202; quiz 203. | | | ✓ | Narrative
(668) | Plikaitis CM, Molnar JA. Subatmospheric pressure wound therapy and the vacuum-assisted closure device: basic science and current clinical successes. Expert Rev Med Devices 2006 Mar;3(2):175-84. | | | ✓ | Narrative
(80) | Ploumis A, Mehbod AA, Dressel TD, Dykes DC, Transfeldt EE, Lonstein JE. Therapy of spinal wound infections using vacuum-assisted wound closure: risk factors leading to resistance to treatment. J Spinal Disord Tech 2008 Jul;21(5):320-3. | ✓ | KQ3 | | | ✓
(669) | Pollak AN. Use of negative pressure wound therapy with reticulated open cell foam for lower extremity trauma. J Orthop Trauma 2008 Nov-Dec;22(10 Suppl):S142-5. | | | ✓ | Narrative
(670) | Poulakidas S, Cologne K, Kowal-Vern A. Treatment of frostbite with subatmospheric pressure therapy. J Burn Care Res 2008 Nov-Dec;29(6):1012-4. | | | ✓ | Case report
(671) | Poulakidas S, Kowal-Vern A. Facilitating residual wound closure after partial graft loss with vacuum assisted closure therapy. J Burn Care Res 2008 Jul-Aug;29(4):663-5. | | | ✓ | Case report
(672) | Powell ET 4th. The role of negative pressure wound therapy with reticulated open cell foam in the treatment of war wounds. J Orthop Trauma 2008 Nov-Dec;22(10 Suppl):S138-41. | | | ✓ | Narrative
(673) | Principles of best practice: vacuum assisted closure: recommendations for use. A consensus document. [internet]. The Medical Education Partnership (MEP); 2008 Jun [10]. Available: http://www.mepltd.co.uk/oneoffsdetail.html?p=vaccon. | | | ✓ | Guideline
(791) | Product labeling information. San Antonio (TX): Kinetic Concepts, Inc.; 176 p. | | | ✓ | Product labeling
(301) | Pu LL. An alternative approach for soft-tissue coverage of a complex wound in the foot and ankle with vacuum-assisted closure over artificial dermis and subsequent skin graft. J Plast Reconstr Aesthet Surg 2008 Nov 20;Epub ahead of print. | | | ✓ | Narrative
(674) | Quah HM, Maw A, Young T, Hay DJ. Vacuum-assisted closure in the management of the open abdomen: a report of a case and initial experiences. J Tissue Viability 2004 Apr;14(2):59-62. | | | ✓ | Case report
(186) | Raja SG, Berg GA. Should vacuum-assisted closure therapy be routinely used for management of deep sternal wound infection after cardiac surgery. Interact Cardiovasc Thorac Surg 2007 Aug;6(4):523-7. | ✓ | Previous Systematic Reviews
(675) | Ramnarine IR, McLean A, Pollock JC. Vacuum-assisted closure in the paediatric patient with post-cardiotomy mediastinitis. Eur J Cardiothorac Surg 2002 Dec;22(6):1029-31. | | | ✓ | Case report
(163) | Rao M, Burke D, Finan PJ, Sagar PM. The use of vacuum-assisted closure of abdominal wounds: a word of caution. Colorectal Dis 2007 Mar;9(3):266-8. | ✓ | KQ3
(676) | Rapp SM. Negative pressure wound therapy reduces infections in lower extremity fractures. Orthop Today 2008 Feb;28(54) Also available: http://www.orthosupersite.com/print.asp?rID=26142. Accessed on Feb 7, 2008. | | | ✓ | Narrative
(677) | Reed SF, Novosel TJ, Weireter LJ, Collins JN, Britt RC, Alvey C, Merkh K, Britt LD. A novel technique for vacuum assisted closure on injured tissue or in confined spaces. J Trauma 2008 May;64(5):1406-7. | | | ✓ | Narrative
(678) | Reed T, Economon D, Wiersema-Bryant L. Colocutaneous fistula management in a dehisced wound: a case study. Ostomy Wound Manage 2006 Apr;52(4):60-4, 66. | | | ✓ | Case report
(679) | Reid DJ, Linneman P, Lentz CW. Negative pressure dressing to secure skin grafts. Surg Phys Assist 2001 Feb;9-13. | | | ✓ | Case report
(680) | Reisler T. A simple method of securing an interface dressing and vacuum-assisted closure foam pad to difficult wounds. Ann Plast Surg 2007 Aug;59(2):230-1. | | | ✓ | Narrative
(681) | Reitsma AM, Rhodeheaver GT. Effectiveness of a new antimicrobial gauze dressing as a bacterial barrier. [internet]. Charlottesville (VA): University of Virginia Health System; 2001 Sep 1 Available: http://www.kendallhq.com/imageServer.aspx?contentID=7598&contenttype=application/pdf. | | | ✓ | Narrative
(682) | Renner R, Rogalski C, Friedlein H, Simon JC. [Vacuum therapy in dermatology: a review. J Dtsch Dermatol Ges 2006 Jun;4(6):468-76. | | | ✓ | Narrative
(683) | Repta R, Ford R, Hoberman L, Rechner B. The use of negative-pressure therapy and skin grafting in the treatment of soft-tissue defects over the Achilles tendon. Ann Plast Surg 2005 Oct;55(4):367-70. | | | ✓ | Fewer than five patients
(684) | Rhee P, Velmahos GC. Traumatic wounds. Ostomy Wound Manage 2004 Apr;50(4A Suppl):22-5. | | | ✓ | Case report
(121) | Rinker B, Amspacher JC, Wilson PC, Vasconez HC. Subatmospheric pressure dressing as a bridge to free tissue transfer in the treatment of open tibia fractures. Plast Reconstr Surg 2008 May;121(5):1664-73. | ✓ | KQ1, KQ3
(685) | Robson MC, Cooper DM, Aslam R, Gould LJ, Harding KG, Margolis DJ, Ochs DE, Serena TE, Snyder RJ, Steed DL, Thomas DR, Wiersma-Bryant L. Guidelines for the treatment of venous ulcers. Wound Repair Regen 2006 Nov-Dec;14(6):649-62. | | | ✓ | Guideline
(89) | Rosenthal EL, Blackwell KE, McGrew B, Carroll WR, Peters GE. Use of negative pressure dressings in head and neck reconstruction. Head Neck 2005 Nov;27(11):970-5. | ✓ | KQ3 | | | ✓
(686) | Rosser CJ, Morykwas MJ, Argenta LC, Bare RL. A new technique to manage perineal wounds. Infect Urol 2000 Mar/Apr;13(2):45-7. | | | ✓ | Case report
(378) | Routledge T, Saeb-Parsy K, Murphy F, Ritchie AJ. The use of vacuum-assisted closure in the treatment of post-transplant wound infections: A case series. J Heart Lung Transplant 2005;24(9):1444.e15-6. | ✓ | KQ3
(687) | Saad SA, Shakov E, Sebastian V, Saad A. The use of wound vacuum-assisted closure (VAC) system in the treatment of recurrent or complex pilonidal cystDisease: experience in 4 adolescent patients. Internet J Surg 2007 Jan;11(1) | | | ✓ | Fewer than five patients
(688) | Sadat U, Chang G, Noorani A, Walsh SR, Hayes PD, Varty K. Efficacy of TNP on lower limb wounds: a meta-analysis. J Wound Care 2008 Jan;17(1):45-8. | | | ✓ | Narrative
(689) | Saeed MU, Kennedy DJ. A retained sponge is a complication of vacuum-assisted closure therapy. Int J Low Extrem Wounds 2007 Sep;6(3):153-4. | | | ✓ | Case report
(690) | Saiki Y, Hata M, Akasaka J, Saito T, Tabayashi K. Vacuum-assisted closure system for the treatment of mediastinitis after total aortic arch replacement. Jpn J Thorac Cardiovasc Surg 2005 Dec;53(12):638-40. | | | ✓ | Case report
(691) | Salazard B, Niddam J, Ghez O, Metras D, Magalon G. Vacuum-assisted closure in the treatment of poststernotomy mediastinitis in the paediatric patient. J Plast Reconstr Aesthet Surg 2008;61(3):302-5. | | | ✓ | Fewer than five patients
(151) | Sartipy U, Lockowandt U, Gabel J, Jideus L, Dellgren G. Cardiac Rupture During Vacuum-Assisted Closure Therapy. Ann Thorac Surg 2006 Sep;82(3):1110-1. | ✓ | KQ3
(34) | Saxena V, Hwang CW, Huang S, Eichbaum Q, Ingber D, Orgill DP. Vacuum-assisted closure: microdeformations of wounds and cell proliferation. Plast Reconstr Surg 2004 Oct;114(5):1086-96; discussion 1097-. | | | ✓ | Not a clinical study
(692) | Saxena V, Orgill D, Kohane I. A set of genes previously implicated in the hypoxia response might be an important modulator in the rat ear tissue response to mechanical stretch. BMC Genomics 2007;8:430. | | | ✓ | Animal study
(693) | Schaffzin DM, Douglas JM, Stahl TJ, Smith LE. Vacuum-assisted closure of complex perineal wounds. Dis Colon Rectum 2004 Oct;47(10):1745-8. | | | ✓ | Case reports
(132) | Scherer LA, Shiver S, Chang M, Meredith JW, Owings JT, Tominaga GT, Schecter WP, Parks SN, Peck J, Mayberry J. The vacuum assisted closure device: a method of securing skin grafts and improving graft survival. Arch Surg 2002;137(8):930-4. | ✓ | KQ1, KQ3
(35) | Scherer SS, Pietramaggiori G, Mathews JC, Prsa MJ, Huang S, Orgill DP. The mechanism of action of the vacuum-assisted closure device. Plast Reconstr Surg 2008 Sep;122(3):786-97. | | | ✓ | Animal study
(694) | Scheufler O, Peek A, Kania NM, Exner K. Problem-adapted application of vacuum occlusion dressings: case report and clinical experience. Eur J Plastic Surg 2000 Oct;23(7):386-90. | | | ✓ | Case report
(307) | Schimmer C, Sommer SP, Bensch M, Leyh R. Primary treatment of deep sternal wound infection after cardiac surgery: a survey of German heart surgery centers. Interact Cardiovasc Thorac Surg 2007 Dec;6(6):708-11. | | | ✓ | Does not address key question
(147) | Schimp VL, Worley C, Brunello S, Levenback CC, Wolf JK, Sun CC, Bodurka DC, Ramirez PT. Vacuum-assisted closure in the treatment of gynecologic oncology wound failures. Gynecol Oncol 2004 Feb;92(2):586-91. | ✓ | KQ3
(695) | Schintler M, Maier A, Matzi V, Smolle-Juttner FM. Vacuum assisted closure system in the management of cervical anastomotic leakage after gastric pull-up. Interact Cardiovasc Thorac Surg 2004 Mar;3(1):92-4. | | | ✓ | Case report
(696) | Schintler M, Marschitz I, Trop M. The use of topical negative pressure in a paediatric patient with extensive burns. Burns 2005 Dec;31(8):1050-3. | | | ✓ | Case report
(697) | Schipper J, Ridder GJ, Maier W, Teszler CB, Horch RE. Laryngotracheal reconstruction using prefabricated and preconditioned composite radial forearm free flaps. A report of two cases. Auris Nasus Larynx 2007 Jun;34(2):253-8. | | | ✓ | Not relevant
(308) | Schlatterer D, Hirshorn K. Negative pressure wound therapy with reticulated open cell foam-adjunctive treatment in the management of traumatic wounds of the leg: a review of the literature. J Orthop Trauma 2008 Nov-Dec;22(10 Suppl):S152-60. | | | ✓ | Narrative
(698) | Schlatterer D, Webb LX. Orthopedic indications for negative pressure wound therapy. Ostomy Wound Manage 2005 Feb;51(2A Suppl):27-8. | | | ✓ | Case report
(699) | Schneider AM, Morykwas MJ, Argenta LC. A new and reliable method of securing skin grafts to the difficult recipient bed. Plast Reconstr Surg 1998 Sep;102(4):1195-8. | | | ✓ | No abstract available
(700) | Schoemann MB, Lentz CW. Treating surgical wound dehiscence with negative pressure dressings. Ostomy Wound Manage 2005 Feb;51(2A Suppl):15-20. | | | ✓ | Narrative
(81) | Scholl L, Chang E, Reitz B, Chang J. Sternal osteomyelitis: use of vacuum-assisted closure device as an adjunct to definitive closure with sternectomy and muscle flap reconstruction. J Card Surg 2004 Sep-Oct;19(5):453-61. | ✓ | KQ3 | | | ✓
(701) | Schuster R, Moradzadeh A, Waxman K. The use of vacuum-assisted closure therapy for the treatment of a large infected facial wound. Am Surg 2006 Feb;72(2):129-31. | | | ✓ | Case report
(126) | Schwien T, Gilbert J, Lang C. Pressure ulcer prevalence and the role of negative pressure wound therapy in home health quality outcomes. Ostomy Wound Manag 2005;51:47-60. | ✓ | KQ1, KQ3
(311) | Segers P, de Jong AP, Kloek JJ, Spanjaard L, de Mol BA. Risk control of surgical site infection after cardiothoracic surgery. J Hosp Infect 2006 Apr;62(4):437-45. | | | ✓ | Case report
(310) | Segers P, de Jong AP, Kloek JJ, van der Horst CM, Spanjaard L, de Mol BA. Topical negative pressure therapy in wounds after cardiothoracic surgery: successful experience supported by literature. Thorac Cardiovasc Surg 2006 Aug;54(5):289-94. | | | ✓ | Not a clinical study
(354) | Segers P, Kloek JJ, Strackee DS, de Mol BA. Open window thoracostomy: a new therapeutic option using topical negative presure wound therapy. Wounds 2007 Oct;19(10):264-9. | ✓ | KQ3
(702) | Senchenkov A, Knoetgen J, Chrouser KL, Nehra A. Application of vacuum-assisted closure dressing in penile skin graft reconstruction. Urology 2006 Feb;67(2):416-9. | | | ✓ | Narrative
(355) | Senchenkov A, Petty PM, Knoetgen J 3rd, Moran SL, Johnson CH, Clay RP. Outcomes of skin graft reconstructions with the use of Vacuum Assisted Closure (VAC) dressing for irradiated extremity sarcoma defects. World J Surg Oncol 2007;5:138. | ✓ | KQ3
(703) | Sentenac J. Facilitating wound healing with VAC therapy: a pharmacist’s role. European Journal of Hospital Pharmacists 2008 May;14(5):57-8. | | | ✓ | Narrative
(138) | Shilt JS, Yoder JS, Manuck TA, Jacks L, Rushing J, Smith BP. Role of vacuum-assisted closure in the treatment of pediatric lawnmower injuries. J Pediatr Orthop 2004;24(5):482-487. | ✓ | KQ1, KQ3
(704) | Shirakawa M, Isseroff RR. Topical negative pressure devices: Use for enhancement of healing chronic wounds. Arch Dermatol 2005 Nov;141(11):1449-53. | | | ✓ | Narrative
(705) | Short B, Claxton M, Armstrong DG. How to use VAC therapy on chronic wounds. Podiatry Today 2002 Jul;15(7):48-54. | | | ✓ | Narrative
(367) | Shrestha BM, Nathan VC, Delbridge MC, Parker K, Throssell D, McKane WS, Karim MS, Raftery AT. Vacuum-assisted closure (VAC) therapy in the management of wound infection following renal transplantation. Kathmandu Univ Med J (KUMJ) 2007 Jan-Mar;5(1):4-7. | ✓ | KQ3
(706) | Shvartsman HS, Langstein H, Worley C, Malpica A, Ramondetta LM. Use of a vacuum-assisted closure device in the treatment of recurrent Paget’s disease of the vulva. Obstet Gynecol 2003 Nov;102(5 Pt 2):1163-6. | | | ✓ | Case report
(119) | Siegel HJ, Long JL, Watson KM, Fiveash JB. Vacuum-assisted closure for radiation-associated wound complications. J Surg Oncol 2007 Dec 1;96(7):575-82. | ✓ | KQ1, KQ3
(707) | Silberstein J, Grabowski J, Parsons JK. Use of a Vacuum-Assisted Device for Fournier’s Gangrene: A New Paradigm. Rev Urol 2008 Winter;10(1):76-80. | | | ✓ | Case report
(708) | Simek M, Nemec P, Zalesak B, Kalab M, Hajek R, Jecminkova L, Kolar M. Vacuum-assisted closure in the treatment of sternal wound infection after cardiac surgery. Biomed Pap Med Fac Univ Palacky Olomouc Czech Repub 2007 Dec;151(2):295-9. | | | ✓ | Duplicate study(123)
(709) | Simman R, Forte R, Silverberg B, Moriera-Gonzalez A, Williams F. A comparative histological study of skin graft take with tie-over bolster dressing versus negative pressure wound therapy in a pig model: a preliminary study. Wounds 2004 Feb;16(2):76-80. | | | ✓ | Animal study
(710) | Simon DH, Key JJ, Blume PA. Lower extremity wounds respond to negative pressure. Biomechanics 2008 Aug;15(8):53-9. | | | ✓ | Narrative
(711) | Simon S, Hammoudeh J, Low C, Nathan N, Armstrong M, Thaller S. Complex wound management with an artificial dermal regeneration template. Wounds 2008 Nov;20(11):299-302. | | | ✓ | Case reports
(712) | Singh K, Samartzis D, Heller JG, An HS, Vaccaro AR. The management of complex soft-tissue defects after spinal instrumentation. J Bone Joint Surg Br 2006 Jan;88(1):8-15. | | | ✓ | Narrative
(713) | Singh S, Mackey S, Soldin M. VAC it - Some techniques on the application of VAC dressings. Ann R Coll Surg Engl 2008 Mar;90(2):161-2. | | | ✓ | Narrative
(714) | Sjogren J, Gustafsson R, Koul B, Ingemansson R. Selective mediastinal tamponade to control coagulopathic bleeding. Ann Thorac Surg 2003 Apr;75(4):1311-3. | | | ✓ | Case report
(139) | Sjogren J, Gustafsson R, Nilsson J, Malmsjo M, Ingemansson R. Clinical outcome after poststernotomy mediastinitis: Vacuum-assisted closure versus conventional treatment. Ann Thorac Surg 2005;79(6):2049-55. | ✓ | KQ1, KQ3, Previous Systematic Reviews
(715) | Sjogren J, Gustafsson R, Wackenfors A, Malmsjo M, Algotsson L, Ingemansson R. Effects of vacuum-assisted closure on central hemodynamics in a sternotomy wound model. Interact Cardiovasc Thorac Surg 2004 Dec;3(4):666-71. | | | ✓ | Animal study
(716) | Sjogren J, Malmsjo M, Gustafsson R, Ingemansson R. Poststernotomy mediastinitis: a review of conventional surgical treatments, vacuum-assisted closure therapy and presentation of the Lund University Hospital mediastinitis algorithm. Eur J Cardiothorac Surg 2006 Dec;30(6):898-905. | | | ✓ | Narrative
(717) | Sjogren J, Mokhtari A, Gustafsson R, Malmsjo M, Nilsson J, Ingemansson R. Vacuum-assisted closure therapy for deep sternal wound infections: the impact of learning curve on survival and predictors for late mortality. Int Wound J 2008 Jun;5(2):216-23. | | | ✓ | Not relevant
(179) | Sjogren J, Nilsson J, Gustafsson R, Malmsjo M, Ingemansson R. The impact of vacuum-assisted closure on long-term survival after post-sternotomy mediastinitis. Ann Thorac Surg 2005 Oct;80(4):1270-5. | ✓ | Previous Systematic Reviews
(718) | Skillman J, Kirkpatrick N, Coombes A, Coghlan B, Waterhouse N, Joshi N, Kelly M. Vacuum Assisted Closure (VAC) dressing for skin graft application following exenteration of the orbit. Orbit 2003 Mar;22(1):63-5. | | | ✓ | Case report
(719) | Smith APS. A closer look at the potential of hyperbaric oxygen therapy. APMA News 2005 May;26(5-Suppl):39-42. | | | ✓ | Not relevant
(720) | Smith APS. Case study: treating a diabetic puncture wound. APMA News 2005 May;26(5-Suppl):16-18. | | | ✓ | Case report
(315) | Smith N. The benefits of VAC therapy in the management of pressure ulcers. Br J Nurs 2004 Dec 9-2005 Jan 12;13(22):1359-65. | | | ✓ | Reanalysis of already published data
(721) | Snyder N, Gould LJ. Scrotal and penile reconstruction using the vacuum-assisted closure device. Can J Plast Surg 2005 Dec;13(4):205-6. | | | ✓ | No abstract available
(124) | Song DH, Wu LC, Lohman RF, Gottlieb LJ, Franczyk M. Vacuum assisted closure for the treatment of sternal wounds: the bridge between debridement and definitive closure. Plast Reconstr Surg 2003 Jan;111(1):92-7. | ✓ | KQ1,KQ3, Previous Systematic Reviews
(316) | Sposato G, Molea G, Di Caprio G, Scioli M, La Rusca I, Ziccardi P. Ambulant vacuum-assisted closure of skin-graft dressing in the lower limbs using a portable mini-VAC device. Br J Plast Surg 2001 Apr;54(3):235-7. | | | ✓ | Narrative
(125) | Stannard JP, Robinson JT, Anderson ER, McGwin G Jr, Volgas DA, Alonso JE. Negative pressure wound therapy to treat hematomas and surgical incisions following high-energy trauma. J Trauma 2006 Jun;60(6):1301-6. | ✓ | KQ1, KQ3
(722) | Stawicki SP, Grossman M. "Stretching" negative pressure wound therapy: Can dressing change interval be extended in patients with open abdomens. Ostomy Wound Manage 2007 Jan;53(1):26-9. | | | ✓ | Narrative
(723) | Stawicki SP, Schwarz NS, Schrag SP, Lukaszczyk JJ, Schadt ME, Dippolito A. Application of vacuum-assisted therapy in postoperative ascitic fluid leaks: an integral part of multimodality wound management in cirrhotic patients. J Burns Wounds 2007 Apr 16;6:91-9. | | | ✓ | Fewer than five patients
(724) | Steed DL, Attinger C, Colaizzi T, Crossland M, Franz M, Harkless L, Johnson A, Moosa H, Robson M, Serena T, Sheehan P, Veves A, Wiersma-Bryant L. Guidelines for the treatment of diabetic ulcers. Wound Repair Regen 2006 Nov;14(6):680-92. | | | ✓ | Guideline
(725) | Steenvoorde P, de Roo RA, Oskam J, Neijenhuis P. Negative pressure wound therapy to treat peri-prosthetic methicillin-resistant Staphylococcus aureus infection after incisional herniorrhaphy. A case study and literature review. Ostomy Wound Manage 2006 Jan;52(1):52-4. | | | ✓ | Case report
(726) | Steenvoorde P, Rozeboom Al, Melief P, Elzo Kraemer CV, Bonsing BA. Failure of the topical negative pressure abdominal dressing system in the "fat" open abdomen: report of a case and review of literature. Wounds 2006 Feb;18(2):44-50. | | | ✓ | Case report
(727) | Steenvoorde P, Slotema E, Adhin S, Oskam J. Deep infection after ilioinguinal node dissection: vacuum-assisted closure therapy. Int J Low Extrem Wounds 2004 Dec;3(4):223-6. | | | ✓ | Case report
(728) | Steenvoorde P, van Engeland A, Bonsing B, da Costa SA, Oskam J. Combining topical negative pressure and a Bogota bag for managing a difficult laparostomy. J Wound Care 2004 Apr;13(4):142-3. | | | ✓ | Case report
(349) | Steiert AE, Gohritz A, Schreiber TC, Krettek C, Vogt PM. Delayed flap coverage of open extremity fractures after previous vacuum-assisted closure (VAC) therapy - worse or worth. J Plast Reconstr Aesthet Surg 2008 Mar 24;Epub ahead of print. | ✓ | KQ3
(729) | Steinberg JS. Exploring adjunctive combination therapy for wound bed preparation. APMA News 2005 May;26(5 Suppl):24-6. | | | ✓ | Narrative
(730) | Stinson JA, Powell JL. Necrotizing fasciitis in women at a community teaching hospital. J Pelvic Med Surg 2005 Jul-Aug;11(4):209-13. | | | ✓ | Not relevant to topic
(358) | Stoeckel WT, David L, Levine EA, Argenta AE, Perrier ND. Vacuum-assisted closure for the treatment of complex breast wounds. Breast 2006 Nov;15(5):610-3. | ✓ | KQ3
(731) | Stokes TH, Follmar KE, Silverstein AD, Weizer AZ, Donatucci CF, Anderson EE, Erdmann D. Use of negative-pressure dressings and split-thickness skin grafts following penile shaft reduction and reduction scrotoplasty in the management of penoscrotal elephantiasis. Ann Plast Surg 2006 Jun;56(6):649-53. | | | ✓ | Not relevant
(133) | Stone P, Progozen J, Hofeldt m, Hass S, DeLuca J, Flaherty S. Bolster versus negative pressure wound therapy for securing split-thickness skin grafts in trauma patients. Wounds 2004;16(7):219-23. | ✓ | KQ1, KQ3
(90) | Stone PA, Hass SM, Flaherty SK, DeLuca JA, Lucente FC, Kusminsky RE. Vacuum-assisted fascial closure for patients with abdominal trauma. J Trauma 2004 Nov;57(5):1082-6. | ✓ | KQ3 | | | ✓
(77) | Stonerock CE, Bynoe RP, Yost MJ, Nottingham JM. Use of a vacuum-assisted device to facilitate abdominal closure. Am Surg 2003 Dec;69(12):1030-4; discussion 1034-5. | ✓ | KQ3 | | | ✓
(320) | Suess JJ, Kim PJ, Steinberg JS. Negative pressure wound therapy: evidence-based treatment for complex diabetic foot wounds. Curr Diab Rep 2006 Dec;6(6):446-50. | | | ✓ | Narrative
(166) | Suliburk JW, Ware DN, Balogh Z, McKinley BA, Cocanour CS, Kozar RA, Moore FA. Vacuum-Assisted Wound Closure Achieves Early Fascial Closure of Open Abdomens after Severe Trauma. J Trauma Inj Infect Crit Care 2003;55(6):1155-60. | ✓ | KQ3
(732) | Summaries of current clinical evidence Engenex NPWT system. Skillman (NJ): ConvaTec, Inc.; 2 p. | | | ✓ | Poster presentation
(733) | Sunog T. Closing time. Adv Nurs 2003 Aug;18(34):39. | | | ✓ | No abstract available
(734) | Svedman, et al. A dressing system providing fluid supply and suction drainage used for continuous or intermittent irrigation. Ann Plast Surg 1986 Aug;17(2):125-33. | | | ✓ | Narrative
(149) | Svensson S, Monsen C, Kolbel T, Acosta S. Predictors for Outcome after Vacuum Assisted Closure Therapy of Peri-vascular Surgical Site Infections in the Groin. Eur J Vasc Endovasc Surg 2008 Jul;36(1):84-9. | ✓ | KQ3
(735) | Tan D, Rajanayagam J, Schwarz F. Treatment of long-standing, poor-healing diabetic foot ulcers with topical negative pressure in the Torres Strait. Aust J Rural Health 2007 Aug;15(4):275-6. | | | ✓ | Case report
(736) | Tang AT, Ohri SK, Haw MP. Novel application of vacuum assisted closure technique to the treatment of sternotomy wound infection. Eur J Cardiothorac Surg 2000 Apr;17(4):482-4. | | | ✓ | Narrative
(737) | Tang AT, Okri SK, Haw MP. Vacuum-assisted closure to treat deep sternal wound infection following cardiac surgery. J Wound Care 2000 May;9(5):229-30. | | | ✓ | Case report
(323) | Tanna N, Clary MS, Conrad DE, Lenert J, Sadeghi N. Vacuum-assisted closure for wound dehiscence in head and neck reconstruction. Plast Reconstr Surg 2009 Jan;123(1):19e-21e. | | | ✓ | Case report
(738) | Tarkin IS. The versatility of negative pressure wound therapy with reticulated open cell foam for soft tissue management after severe musculoskeletal trauma. J Orthop Trauma 2008 Nov-Dec;22(10 Suppl):S146-51. | | | ✓ | Narrative
(739) | Taub PJ, Schulman MR, Sett S, Koch RM. Revisiting vascularized muscle flaps for complicated sternal wounds in children. Ann Plast Surg 2005 Nov;55(5):535-7. | | | ✓ | Case report
(229) | Teot L, Lambert L, Ourabah Z, Bey E, Steenman C, Wierzbiecka E, Malikov S, Charles JP, Vives F, Bohbot S. Use of topical negative pressure with a lipidocolloid dressing: results of a clinical evaluation. J Wound Care 2006 Sep;15(8):355-8. | | | ✓ | Homemade device
(740) | Terrazas SG. Adjuvant dressing for negative pressure wound therapy in burns. Ostomy Wound Manage 2006 Jan;52(1):16, 18. | | | ✓ | No abstract available
(741) | Thomas S. An introduction to the use of vacuum assisted closure. In: World Wide Wounds [serial online]. ; 2001 May [accessed 2001 Jun 11]. [25 screens]. Available: http://www.worldwidewounds.com/2001/may/Thomas/Vacuum-Assisted-Closure.htm. | | | ✓ | Narrative
(742) | Thomas T. (Executive Director, Association for the Advancement of Wound Care. Malvern, PA). Personal communication – Full submission packet. 2009 Feb 1. 142 p p. | | | ✓ | Personal communication
(743) | Thompson JT, Marks MW. Negative pressure wound therapy. Clin Plast Surg 2007 Oct;34(4):673-84. | | | ✓ | Narrative
(326) | Timmers MS, Le Cessie S, Banwell P, Jukema GN. The effects of varying degrees of pressure delivered by negative-pressure wound therapy on skin perfusion. Ann Plast Surg 2005 Dec;55(6):665-71. | | | ✓ | No relevant outcomes
(744) | Torbrand C, Ingemansson R, Gustafsson L, Paulsson P, Malmsjo M. Pressure transduction to the thoracic cavity during topical negative pressure therapy of a sternotomy wound. Int Wound J 2008 Oct;5(4):579-84. | | | ✓ | Animal study
(745) | Torbrand C, Wackenfors A, Lindstedt S, Ekman R, Ingemansson R, Malmsjo M. Sympathetic and sensory nerve activation during negative pressure therapy of sternotomy wounds. Interact Cardiovasc Thorac Surg 2008 Dec;7(6):1067-70. | | | ✓ | Animal study
(746) | Trop M, Schintler M, Urban E, Roedl S, Stockenhuber A. Are 1:4 mesh and donor site contraindications for vacuum-assisted closure device. J Trauma 2006 Nov;61(5):1267-70. | | | ✓ | No abstract available
(747) | Trueman P, Flack S, Loonstra A, Hauser T. The feasibility of using V.A.C. Therapy in home care patients with surgical and traumatic wounds in the Netherlands. Int Wound J 2008 Jun;5(2):225-31. | | | ✓ | Not a clinical study
(748) | Trueman P. Cost-effectiveness considerations for home health V.A.C. Therapy in the United States of America and its potential international application. Int Wound J 2008 Jun;5 Suppl 2:23-6. | | | ✓ | Cost effectiveness
(174) | Ubbink DT, Westerbos SJ, Evans D, Land L, Vermeulen H. Topical negative pressure for treating chronic wounds (Review). In: Cochrane Database of Systematic Reviews [internet]. Issue 3. Hoboken (NJ): John Wiley & Sons, Ltd.; 2008 [Art. No.: CD001898]. | ✓ | Previous Systematic Reviews
(183) | Ubbink DT, Westerbos SJ, Nelson EA, Vermeulen H. A systematic review of topical negative pressure therapy for acute and chronic wounds. Br J Surg 2008 Jun;95(6):685-92. | ✓ | Previous Systematic Reviews
(228) | Using topical negative pressure with a lipidocolloid dressing. Ostomy Wound Manage 2008 Jun;54(6):12-4. | | | ✓ | No abstract available
(749) | Uygur F, Duman H, Ulkur E, Ceikoz B. The role of the vacuum-assisted closure therapy in the salvage of venous congestion of the free flap: case report. Int Wound J 2008 Mar;5(1):50-3. | | | ✓ | Case report
(750) | Vallet C, Saucy F, Haller C, Meier P, Rafoul W, Corpataux JM. Vacuum-assisted conservative treatment for the management and salvage of exposed prosthetic hemodialysis access. Eur J Vasc Endovasc Surg 2004 Oct;28(4):397-9. | | | ✓ | Case reports
(107) | van den Boogaard M, de Laat E, Spauwen P, Schoonhoven L. The effectiveness of topical negative pressure in the treatment of pressure ulcers: a literature review. Eur J Plastic Surg 2008 Apr;31(1):1-7. | ✓ | KQ1, KQ3
(368) | van Rhee MA, de Klerk LW, Verhaar JA. Vacuum-assisted wound closure of deep infections after instrumented spinal fusion in six children with neuromuscular scoliosis. Spine J 2007 Sep-Oct;7(5):596-600. | ✓ | KQ3
(751) | Varker KA, Ng T. Management of empyema cavity with the vacuum-assisted closure device. Ann Thorac Surg 2006 Feb;81(2):723-5. | | | ✓ | Case report
(752) | Venturi ML, Attinger CE, Mesbahi AN, Hess CL, Graw KS. Mechanisms and clinical applications of the vacuum-assisted closure (VAC) Device: a review. Am J Clin Dermatol 2005;6(3):185-94. | | | ✓ | Narrative
(753) | Verhaalen Al. Isolation of an entercutaneous fistula within a vacuum-assisted wound closure system. Gen Surg 2006 Aug;33(8) | | | ✓ | Case report
(754) | Verrillo SC. Negative pressure therapy for infected sternal wounds: a literature review. J Wound Ostomy Continence Nurs 2004 Mar-Apr;31(2):72-4. | | | ✓ | Narrative
(342) | Vidrine DM, Kaler S, Rosenthal EL. A comparison of negative-pressure dressings versus Bolster and splinting of the radial forearm donor site. Otolaryngol Head Neck Surg 2005 Sep;133(3):403-6. | ✓ | KQ1, KQ3
(178) | Vikatmaa P, Juutilainen V, Kuukasjarvi P, Malmivaara A. Negative Pressure Wound Therapy: a Systematic Review on Effectiveness and Safety. Eur J Vasc Endovasc Surg 2008 Oct;36(4):438-48. | ✓ | Previous Systematic Reviews
(755) | von Gossler CM, Horch RE. Rapid aggressive soft-tissue necrosis after beetle bite can be treated by radical necrectomy and vacuum suction-assisted closure. J Cutan Med Surg 2000 Oct;4(4):219-22. | | | ✓ | Case report
(115) | Vuerstaek JD, Vainas T, Wuite J, Nelemans P, Neumann MH, Veraart JC. State-of-the-art treatment of chronic leg ulcers: A randomized controlled trial comparing vacuum-assisted closure (V.A.C.) with modern wound dressings. J Vasc Surg 2006 Nov;44(5):1029-37; discussion 1038. | ✓ | KQ1, KQ3
(756) | Wackenfors A, Gustafsson R, Sjogren J, Algotsson L, Ingemansson R, Malmsjo M. Blood flow responses in the peristernal thoracic wall during vacuum-assisted closure therapy. Ann Thorac Surg 2005 May;79(5):1724-30; discussion 1730-. | | | ✓ | Animal study
(757) | Wackenfors A, Sjogren J, Algotsson L, Gustafsson R, Ingemansson R, Malmsjo M. The effect of vacuum-assisted closure therapy on the pig femoral artery vasomotor responses. Wound Repair Regen 2004 Mar-Apr;12(2):244- | | | ✓ | Animal study
(40) | Wackenfors A, Sjogren J, Gustafsson R, Algotsson L, Ingemansson R, Malmsjo M. Effects of vacuum-assisted closure therapy on inguinal wound edge microvascular blood flow. Wound Repair Regen 2004 Nov-Dec;12(6):600-6. | | | ✓ | Animal study
(384) | Wada A, Ferreira MC, Tuma Junior P, Arrunategui G. Experience with local negative pressure (vacuum method) in the treatment of complex wounds. Sao Paulo Med J 2006 May 4;124(3):150-3. | ✓ | KQ3
(118) | Wanner MB, Schwarzl F, Strub B, Zaech GA, Pierer G. Vacuum-assisted wound closure for cheaper and more comfortable healing of pressure sores: a prospective study. Scand J Plast Reconstr Surg Hand Surg 2003;37(1):28-33. | ✓ | KQ1,KQ3
(172) | Wasiak J, Cleland H. Topical negative pressure (TNP) for partial thickness burns. Cochrane Database Syst Rev 2007;(3):CD006215. | ✓ | Previous Systematic Review
(758) | Webb LX, Lavery D, DeFranzo A. Negative pressure wound therapy in the management of orthopedic wounds. Ostomy Wound Manage 2004 Apr;50(4A Suppl):26-7. | | | ✓ | Narrative
(759) | Webb LX, Pape HC. Current thought regarding the mechanism of action of negative pressure wound therapy with reticulated open cell foam. J Orthop Trauma 2008 Nov-Dec;22(10 Suppl):S135-7. | | | ✓ | Narrative
(760) | Webb LX. New techniques in wound management: vacuum-assisted wound closure. J Am Acad Orthop Surg 2002 Sep-Oct;10(5):303-11. | | | ✓ | Narrative
(37) | Weed T, Ratliff C, Drake DB. Quantifying bacterial bioburden during negative pressure wound therapy: does the wound VAC enhance bacterial clearance. Ann Plast Surg 2004 Mar;52(3):276-9; discussion 279-80. | ✓ | KQ3
(761) | Weinfeld AB, Kelley P, Yuksel E, Tiwari P, Hsu P, Choo J, Hollier LH. Circumferential negative-pressure dressing (VAC) to bolster skin grafts in the reconstruction of the penile shaft and scrotum. Ann Plast Surg 2005 Feb;54(2):178-83. | | | ✓ | Case reports
(762) | Wessel LC, Cunningham BL. Patient with compartment syndrome of the lower extremity. J Wound Ostomy Continence Nurs 2002 Jul;29(4):210-5. | | | ✓ | Case report
(763) | Whelan C, Stewart J, Schwartz BF. Mechanics of wound healing and importance of Vacuum Assisted Closure in urology. J Urol 2005 May;173(5):1463-70. | | | ✓ | Narrative
(764) | White RA, Miki RA, Kazmier P, Anglen JO. Vacuum-assisted closure complicated by erosion and hemorrhage of the anterior tibial artery. J Orthop Trauma 2005 Jan;19(1):56-9. | | | ✓ | Case report
(765) | Whitney J, Phillips L, Aslam R, Barbul A, Gottrup F, Gould L, Robson MC, Rodeheaver G, Thomas D, Stotts N. Guidelines for the treatment of pressure ulcers. Wound Repair Regen 2006 Nov-Dec;14(6):663-79. | | | ✓ | Guideline
(116) | Wild T, Stremitzer S, Budzanowski A, Hoelzenbein T, Ludwig C,Ohrenberger G. Definition of efficiency in vacuum therapy - A randomised controlled trial comparing Redon drains with V.A.C. Therapy™. Int Wound J 2008 Dec;5(5):641-7. | ✓ | KQ2
(766) | Wilkes R, Zhao Y, Kieswetter K, Haridas B. Effects of Dressing Type on 3D Tissue Microdeformations During Negative Pressure Wound Therapy: A Computational Study. J Biomech Eng 2009 Mar;131(3):031012. | | | ✓ | Not a clinical study
(767) | Willy C, Voelker HU, Engelhardt M. Literature on the subject of vacuum therapy: review and update 2006. Eur J Trauma Emerg Surg 2007 Feb;33(1):33-9. | | | ✓ | Not relevant - not a systematic review of wound healing data
(768) | Wiseman J, Cullington JR, Schaeferle M 3rd, Beckham PH, Salisbury M, Ersek RA. Aesthetic aspects of neurofibromatosis reconstruction with the vacuum-assisted closure system. Aesthetic Plast Surg 2001 Sep-Oct;25(5):326-31. | | | ✓ | Case Report
(769) | Wolvos T. Wound instillation with negative pressure wound therapy. Ostomy Wound Manage 2005 Feb;51(2A Suppl):21S-6S. | | | ✓ | Narrative
(770) | Wolvos T. Wound instillation--the next step in negative pressure wound therapy. Lessons learned from initial experiences. Ostomy Wound Manage 2004 Nov;50(11):56-66. | | | ✓ | Narrative
(161) | Wondberg D, Larusson HJ, Metzger U, Platz A, Zingg U. Treatment of the open abdomen with the commercially available vacuum-assisted closure system in patients with abdominal sepsis : low primary closure rate. World J Surg 2008 Dec;32(12):2724-9. | ✓ | KQ3
(771) | Wong LK, Nesbit RD, Turner LA, Sargent LA. Management of a circumferential lower extremity degloving injury with the use of vacuum-assisted closure. South Med J 2006 Jun;99(6):628-30. | | | ✓ | Case Report
(75) | Wongworawat MD, Schnall SB, Holtom PD, Moon C, Schiller F. Negative pressure dressings as an alternative technique for the treatment of infected wounds. Clin Orthop Relat Res 2003 Sep;(414):45-8. | ✓ | KQ3 | | | ✓
(772) | Woo KY, Sibbald RG. Vacuum-assisted closure home care training: a process to link education to improved patient outcomes. Int Wound J 2008 Jun;5 Suppl 2:1-9. | | | ✓ | Narrative
(773) | Wound wonder. Middle East Medical 2003 May-Jun;61-5. | | | ✓ | Narrative
(774) | Wu S. Case study: treating a patient with a diabetic neuropathic ulceration. APMA News 2005 May;26(5-Suppl):19. | | | ✓ | Case Report
(775) | Wu SC, Lavery LA, Armstrong DG. Closing difficult wounds. Podiatry Today 2006 Mar;19(3):44-54. | | | ✓ | Narrative
(776) | Wu Sc, Yoon H, Armstrong DG. Therapy with advanced modalities: can it expedite healing?. Podiatry Today 2005 Sep;18(9):18-24. | | | ✓ | Narrative
(158) | Wu SH, Zecha PJ, Feitz R, Hovius SE. Vacuum therapy as an intermediate phase in wound closure: A clinical experience. Eur J Plastic Surg 2000 May;23(4):174-7. | ✓ | KQ3
(777) | Wustmann O, Ulrich HC. German patent specification. Appliance for the drainage of wounds. No. 847 475 Class 30 K Group 17 04. 1952 | | | ✓ | Not relevant
(72) | Yang CC, Chang DS, Webb LX. Vacuum-assisted closure for fasciotomy wounds following compartment syndrome of the leg. J Surg Orthop Adv 2006 Spring;15(1):19-23. | ✓ | KQ1 | | | ✓
(778) | Yoong S, Dunne G, Cochrane J, Lee B, Lee J. Vacuum-assisted closure for the treatment of parastomal skin necrosis: a novel approach to an unusual complication. Report of a case. Dis Colon Rectum 2008 Oct;51(10):1577-9. | | | ✓ | Case report
(779) | Yousaf M, Witherow A, Gardiner KR, Gilliland R. Use of vacuum-assisted closure for healing of a persistent perineal sinus following panproctocolectomy: report of a case. Dis Colon Rectum 2004 Aug;47(8):1403-7; discussion 1407-8. | | | ✓ | Case report
(780) | Yuan-Innes MJ, Temple CL, Lacey MS. Vacuum-assisted wound closure: a new approach to spinal wounds with exposed hardware. Spine 2001 Feb 1;26(3):E30-3. | | | ✓ | Fewer than five patients
(781) | Yuh DD, Albaugh M, Ullrich S, Conte JV. Treatment of ventricular assist device driveline infection with vacuum-assisted closure system. Ann Thorac Surg 2005 Oct;80(4):1493-5. | | | ✓ | Case report
(782) | Zamierowski D. United States Patent. Wound dressing and treatment method. No. 4969880. 1990. | | | ✓ | Patent
(783) | Zehnder SW, Place HM. Vacuum-assisted wound closure in postoperative spinal wound infection. Orthopedics 2007 Apr;30(4):267-72. | | | ✓ | Narrative
(784) | Zutt M, Haas E, Kruger U, Distler M, Neumann C. Successful use of vacuum-assisted closure therapy for leg ulcers caused by occluding vasculopathy and inflammatory vascular diseases—a case series. Dermatology 2007;214(4):319-24. | | | ✓ | Case reports

Figure 8 Disposition of Submission by CMS

Note: Language has been corrected to reflect screening of meeting abstracts, poster presentations and other documents in addition to abstracts and full articles.

Figure 8 is an attrition diagram that depicts the status of documents that the Centers for Medicare and Medicaid Services (CMS) submitted for possible inclusion in the report. The diagram begins with a box outlining the total submission of 67 documents. Several boxes ensue which are connected by arrows going from top to bottom which follow the submissions as they are being screened for possible inclusion in the report. In the first frame, we compare CMS’s submission to submissions by other interested stakeholders and remove any duplicates. CMS had 5 duplicate submissions. An arrow leads from the 62 Unique Submissions to the Initial Screening Phase where documents may be excluded, used in our Background Section or passed to the next level. In this instance, 37 documents were identified for exclusion. One was a “personal communication” and 36 were “other documents not relevant to the report.” 15 documents were identified for inclusion in our Background Section. The path then follows the 10 full articles remaining. During this phase of screening we do a more extensive screening which is again based on our pre-determined inclusion/exclusion criteria. See our Methods Section for additional information on the criteria. Ten full articles were excluded during this evaluation phase. Two were narrative reviews. Eight were excluded for Other Reasons which may include “inclusion of healthy subjects”, “lack of reporting wound healing outcomes” or “patients treated with dual therapies.” Due to the exclusion of all 67 submissions, zero submissions remained for possible inclusion in the report. Note: Language has been corrected to reflect screening of meeting abstracts, poster presentations and other documents in addition to abstracts of full articles.

Table 45 Status of CMS submission: Publications

Reference Number | Reference | Included | Placement in Report | Excluded | Reason for Exclusion | Included but Not Identified in ECRI Search
(792) | Biblehimer HL. Dealing with a wound that drains 1.5 liters a day. RN 1986 Aug;49(8):21-3. | | | ✓ | Case study/Technical description
(114) | Braakenburg A, Obdeijn MC, Feitz R, van Rooij IA, van Griethuysen AJ, Klinkenbijl JH. The clinical efficacy and cost effectiveness of the vacuum-assisted closure technique in the management of acute and chronic wounds: a randomized controlled trial. Plast Reconstr Surg 2006 Aug;118(2):390-7; discussion 398-400. | ✓ | KQ1, KQ3
(442) | Chariker ME, Jeter KF, Tintle TE, Bottsford JE. Effective management of incisional and cutaneous fistulae with close suction wound drainage. Contemp Surg 1989 Jun;34:59-63. | | | ✓ | Case series/Technical description
(793) | Coleman D. No wound is too big for resourceful nurses. RN 1988 Dec;51(12):22-5. | | | ✓ | Case study/Technical description
(110) | Ford C, Reinhard E, Yeh D, Syrek D, de las Morenas A, Bergman S, Williams S, Hamori C. Interim analysis of a prospective randomized trial of vacuum-assisted closure versus the healthpoint system in the management of pressure ulcers. Ann Plast Surg 2002;49(1):7 p. | ✓ | KQ1, KQ3
(794) | Garcia-Rinaldi R, Defore WW Jr, Green ZD, McBride C. Improving the efficiency of wound drainage catheters. Am J Surg 1975 Sep;130(3):372-3. | | | ✓ | Case study/Technical description
(795) | Miller MS, Lowery CA. Negative pressure wound therapy: ‘a rose by any other name’. Ostomy Wound Manage 2005 Mar;51(3):44-6, 48-9. | | | ✓ | Narrative review
(796) | Q209 hospital purchasing manager survey. Charlotte (NC): Wachovia Capital Markets, LLC; 2009 Apr 7. 13 p. | | | ✓ | Survey
(797) | Q2 2008 wound care nurse survey. Charlotte (NC): Wachovia Capital Markets, LLC; 2008 May 21. 13 p. | | | ✓ | Survey
(798) | Q208 hospital purchasing manager survey. Charlotte (NC): Wachovia Capital Markets, LLC; 2008 Apr 21. 16 p. | | | ✓ | Survey
(799) | Q4 2007 wound care nurse survey. Charlotte (NC): Wachovia Capital Markets, LLC; 2007 Dec 6. 11 p. | | | ✓ | Survey
(800) | Q4 2008 wound care nurse survey. Charlotte (NC): Wachovia Capital Markets, LLC; 2008 Dec 1. 15 p. | | | ✓ | Survey
(801) | RAFFL AB. The use of negative pressure under skin flaps after radical mastectomy. Ann Surg 1952 Dec;136(6):1048. | | | ✓ | Case study/Technical description
(802) | Ramirez OM, Granick MS, Futrell JW. Optimal wound healing under Op-Site dressing. Plast Reconstr Surg 1984 Mar;73(3):474-5. | | | ✓ | Case study/Technical description
(182) | Samson D, Lefevre F. Wound-healing technologies: low-level laser and vacuum-assisted closure. Rockville (MD): Agency for Healthcare Research and Quality (AHRQ); 2004. | ✓ | Previous Systematic Reviews
(34) | Saxena V, Hwang CW, Huang S, Eichbaum Q, Ingber D, Orgill DP. Vacuum-assisted closure: microdeformations of wounds and cell proliferation. Plast Reconstr Surg 2004 Oct;114(5):1086-96; discussion 1097-. | | | ✓ | Case study/Technical description
(803) | Schwab PM, Kelly KA. Primary closure of the perineal wound after proctectomy. A new technique. Mayo Clin Proc 1974 Mar;49(3):176-9. | | | ✓ | Case study/Technical description
(312) | Sibbald RG, Mahoney J, V.A.C. Therapy Canadian Consensus Group. A consensus report on the use of vacuum-assisted closure in chronic, difficult-to-heal wounds. Ostomy Wound Manage 2003 Nov;49(11):52-66. | ✓ | | ✓ | Narrative
(804) | VanDuren T. (Case Manager. University of Utah Health Plans & Healthy-U). BlueSky Versatile One. Case study. University of Utah. 2004 Jan 13. 7 p. | | | ✓ | Case study
(805) | Wolvos T. Feature: wound instillation-the next step in negative pressure wound therapy. Lessons learned from initial experiences. Ostomy Wound Manag 2004;50(11):56-66. | | | ✓ | Case study/Technical description

KQ Key question

Table 46 Status of CMS submission: Government Documents

Reference Number | Reference | Disposition in Report
(806) | Beninger P. (Director. Division of General and Restorative Devices. Office of Device Evaluation. Center for Devices and Radiological Health). 510(k) notification of intent to market VACPLUS. K945062. 1995 Mar 14. 50 p. | Used as background information
(807) | Bowman J. Personal Communication. FDA account of NPNT safety issues as summarized by CMS. 2005. 1 p. | Not used in this report
(808) | Dillard J. (Acting Director. Division of General and Restorative Devices. Office of Device Evaluation. Center for Devices and Radiological Health). Approval of 510(k) notification of intent to market. V.A.C. plus. K992448. 2000 Jan 18. 3 p. | Used as background information
(809) | Food and Drug Administration, Center for Devices and Radiological Health. Guidance document for powered suction pump 510(k)s. Rockville (MD): Food and Drug Administration, Center for Devices and Radiological Health; 1998. 5 p. | Not used in this report
(810) | Food and Drug Administration, Center for Devices and Radiological Health. 510(k) premarket notification database. Annelid. K940886. [internet]. Silver Spring (MD): Food and Drug Administration, Center for Devices and Radiological Health; 2002 Nov 5 [updated 2009 Jan 16]; [accessed 2002 Nov 5]. [1 p]. Available: http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfPMN/pmn.cfm?ID=96760. | Used as background information
(811) | Food and Drug Administration, Center for Devices and Radiological Health. 510(k) premarket notification database. Vacuum assisted closure. K021500. [internet]. Silver Spring (MD): Food and Drug Administration, Center for Devices and Radiological Health; 2002 Dec 20 [accessed 2005 Nov 11]. [5 p]. Available: http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfPMN/pmn.cfm?ID=8137. | Used as background information
(812) | Food and Drug Administration. 510 (k) summary statement. V.A.C. plus device, 510(k) No. K945062. [database online]. Silver Spring (MD): Food and Drug Administration; 2000 Jan 18 [2 p]. | Used as background information
(813) | Hake C. (Director, CMS HCPCS Workgroup). Personal communication. Request to establish a code for portable powered suction pump, trade name: versatile wound vacuum system. 2005. 2 p. | Not used in this report
(814) | Hake C. (Director. CMS HCPCS Workgroup). Personal Communication. Request to establish three new codes for negative pressure wound therapy (NPWT) pumps, canisters and dressings which provide wound site pressure feedback. 2006. 2 p. | Not used in this report
(815) | Hake C. Doctors interviewed by the house ways and means reportedly support foam as superior to gauze. 2008. 3 p. | Not used in this report
(816) | Harbour J, Kinetic Concepts, Inc. 510 (k) Summary. Ambulatory Suction Pump. 1997 May 22. 5 p. | Used as background information
(817) | Smith T. Kinetic Concepts patent not infringed. 2006. 1 p. | Not used in this report
(818) | United States patent and trademark office. V.A.C. United States Patent and Trademark Office; 1996 Jun 25. 33 p. | Not used in this report
(819) | Wilson C. Personal communication. FW: Alliance for LTC on Wound VAC/NPWT. 2006. 2 p. | Not used in this report
(820) | Witten C. (Director. Division of General and Restorative Devices, Office of Device Evaluation, Center for Devices and Radiological Health). Approval of 510(k) notification of intent to market. AmbuVAC Device. 1997 May 22. 3 p. | Used as background information
(821) | Witten C. (Director. Division of General, Restorative and Neurological Devices, Office of Device Evaluation, Center for Devices and Radiological Health). Approval of 510(k) notification of intent to market. V.A.C. family of devices: mini V.A.C. V.A.C. Freedom V.A.C. ATS. K032310. 2003 Oct 10. 5 p. | Used as background information
(822) | Witten C. (Director. Division of General, Restorative and Neurological Devices. Office of Device Evaluation. Center for Devices and Radiological Health). 510(k) notification of intent to market Versatile 1 Wound Vacuum System. K042134. 2004 Nov 15. 7 p. | Used as background information
(823) | Witten C. (Director. Division of General, Restorative and Neurological Devices, Office of Device Evaluation, Center for Devices and Radiological Health). Approval of 510(k) notification of intent to market. V.A.C. granufoam silver dressing. K041642. 2005 Jan 25. 3 p. | Used as background information

Table 47 Status of CMS submission: Miscellaneous Material

Reference Number | Reference | Disposition in Report
(824) | AllegroMedical.com. Invacare aspirator product description. [internet]. Mesa (AZ): AllegroMedical.com; 2005 [accessed 2005 Aug 15]. Available: http://www.allegromedical.com/oxygen_therapy/nebulizers/invacare/aspirator.P189899. | Not used in this report
(825) | BlueSky Medical Group, Inc. Negative pressure wound therapy. V1STA Versatile 1 portable. Carlsbad (CA): BlueSky Medical Group, Inc.; 2005. 4 p. – product brochure | Used as background information
(826) | Hake C. (Director, CMS’ HCPCS Workgroup). Personal communication. Negative pressure wound therapy devices. 2008 Jan 23. 5 p. Includes list of materials submitted by CMS for this report. | Personal communication
(827) | Kinetic Concepts, Inc. Advanced Dressings. Dedicated dressings for specific wound applications. San Antonio (TX): Kinetic Concepts, Inc. (KCI); 2005. 6 p. – product brochure | Used as background information
(828) | Kinetic Concepts, Inc. V.A.C. A portable system for advanced wound healing. San Antonio (TX): Kinetic Concepts, Inc. (KCI); 2005. 6 p. – product brochure | Used as background information
(829) | Lewis P. Smith & Nephews acquires BlueSky medical group. Remington Rep 2007; news release | Not used in this report
(830) | Medela, Inc. Medela Clario home care pump. Product Description. [internet]. MCHenry (IL): Medela, Inc.; 2005 [accessed 2005 Sep 16]. [1 p]. – product brochure | Used as background information
(831) | United Publications, Inc. Are negative pressure wound therapy codes created equal?. [internet]. Yarmouth (ME): United Publications, Inc.; 2009 [accessed 2009 Jan 12]. [3 p]. – news report | Not used in this report
| V.A.C. Annotated Peer-reviewed Article Bibliography prepared by KCI | We examined the bibliography for studies not identified in our searches
(832) | Weston R. (President, BlueSky Medical). Personal Communication. BlueSky medical wound drainage kit. 2003. 5 p. – also included product information and brochure | Used as background information

Table 48 Status of CMS submission: Material from KCI or related to KCI

Reference Number | Reference | Disposition in Report
(833) | Cynthia S. Hake. CMS meeting with KCI. 2005. 68 p. KCI presentation to CMS comparing V.A.C. to BlueSky Versatile 1 | Not used in this report
(834) | House small business subcommittee on rural and urban entrepreneurship. Statement by Linwood A. Staub, President, Global V.A.C therapy, Kinetic Concepts, Inc. (KCI) on behalf of the Advanced Medical Technology Association (AdvaMed). Washington (DC): U.S. House of Representatives; 2008 May 21. 11 p. Also available: http://www.house.gov/smbiz/hearings/hearing-05-21-08-DME/Staub.pdf. | Not used in this report
(835) | Kinetic Concepts, Inc. (KCI). Personal Communication. KCI comments on CMS’ preliminary decision to include BlueSky and KCI NPNT devices in the same code. 2005. 20 p. | Not used in this report
(836) | Kinetic Concepts, Inc. Personal communication. Comments following the June 23, 2005 CMS HCPCS workgroup meeting agenda item #11; HCPCS request #05.09. 2005. 3 p. | Not used in this report
(836) | Kinetic Concepts, Inc. Personal communication. Comments following the June 23, 2005 CMS HCPCS workgroup meeting agenda item #11; HCPCS request #05.09. 2005. 3 p. KCI comments regarding BlueSky V1 | Not used in this report
(837) | Larichev A. Vacuum therapy in wounds and wound infection: negative pressure wound therapy.Carlsbad (CA): BlueSky Publication; 2005 [2 p]. - page from Library of Congress Online Catalog | Not used in this report
(838) | Matherne C. (Senior Attorney. LSU, Health Sciences Center). Personal Communication. V.A.C. System. Medical center of Louisiana. 2001 Sep 21. 1 p. | Not used in this report
(839) | Morris S. (Vice President, Health policy & Government Affairs KCI). Personal communication. Public meeting registration for KCI. 2006. 1 p. | Not used in this report
(840) | Morris S. (Vice President, Reimbursement Policy and Compliance). Personal Communication. HCPCS code request for negative pressure wound therapy pumps. 2006. 4 p. | Not used in this report
(841) | Morris S. Additional V1 failures/VAC rescues. 2006. 2 p. Case reports submitted by KCI to CMS | Not used in this report
(842) | Moton T. (Briefing Coordinator). Meeting with Kinetic Concepts Incorporated (KCL). 2006. 30 p. KCI presentation to CMS | Not used in this report
(843) | NPWT HCPCS coding: KCI V.A.C. therapy system. Update for the Centers for Medicare and Medicaid Services. San Antonio (TX): Kinetic Concepts, Inc. (KCI); 2006. 173 p. KCI submission to CMS | Not used in this report
(844) | Quirk, W. Personal Communication. VAC plus premarket notification No. K945062. 2002 Oct 22. 4 p. Letter sent from KCI to BlueSky. | Not used in this report
(845) | Schroeder, W. (Vice President, Medical Department, Kinetic Concepts, Inc.). Misuse of the V.A.C technology. 2000 Feb 01. 2 p. | Not used in this report
(846) | Tarplin R. Letters that raise concerns about the CMS HCPCS coding decision. 2006. 83 p. Letters from Congress and clinicians sent to CMS. | Not used in this report

Table 49 Status of CMS submission: Material from BlueSky or related to BlueSky

Reference Number | Reference | Disposition in Report
(847) | BlueSky Medical Group, Inc. HCPSC coding request Versatile 1 wound vacuum system. Carlsbad (CA): BlueSky Medical Group, Inc.; 2005. 5 p. – BlueSky presentation to CMS | Not used in this report
(848) | BlueSky Medical. Information for Centers for Medicare and Medicaid Services on negative pressure wound therapy. Baltimore (MD): BlueSky Medical; 2002 Oct 25. 45 p. – package of information sent to CMS by BlueSky Medical | Not used in this report
(849) | Guimond J. (Marketing & Sales. BlueSky Medical Group, Inc.). Personal Communication. BlueSky’s product line, VISTA Versatile 1 portable. 2006. 3 p. – announcement about failure of KCI infringement lawsuit | Not used in this report
(850) | Weston R. (President. BlueSky Medical Group, Inc.). Personal Communication. Petition and request to decrease reimbursement levels. 2002 Jun 11. 2 p. | Not used in this report
(851) | Weston R. Personal communication. BlueSky’s 2005 HCPCS code request. 2004. 5 p. | Not used in this report

Figure 9 Disposition of Submission by ConvaTec

Note: Language has been corrected to reflect screening of meeting abstracts, poster presentations and other documents in addition to abstracts and full articles.

Figure 9 is an attrition diagram that depicts the status of documents that ConvaTec submitted for possible inclusion in the report. The diagram begins with a box outlining the total submission of three documents. Several boxes ensue which are connected by arrows going from top to bottom which follow the submissions as they are being screened for possible inclusion in the report. In the first frame, we compare ConvaTec’s submission to submissions by other interested stakeholders and remove any duplicates. ConvaTec had one duplicate submission. An arrow leads from the two Unique Submissions to the Initial Screening Phase where documents may be excluded, used in our Background Section or passed to the next level. In this instance, one document was identified as a personal communication and excluded and one document was identified for inclusion in our Background Section. Due to the exclusion of all three submissions, zero submissions remained for possible inclusion in the report. Note: Language has been corrected to reflect screening of meeting abstracts, poster presentations and other documents in addition to abstracts of full articles.

Table 50 Status of Submission by ConvaTec

Reference Number | Reference | Included | Placement in Report | Disposition in Report
(852) | Engenex Advanced Negative Pressure Wound Therapy System. Instructions for use. Skillman (NJ): ConvaTec, Inc.; 2008 Dec. 33 p. – product information | ✓ | Background
(853) | Rolley J. (Vice President, Global Government Affairs and Health Policy, ConvaTec). Personal communication. 2009 Feb 6. 3 p. | | | Not included in this report – personal communication
(732) | Summaries of current clinical evidence Engenex NPWT system. Skillman (NJ): ConvaTec, Inc.; 3 p.; - ConvaTec provided 6 references to poster presentations at wound care meetings. A total of 14 patients of various wound types were treated with the Engenex® NPWT system using the Bio-Dome™ dressing set. | | | Not included in this report – poster presentation

Figure 10 Disposition of Submission by Individuals

Note: Language has been corrected to reflect screening of meeting abstracts, poster presentations and other documents in addition to abstracts and full articles.

Figure 10 is an attrition diagram that depicts the status of documents that individual parties submitted for possible inclusion in the report. The diagram begins with a box outlining the total submission of 39 documents. Several boxes ensue which are connected by arrows going from top to bottom which follow the submissions as they are being screened for possible inclusion in the report. In the first frame, we compare the Individuals submission to submissions by other interested stakeholders and remove any duplicates. The individual submissions included 14 duplicate submissions. An arrow leads from the 25 Unique Submissions to the Initial Screening Phase where documents may be excluded, used in our Background Section or passed to the next level. In this instance, 20 documents were identified for exclusion. One was a “case report, abstract or poster presentation”; and 19 were “personal communications.” Zero documents were identified for inclusion in our Background Section. The path then follows the five full articles remaining. During this phase of screening we do a more extensive screening which is again based on our pre-determined inclusion/exclusion criteria. See our Methods Section for additional information on the criteria. Four full articles were excluded during this evaluation phase. One included a duplicate study population, one was a narrative review, one had no relevant outcomes and one was excluded for Other Reasons which may include “inclusion of healthy subjects”, “lack of reporting wound healing outcomes” or “patients treated with dual therapies.” One study met the inclusion criteria and was included in Key Question 1. Note: Language has been corrected to reflect screening of meeting abstracts, poster presentations and other documents in addition to abstracts of full articles.

Table 51 Status of Submission by Individuals

Reference Number | Reference | Included | Placement in Report | Excluded | Reason for Exclusion | Included but Not identified in ECRI Search
(854) | Andersen C. (Chief Vascular/Endovascular/LimbPreservation Surgery Service, Madigan Army Medical Center. Ft. Lewis, WA). Personal communication. Re: AHRQ review of NPWT. 2009 Feb 6. 2 p. | | | ✓ | Personal communication
(855) | Annest S. (MD, FACS. Denver, CO). Personal communication. NPWT Comments from Annest. 2009 Feb 3. 1 p. | | | ✓ | Personal communication
(195) | Armstrong DG, Lavery LA, Diabetic Foot Study Consortium. Negative pressure wound therapy after partial diabetic foot amputation: a multicentre, randomised controlled trial. Lancet 2005 Nov 12;366(9498):1704-10. | | | ✓ | Study population reported in(109)
(856) | Arnold DA. (Midwest Hernia Institute, P.C.). Personal communication. Comments on NPWT from Midwest Hernia Institute. 2009 Jan 30. 1 p. | | | ✓ | Personal communication
(857) | Bernstein BH. (DPM, FACFAS). Personal communication. Comparison of types of NPWT, limb salvage specialist’s point of view. 2009 Feb 4. 2 p. | | | ✓ | Personal communication
(108) | Blume PA, Walters J, Payne W, Ayala J, Lantis J. Comparison of negative pressure wound therapy using vacuum-assisted closure with advanced moist wound therapy in the treatment of diabetic foot ulcers: a multicenter randomized controlled trial. Diabetes Care 2008 Apr;31(4):631-6. | ✓ | KQ1, KQ3
(858) | Chaiken N. (Wound Ostomy Continence, Swedish Covenant Hospital). Personal communication. Comments on wound VACs. 2009 Feb 3. 1 p. | | | ✓ | Personal communication
(859) | Clinical V.A.C. therapy slides from the practice of Dr. C. Douglas Fogg, MD, FACS. New Bedford (MA): New Bedford Rehabilitation Hospital Wound Care Center; 14 p. | | | ✓ | Case studies
(860) | Coliauta EA. Personal communication. Support of KCI wound VAC system. 2009 Feb 6. 1 p. | | | ✓ | Personal communication
(861) | Cummings SF. (Director, Wound Recovery and Hyperbaric Medicine Service, Kent Hospital. Warwick, RI). Personal communication. NPWT Response from Kent Hospital. 2009 Jan 30. 1 p. | | | ✓ | Personal communication
(862) | DosRemedios E. (Clinical Assistant Professor of Orthopaedic Surgery, Warren Alpert School of Medicine at Brown University. Providence, Rhode Island.). Personal communication. Comments on NPWT from Brown University. 2009 Feb 2. 1 p. | | | ✓ | Personal communication
(863) | Fetterly MA. (RNFA, CPSN, CNOR. O Plastic & Reconstructive Surgery. Reno, NV). To AHRQ in regards to KCI VAC devices. 2009 Jan 29. 1 p. | | | ✓ | Personal communication
(362) | Fleck T, Kickinger B, Moidl R, Waldenberger F, Wolner E, Grabenwoger M, Wisser W. Management of open chest and delayed sternal closure with the vacuum assisted closure system: Preliminary experience. Interact Cardiovasc Thorac Surg 2008 Oct;7(5):801-4. | ✓ | KQ3
(496) | Fleck T, Moidl R, Giovanoli P, Aszmann O, Bartunek A, Blacky A, Grabenwoger M, Wolner E. A conclusion from the first 125 patients treated with the vacuum assisted closure system for postoperative sternal wound infection. Interact Cardiovasc Thorac Surg 2006 Apr;5(2):145-8. | | | ✓ | Narrative
(497) | Fleck T, Simon P, Burda G, Wolner E, Wollenek G. Vacuum assisted closure therapy for the treatment of sternal wound infections in neonates and small infants. Interact Cardiovasc Thorac Surg 2006 Jun;5(3):285-8. | | | ✓ | Fewer than five patients
(864) | Fleck T. (Department of Cardiothoracic Surgery, AKH Vienna, Medical University of Vienna). Response to the review of NPWT of the AHRQ. 2009 Jan 29. 1 p.; - Dr. Fleck provided a list of 12 studies and abstracts. These were reviewed for possible inclusion. | | | ✓ | Five studies with Dr. Fleck as the first author were considered for this report. Two were included(362,380) and three were excluded.(496-498)
(380) | Fleck TM, Fleck M, Moidl R, Czerny M, Koller R, Giovanoli P, Hiesmayer MJ, Zimpfer D, Wolner E, Grabenwoger M. The vacuum-assisted closure system for the treatment of deep sternal wound infections after cardiac surgery. Ann Thorac Surg 2002 Nov 1;74(5):1596-1600. | ✓ | KQ3
(498) | Fleck TM, Koller R, Giovanoli P, Moidl R, Czerny M, Fleck M, Wolner E, Grabenwoger M. Primary or delayed closure for the treatment of poststernotomy wound infections. Ann Plast Surg 2004 Mar;52(3):310-4. | | | ✓ | Not relevant
(865) | Fogg CD. (Medical Director, New Bedford Rehabilitation Hospital Wound Care Center). Advocacy for V.A.C. therapy. 1 p. | | | ✓ | Personal communication
(866) | Gestring M, Manaker S, Wilson KC. Vacuum assisted wound closure [unpublished]. 2008 Apr 10. 7 p. | | | ✓ | Narrative
(341) | Lavery LA, Boulton AJ, Niezgoda JA, Sheehan P. A comparison of diabetic foot ulcer outcomes using negative pressure wound therapy versus historical standard of care. Int Wound J 2007 Jun;4(2):103-13. | ✓ | KQ1, KQ3
(867) | Marston WA. (Professor and Chief, Division of Vascular Surgery, University of North Carolina School of Medicine. Chapel Hill, NC). Personal communication. Review of Negative Pressure Wound Therapy devices. 2009 Feb 3. 1 p. | | | ✓ | Personal communication
(868) | Mooney TM. (DPM, AACFAS, Western Nevada Foot & Ankle Center, LLC. Reno, NV). Personal communication. 2009. 1 p. | | | ✓ | Personal communication
(869) | Nelson G. (Program Coordinator, Advanced Wound Center, Rogue Valley Medical Center. Medford, OR). Personal communication. Concerns about negative pressure therapy. 2009 Feb 5. 2 p. | | | ✓ | Personal communication
(870) | Pelham FR. (Department of Orthopedic Surgery, Musculoskeletal Research Center, New York University Hospital for Joint Diseases, New York, NY). Personal communication. Re: VAC therapy. 2009 Feb 6. 13 p.; - Dr. Pelham provided a manuscript describing a retrospective case-series of patients with stage III and IV pressure ulcers treated with V.A.C. therapy, but requested that the data not be shared with the public. | | | ✓ | The study provided by Dr. Pelham was not included in the report. The study did not address Key Questions 1, 2, or 4. The study could have been considered under Key Question 3, but the study did not report that they collected data on complications.
(671) | Poulakidas S, Kowal-Vern A. Facilitating residual wound closure after partial graft loss with vacuum assisted closure therapy. J Burn Care Res 2008 Jul-Aug;29(4):663-5. | | | ✓ | Case report
(871) | Ritzman D. (Fremont-Rideout Home Health). Personal communication. HCPS code for KCI Wound Vac. 2009 Jan 31. 1 p. | | | ✓ | Personal communication
(872) | Robins M. (Wound Care Clinic at Utah Valley Regional Medical Center). NPWT study. 2009 Feb 6. 4 p.; - Dr. Robins provided a review of NPWT(866) and three publications.(174,183,195) | | | ✓ | A review of NPWT(866) and three publications.(174,183,195)
(308) | Schlatterer D, Hirshorn K. Negative pressure wound therapy with reticulated open cell foam-adjunctive treatment in the management of traumatic wounds of the leg: a review of the literature. J Orthop Trauma 2008 Nov–Dec;22(10 Suppl):S152-60. | | | ✓ | Review article
(873) | Schultz G. (Professor, Department of Obstetrics and Gynecology, Institute for Wound Research, University of Florida. Gainesville, FL). Personal communication. Re: scientific data on effects of NPWT. 2009 Feb 6. 1 p.; - Dr. Schultz provided references to two publications. | | | ✓ | The publications were not used in this report because they did not report wound healing outcomes considered in this report
(874) | Snow R. (Director, Baptist Wound Care & Hyperbaric Medicine Program @ Princeton). Personal communication Re: negative pressure Rx. 2009 Feb 3. 1 p. | | | ✓ | Personal communication
(738) | Tarkin IS. The versatility of negative pressure wound therapy with reticulated open cell foam for soft tissue management after severe musculoskeletal trauma. J Orthop Trauma 2008 Nov–Dec;22(10 Suppl):S146-51. | | | ✓ | Case reports
(875) | Tedford S. (WOCN Program Coordinator, Sutter VNA & Hospice). Personal communication. HCPCS code response from WOCN. 2009 Jan 30. 1 p. | | | ✓ | Personal communication
(106) | Timmers MS, Graafland N, Bernards AT, Nelissen RGHH, Van Dissel JT, Jukema GN. Negative pressure wound treatment with polyvinyl alcohol foam and polyhexanide antiseptic solution instillation in posttraumatic osteomyelitis. Wound Repair Regen 2009 Mar-Apr;17(2):278-86. | ✓ | Key Question 1 | | | ✓
(174) | Ubbink DT, Westerbos SJ, Evans D, Land L, Vermeulen H. Topical negative pressure for treating chronic wounds (Review). In: Cochrane Database of Systematic Reviews [internet]. Issue 3. Hoboken (NJ): John Wiley & Sons, Ltd.; 2008 [Art. No.: CD001898]. | ✓ | Previous Systematic Reviews
(183) | Ubbink DT, Westerbos SJ, Nelson EA, Vermeulen H. A systematic review of topical negative pressure therapy for acute and chronic wounds. Br J Surg 2008 Jun;95(6):685-92. | ✓ | Previous Systematic Reviews
(876) | Ward RS. (President, American Physical Therapy Association. Alexandria, VA). APTA’s response to AHRQ’s request for information on Negative Pressure Wound Therapy. 2009 Feb 4. 2 p. Dr. Ward provided copies of six publications, all identified by our searches; three were included in the report and three were excluded.; - Included publications:(75,108,341); - Excluded publications:; - (738) – case reports; - (308) – review article; - (671) – case report | | | ✓ | Cover letter
(75) | Wongworawat MD, Schnall SB, Holtom PD, Moon C, Schiller F. Negative pressure dressings as an alternative technique for the treatment of infected wounds. Clin Orthop Relat Res 2003 Sep;(414):45-8. | ✓ | KQ3
(877) | Yee EM. (Sierra Infectious Diseases, Reno, NV). Personal communication. Comments on proposed code change. 2009 Jan 30. 1 p. | | | ✓ | Personal communication

Figure 11 Disposition of Submission by Medela, Inc.

Note: Language has been corrected to reflect screening of meeting abstracts, poster presentations and other documents in addition to abstracts and full articles.

Figure 11 is an attrition diagram that depicts the status of documents that Medela Inc. submitted for possible inclusion in the report. The diagram begins with a box outlining the total submission of 10 documents. Several boxes ensue which are connected by arrows going from top to bottom which follow the submissions as they are being screened for possible inclusion in the report. In the first frame, we compare Medela’s submission to submissions by other interested stakeholders and remove any duplicates. Medela had zero duplicate submissions. An arrow leads from the 10 Unique Submissions to the Initial Screening Phase where documents may be excluded, used in our Background Section or passed to the next level. In this instance, 1 document was identified for exclusion due to “personal communication”. Zero documents were identified for inclusion in our Background Section. The path then follows the 9 full articles remaining. During this phase of screening we do a more extensive screening which is again based on our pre-determined inclusion/exclusion criteria. See our Methods Section for additional information on the criteria. 9 full articles were excluded during this evaluation phase; 2 were animal studies; 2 were narrative reviews; and 5 were excluded for Other Reasons which may include “inclusion of healthy subjects”, “lack of reporting wound healing outcomes” or “patients treated with dual therapies.” Due to the exclusion of all 9 submissions at this level, zero submissions remained for possible inclusion in the report. Note: Language has been corrected to reflect screening of meeting abstracts, poster presentations and other documents in addition to abstracts of full articles.

Table 52 Status of Submission by Medela

Reference Number | Reference | Included | Excluded | Reason for Exclusion
(878) | Best practice statement: gauze-based negative pressure wound therapy. HealthComm UK Limited; 2008 Nov. 19 p. | | ✓ | Narrative review
(879) | Case study 2: Four challenging LE wounds: can these chronic wounds be healed with use of negative pressure wound therapy. McHenry (IL): Medela Healthcare, Inc.; 1 p. | | ✓ | Case study
(880) | Case study: gauze-based NPWT: various wound types from different wound locations. McHenry (IL): Medela Healthcare, Inc.; 1 p. | | ✓ | Case study
(881) | Comparative analysis of gauze-based NPWT systems versus foam-based NPWT systems. McHenry (IL): Medela Healthcare, Inc.; 7 p. – A short description of a retrospective analysis of 55 patients treated with the Invia® wound Therapy system. | | ✓ | Insufficient reporting of study design and results
(882) | Gauze based clinical study 1: Safety and effectiveness of the Invia (vacuum) wound care system versus a saline wet-to-dry gauze dressing. McHenry (IL): Medela Healthcare, Inc.; 5 p. | | ✓ | Protocol for planned RCT
(883) | Gauze based clinical study 2: Gauze versus foam for topical negative pressure wound therapy (NPWT) in postoperative subcutaneous wound infections after abdominal operations. First clinical observations. McHenry (IL): Medela Healthcare, Inc.; 22 p. | | ✓ | Case study
(884) | Long C. (Director, Medela Healthcare. McHenry, IL). Submission letter from Medlea Healthcare regarding NPWT. 2009 Feb 3. 1 p. – cover letter | | ✓ | Cover letter
(885) | McHenry (IL): Medela Healthcare; 2009. Introduction to NPWT. p. 3. – short discussion of NPWT | | ✓ | Narrative
(886) | Pre-clinical study: a comparison of various dressings combined with NPWT. McHenry (IL): Medela Healthcare, Inc.; 2008. 15 p. Also available: http://www.etrs.org/malta3.html. | | ✓ | Animal study
(887) | The effect of an antimicrobial gauze dressing impregnated with 0.2% polyhexamethylene biguanide (PHMB) as a barrier to prevent pseudomonas aeruginosa wound invasion. McHenry (IL): Medela Healthcare, Inc.; 7 p. | | ✓ | Animal study

Figure 12 Disposition of Submission by Prospera

Note: Language has been corrected to reflect screening of meeting abstracts, poster presentations and other documents in addition to abstracts and full articles.

Figure 12 is an attrition diagram that depicts the status of documents that Prospera submitted for possible inclusion in the report. The diagram begins with a box outlining the total submission of 56 documents. Several boxes ensue which are connected by arrows going from top to bottom which follow the submissions as they are being screened for possible inclusion in the report. In the first frame, we compare Prospera’s submission to submissions by other interested stakeholders and remove any duplicates. Prospera had 19 duplicate submissions. An arrow leads from the 37 Unique Submissions to the Initial Screening Phase where documents may be excluded, used in our Background Section or passed to the next level. In this instance, nine documents were identified for exclusion. One was product information, three were personal communications and five were “other documents not relevant to the report”. Four documents were identified for inclusion in our Background Section. The path then follows the 24 full articles remaining. During this phase of screening we do a more extensive screening which is again based on our pre-determined inclusion/exclusion criteria. See our Methods Section for additional information on the criteria. 24 full articles were excluded during this evaluation phase; five were animal studies; six were narrative reviews; one was not a clinical study; six did not include a NPWT device and six were excluded for Other Reasons which may include “inclusion of healthy subjects”, “lack of reporting wound healing outcomes” or “patients treated with dual therapies.” Due to the exclusion of all 24 submissions at this level, zero submissions remained for possible inclusion in the report. Note: Language has been corrected to reflect screening of meeting abstracts, poster presentations and other documents in addition to abstracts of full articles.

Table 53 Status of Submissions by Prospera

Reference Number | Reference | Included | Placement in Report | Excluded | Reason for Exclusion | Included but Not identified in ECRI Search
(888) | Advancing the art and science of NPWT. Fort Worth (TX): Prospera; 2008. CD-ROM. – product information | | | ✓ | Product Information
(889) | Ahearn C. (Director of Clinical Services, Prospera). Prospera response to ECRI Institute’s December 20, 2008 request for information regarding our Negative Pressure Wound Therapy system. 2009 Feb 2. 1 p. – cover letter | | | ✓ | Cover letter
(890) | Allison Hendrickson M, Reaves L, Ulbrich M. Optimizing wound care by integrating negative pressure wound therapy (NPWT), adjunctive topical treatments and surgical debridement. Grapevine (TX): Ethicus Long Term Acute Care Hospital; 1 p. | | | ✓ | Case study
(891) | AMD antimicrobial gauze dressings [slide]. Fort Worth (TX): Prospera; 1 p. | | | ✓ | Not a NPWT device
(892) | Bonham PA, Ramundo JM. Commentary: surgical wound case studies with the Versatile 1 wound vacuum system for negative pressure wound therapy. J Wound Ostomy Continence Nurs 2006 Mar–Apr;33(2):185–90. | | | ✓ | Narrative review
(893) | Borgquist O, Torbrand C, Ingemansson R, Malmsjo M. Biological effects of negative pressure wound therapy (NPWT) at low levels of negative pressure - intermittent and variable NPWT [confidential info prepared for ECRI on behalf of AHRQ]. 2009 Feb. 5 p. | | | ✓ | Animal study
(894) | Borgquist O, Torbrand C, Ingemansson R, Malmsjo M. Biological effects of negative pressure wound therapy at low levels of negative pressure - intermittent and variable NPWT. 2 p. | | | ✓ | Animal study
(207) | Bovill E, Banwell PE, Teot L, Eriksson E, Song C, Mahoney J, Gustafsson R, Horch R, Deva A, Whitworth I, International Advisory Panel on Topical Negative Pressure. Topical negative pressure wound therapy: a review of its role and guidelines for its use in the management of acute wounds. Int Wound J 2008 Oct;5(4):511–29. | | | ✓ | Narrative review
(84) | Campbell PE, Smith GS, Smith JM. Retrospective clinical evaluation of gauze-based negative pressure wound therapy. Int Wound J 2008 Jun;5(2):280–6. | ✓ | KQ3 | | | ✓
(895) | Case studies: Prospera PRO-I negative pressure wound therapy [MR124-02/08]. Fort Worth (TX): Prospera; 2008. 7 p. | | | ✓ | Case study
(896) | Caudill T. Clinical and economic benefit to surgical patients with the use of an antimicrobial impregnated surgical dressing. 2 p. | | | ✓ | Not a NPWT device
(442) | Chariker ME, Jeter KF, Tintle TE, Bottsford JE. Effective management of incisional and cutaneous fistulae with close suction wound drainage. Contemp Surg 1989 Jun;34:59–63. | | | ✓ | Did not use a commercially available NPWT system
(897) | Clinical and patient testimonials [Confidential info prepared for ECRI on behalf of AHRQ]. Fort Worth (TX): Prospera; 2009 Feb. 5 p. | | | ✓ | Testimonials were not used in this report
(898) | CPT - continuous pressure therapy [graph]. Fort Worth (TX): Prospera; 1 p. | | | ✓ | Graph
(461) | Davydov YA, Larichev AB, Abramov AY, Menkov KG. [Concepts for clinical biological management of the wound process in the treatment of purulent wounds using vacuum therapy] translated from Russian. Vestnik Khirurgii 1991 Feb;132–5. (Rus). | | | ✓ | Not a NPWT device
(462) | Davydov YA, Larichev AB, Menlov KG. [The bacteriological and cytological assessment of vacuum therapy of purulent wounds] translated from Russian. Vestnik Khirurgii 1988 Oct;48–52. | | | ✓ | Not a NPWT device
(460) | Davydov YA, Malafeeva EV, Smirnov AP, Flegontov VB. [Vacuum therapy in the treatment of purulent lactation mastitis] translated from Russian. Vestnik Khirurgii 1986 Sep;66–70. (Rus). | | | ✓ | Not a NPWT Device
(899) | Donahue K. (Administrative Assistant, Health Technology Assessment Information Service and Evidence-Based Practice Center, ECRI Institute. Plymouth Meeting, PA). ECRI Institute’s request for submissions on NPWT from interested stakeholders. 2008 Dec 30. 2 p. – copy of letter from ECRI Institute to Prospera | | | ✓ | Communication
(900) | Eberlein T, Fedler H. Using a new technique of negative pressure wound therapy (NPWT): variable pressure therapy (VPT) for the management of chronic, non-healing wounds [poster]. Neuremberg, Germany: Gesundheits Manager Health and Wound Management; 1 p. | | | ✓ | Case study
(901) | Eberlein T, Fendler H, Ahearn C. Using a new technique for negative pressure wound therapy (NPWT) for the management of chronic, non-healing wounds [poster]. Neuremberg, Germany: Gesundheits Manager Health and Wound Management; 1 p. | | | ✓ | Case study
(902) | Eberlein T, Fendler H, Ahearn C. Using a new technique of negative pressure wound therapy (NPWT): variable pressure therapy (VPT) for the management of chronic, non-healing wounds. 4 p. – A short description of unpublished data from a prospective analysis of 37 patients treated with the Prospera® NPWT system. | | | ✓ | Insufficient reporting of study design and results
(903) | Etoz A, Ozgenel Y, Ozcan M. The use of negative pressure wound therapy on diabetic foot ulcers: a preliminary controlled trial. Wounds 2004 Aug;16(8):264–9. | | | ✓ | Did not use a commercially available NPWT system
(811) | Food and Drug Administration, Center for Devices and Radiological Health. 510(k) premarket notification database. Vacuum assisted closure. K021500. [internet]. Silver Spring (MD): Food and Drug Administration, Center for Devices and Radiological Health; 2002 Dec 20 [accessed 2005 Nov 11]. [5 p]. Available: http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfPMN/pmn.cfm?ID=8137. | ✓ | Background
(904) | Guiding principles/documentation behind Prospera variable pressure therapy (VPT). Fort Worth (TX): Prospera; 1 p. – list of references | | | ✓ | List of references
(905) | Guiding principles/documentation behind the use of Lower Pressure Settings. Fort Worth (TX): Prospera; 1 p. – list of references | | | ✓ | List of references
(906) | Introducing the all-new PRO-II [MR-131-09/08]. Fort Worth (TX): Prospera; 2008. 6 p. – product information | ✓ | Background
(543) | Isago T, Nozaki M, Kikuchi Y, Honda T, Nakazawa H. Effects of different negative pressures on reduction of wounds in negative pressure dressings. J Dermatol 2003 Aug;30(8):596–601. | | | ✓ | Animal study
(907) | Kairinos N, Solomons M, Hudson DA. The paradox of negative pressure wound therapy - in vitro studies. J Plast Reconstr Aesthet Surg 2008 Nov 24;Epub ahead of print. | | | ✓ | Not a clinical study
(908) | Kirby M. Negative pressure wound therapy. Br J Diabetes Vasc Dis 2007 Sep;7(5):230–4. | | | ✓ | Narrative review
(570) | Kostiuchenok BM, Kolker II, Karlov VA, Ignatenko SN, Samykina TD. [The vacuum effect in the surgical treatment of purulent wounds] translated from Russian. Vestnik Khirurgii 1986;18–21. (Rus). | | | ✓ | Not a NPWT device
(253) | Krasner DL. Managing wound pain in patients with vacuum-assisted closure devices. Ostomy Wound Manage 2002 May;48(5):38–43. | | | ✓ | Narrative review
(909) | Malmsjo M, Ingemansson R, Martin R, Huddleston E. Negative pressure wound therapy using gauze or polyurethane open cell foam: similar effects on pressure transduction and wound contraction. Lund, Sweden: Lund University; 1 p. | | | ✓ | Animal study
(910) | Miller MS. Commentary: new microvascular blood flow research challenges practice protocols in negative pressure wound therapy. Wounds 2005;17(10):290–4. | | | ✓ | Narrative review
(911) | Molnar JA. The science behind negative pressure wound therapy. Ostomy Wound Manage 2004 Apr;50(4A Suppl):2–5. | | | ✓ | Narrative review
(33) | Morykwas MJ, Argenta LC, Shelton-Brown EI, McGuirt W. Vacuum-assisted closure: a new method for wound control and treatment: animal studies and basic foundation. Ann Plast Surg 1997 Jun;38(6):553–62. | | | ✓ | Animal study
(912) | Motta GJ, Corbett LQ, Milne CT. Impact of an antimicrobial gauze upon bacterial colonies in wounds that require packing. 11 p. | | | ✓ | Not a NPWT device
(913) | NovaSpine LLC. 510(k) summary of safety and effectiveness. K062456. Rockville (MD): U.S. Food and Drug Administration; 2006 Sep 27. 5 p. | ✓ | Background
(665) | Philbeck TE Jr, Whittington KT, Millsap MH, Briones RB, Wight DG, Schroeder WJ. The clinical and cost effectiveness of externally applied negative pressure wound therapy in the treatment of wounds in home healthcare Medicare patients. Ostomy Wound Manage 1999 Nov;45(11):41–50. | | | ✓ | Patients treated with dual therapies
(914) | Price RD, Nagarajan M, Srinivasan JR. Local anesthetic for change of vacuum-assisted closure dressings. Plast Reconstr Surg 2006 Jun;117(7):2537–8. | | | ✓ | Letter to the editor
(915) | PRO-I [MR-125-04/08]. Fort Worth (TX): Prospera; 2008. 4 p. – product information | ✓ | Background
(916) | Prospera overview [confidential info prepared for ECRI on behalf of AHRQ]. Forth Worth (TX): Prospera; 2009 Feb. 1 p. – discussion of Prospera approach to NPWT | | | ✓ | Narrative
(917) | Rationale for the Choice AMD gauze dressing system. Fort Worth (TX): Prospera; 2 p. – discussion of Prospera’s reasons for selecting gauze dressings | | | ✓ | Narrative
(918) | Sargent RL, Mudro P, Mele J, Sons J. The use of antimicrobial gauze in a home care setting: a cost effective, proactive wound management plan. 2 p. | | | ✓ | Not a NPWT device
(126) | Schwien T, Gilbert J, Lang C. Pressure ulcer prevalence and the role of negative pressure wound therapy in home health quality outcomes. Ostomy Wound Manag 2005;51:47–60. | ✓ | KQ1, KQ3
(919) | Shah CB, Swogger E, James G. Efficacy of AMD dressings against MRSA and VRE. 2006 Jul. 4 p. | | | ✓ | Not a NPWT device
(704) | Shirakawa M, Isseroff RR. Topical negative pressure devices: Use for enhancement of healing chronic wounds. Arch Dermatol 2005 Nov;141(11):1449–53. | | | ✓ | Narrative review
(920) | Similar physical properties of gauze and polyurethane foam in delivery of negative pressure wound therapy. St. Petersburg (FL): Smith & Nephew; 2008. 2 p. | | | ✓ | Animal study
(921) | Tillery T. The use of a gauze-based dressing for negative pressure wound therapy (NPWT): clinical and financial outcomes. 2008. 2 p. | | | ✓ | Case study
(183) | Ubbink DT, Westerbos SJ, Nelson EA, Vermeulen H. A systematic review of topical negative pressure therapy for acute and chronic wounds. Br J Surg 2008 Jun;95(6):685–92 | ✓ | Previous Systematic Reviews
(922) | Usupov YN, Yepifanov MV. [Active wound drainage] translated from Russian. Vestnik Khirurgii 1987;42–5. (Rus). | | | ✓ | Animal study
(923) | VPT variable pressure therapy [graph]. Forth Worth (TX): Prospera; 1 p. | | | ✓ | Graph
(756) | Wackenfors A, Gustafsson R, Sjogren J, Algotsson L, Ingemansson R, Malmsjo M. Blood flow responses in the peristernal thoracic wall during vacuum-assisted closure therapy. Ann Thorac Surg 2005 May;79(5):1724–30; discussion 1730-. | | | ✓ | Animal study
(40) | Wackenfors A, Sjogren J, Gustafsson R, Algotsson L, Ingemansson R, Malmsjo M. Effects of vacuum-assisted closure therapy on inguinal wound edge microvascular blood flow. Wound Repair Regen 2004 Nov–Dec;12(6):600–6. | | | ✓ | Animal study
(760) | Webb LX. New techniques in wound management: vacuum-assisted wound closure. J Am Acad Orthop Surg 2002 Sep–Oct;10(5):303–11. | | | ✓ | Narrative review
(32) | Willy C, editor(s). The theory and practice of vacuum therapy. Scientific basis, indications for use, case reports, practical advice. Ulm,Germany: Lindqvist book publishing; 2006. 405 p. | ✓ | Background
(767) | Willy C, Voelker HU, Engelhardt M. Literature on the subject of vacuum therapy: review and update 2006. Eur J Trauma Emerg Surg 2007 Feb;33(1):33–9. | | | ✓ | Systematic review, but did not evaluate wound healing outcomes

KQ Key question

Figure 13 Disposition of Submission by Smith & Nephew

Note: Language has been corrected to reflect screening of meeting abstracts, poster presentations and other documents in addition to abstracts and full articles.

Figure 13 is an attrition diagram that depicts the status of documents that Smith & Nephew submitted for possible inclusion in the report. The diagram begins with a box outlining the total submission of 82 documents. Several boxes ensue which are connected by arrows going from top to bottom which follow the submissions as they are being screened for possible inclusion in the report. In the first frame, we compare Smith & Nephew’s submission to submissions by other interested stakeholders and remove any duplicates. Smith & Nephew had 17 duplicate submissions. An arrow leads from the 65 Unique Submissions to the Initial Screening Phase where documents may be excluded, used in our Background Section or passed to the next level. In this instance, 21 documents were identified for exclusion. One was an abstract; one was a personal communication; and 19 were other documents not relevant to the report. Seven documents were identified for inclusion in our Background Section. The path then follows the 37 full articles remaining. During this phase of screening we do a more extensive screening which is again based on our pre-determined inclusion/exclusion criteria. See our Methods Section for additional information on the criteria. 35 full articles were excluded during this evaluation phase. One was an animal study; one was an in vitro study; 27 were not a NPWT study, and six were excluded for Other Reasons which may include “inclusion of healthy subjects”, “lack of reporting wound healing outcomes” or “patients treated with dual therapies.” Two full articles remained for possible inclusion in the report. One article was a published study which was not identified in our literature search and met the inclusion criteria. This study was ultimately included in Key Question 3. In addition, one unpublished article was included in Key Question 3 due to relevancy of the study. Note: Language has been corrected to reflect screening of meeting abstracts, poster presentations and other documents in addition to abstracts of full articles.

Table 54 Status of Submissions by Smith and Nephew

Reference Number | Reference | Included | Placement In Report | Excluded | Reason for Exclusion | Included but Not Identified in ECRI Search
(924) | Baffie A, Fromantin L. Clinical case: V1STA. J Wound Tech 2008 Jun;1:24. | | | ✓ | Case study
(925) | Beneke MJ, Doner J. Observation of nosocomial surgical-site infection rates with utilization of antimicrobial gauze dressing in an acute care setting. Mansfield (MA): Tyco Healthcare; 2005 Jun. 4 p. | | | ✓ | Not a NPWT study
(926) | BlueSky Medical Group, Inc. 510(k) summary for BlueSky VISTA Wound Vacuum System. K061367. Rockville (MD): U.S. Food and Drug Administration (FDA); 2006 Aug 10. 5 p. | ✓ | Background
(927) | BlueSky Medical Group, Inc. 510(k) summary for Versatile 1 EZCare Wound Vacuum System. K061919. Rockville (MD): U.S. Food and Drug Administration (FDA); 2007 Feb 5. 4 p. | ✓ | Background
(928) | Bogart A. The use of antimicrobial gauze dressing on an infected lower extremity vascular bypass wounds. Mansfield (MA): Tyco Healthcare; 2005 Oct. 4 p. | | | ✓ | Not a NPWT study
(929) | Brooks B. (HCPCS Medical Analyst, SADMERC). Letter regarding the consensus coding decision of SADMERC and the four durable medical equipment regional carriers (DMERCs) for Kerlix A.M.D. antimicrobial Large roll and Kerlix A.M.D. antimicrobial super sponge. 2002 Sep 23. 1 p. | | | ✓ | Not part of report
(930) | Brown C. (PDAC Medicare Pricing, Data Analysis, and Coding / Data Analyst, Noridian Administrative Services, Ltd.). Response to inquiry for coding verification of Renasys EZ (model # 66800059). Xref 7118176. 2008 Dec 22. 2 p. | | | ✓ | Not part of report
(84) | Campbell PE, Smith GS, Smith JM. Retrospective clinical evaluation of gauze-based negative pressure wound therapy. Int Wound J 2008 Jun;5(2):280-6. | ✓ | KQ3 | | | √
(931) | Carson R. (Manager, Health Policy & Reimbursement, North America. Smith & Nephew Wound Management). Additional evidence for consideration in review of Negative Pressure Wound Therapy (NPWT). 2009 Feb 5. 3 p; binder of material | | | ✓ | Cover letter
(932) | Case JM. Microbial challenge test for porous materials using methylicillin resistant staphylococcus aureus. Mansfield (MA): Tyco Healthcare; 2001 Jul. 6 p. | | | ✓ | Not a NPWT study
(442) | Chariker ME, Jeter KF, Tintle TE, Bottsford JE. Effective management of incisional and cutaneous fistulae with close suction wound drainage. Contemp Surg 1989 Jun;34:59-63. | | | ✓ | Homemade device
(96) | Clinical in-market evaluation interim report. Hull, United Kingdom: Smith & Nephew Medical, Ltd.; 2009 Feb 2. 30 p.; - This report provides unpublished data from a non-comparative study of 132 patients treated with NPWT systems made by Smith and Nephew. These data were included under Key Question 3. | ✓ | KQ3 | | | ✓
(933) | Comstock M. Process improvement project: reduction of surgical site infections utilizing antimicrobial dressings. Mansfield (MA): Covidien; 2008 Sep. 4 p. | | | ✓ | Not a NPWT study
(934) | Coutts P, Fierheller M, Broughton C, Sibbald RG. Effective wound management influences quality of life. Mansfield (MA): Covidien; 2008 Sep. 1 p. | | | ✓ | Not a NPWT study
(935) | Davis S, Mertz P, Cazzaniga A, Serralta V, Orr R, Eaglstein W. The use of a new antimicrobial gauze dressing: effects on the rate of epithelization of partial thickness wounds. Mansfield (MA): Tyco Healthcare; 2001 Apr. 4 p. | | | ✓ | Not a NPWT study
(226) | Eginton MT, Brown KR, Seabrook GR, Towne JB, Cambria RA. A prospective randomized evaluation of negative-pressure wound dressings for diabetic foot wounds. Ann Vasc Surg 2003 Nov;17(6):645-9. | | | ✓ | Fewer than five patients
(936) | EZCARE negative pressure wound therapy. User guide. Smith & Nephew, Inc.; 31 p. | ✓ | Background
(937) | Fierheller M, Coutts P, Sibbald RG. Holistic effect of an antimicrobial gauze dressing with Claggett’s Window. Mansfield (MA): Covidien; 2008 Sep. 1 p. | | | ✓ | Not a NPWT study
(938) | Findley RD, McGaha EC. The successful use of Negative Pressure Would Therapy after left above the knee amputation (AKA) revision, in a challenging patient. | | | ✓ | Case study
(499) | Fleischmann W, Strecker W, Bombelli M, Kinzl L. [Vacuum sealing as treatment of soft tissue damage in open fractures]. Unfallchirurgie 1993;96(9):488-92. | | | ✓ | Article in German
(110) | Ford CN, Reinhard ER, Yeh D, Syrek D, De Las Morenas A, Bergman SB, Williams S, Hamori CA. Interim analysis of a prospective, randomized trial of vacuum-assisted closure versus the Healthpoint system in the management of pressure ulcers. Ann Plast Surg 2002 Jul;49(1):55-61; discussion 61. | ✓ | KQ1, KQ3
(939) | Harris R. Analysis of surgical site infection rates and cost benefits associated with plain gauze dressings versus gauze dressings impregnated with polyhexamethylene biguanide (PHMB). Mansfield (MA): Covidien; 4 p. | | | ✓ | Not a NPWT study
(940) | Hoover J, Kent DJ. Polyhexamethylene biguanide (PHMB) impregnated gauze for use in treating a gunshot wound. Mansfiled (MA): Covidien; 2008 Sep. 4 p. | | | ✓ | Not a NPWT study
(941) | Howe T, Graham R. The successful management and wound closure of a challenging patient with necrotizing fasciitis with enteric fistula using negative pressure wound therapy. | | | ✓ | Case study
(942) | Hutton CL. The use of antimicrobial gauze packing in an infected coronary artery bypass graft surgical incision. Mansfield (MA): Tyco Healthcare; 2005 Jun. 4 p. | | | ✓ | Not a NPWT study
(39) | Ichioka S, Watanabe H, Sekiya N, Shibata M, Nakatsuka T. A technique to visualize wound bed microcirculation and the acute effect of negative pressure. Wound Repair Regen 2008;16:460-5. | | | ✓ | Animal study
(943) | Jonjo SF. Length of stay: reducing a "weighty" problem in wound care saving time and improving outcomes. Mansfield (MA): Tyco Healthcare; 2007 Apr. 1 p. | | | ✓ | Not a NPWT study
(113) | Joseph E, Hamori CA, Bergman S, et al. A prospective randomized trial of vacuum-assisted closure versus standard therapy of chronic nonhealing wounds. Wounds 2002;12(3):60-7. | ✓ | KQ1, KQ3
(907) | Kairinos N, Solomons M, Hudson DA. The paradox of negative pressure wound therapy - in vitro studies. J Plast Reconstr Aesthet Surg 2008 Nov 24; Epub ahead of print. | | | ✓ | In vitro study
(944) | LCD for negative pressure wound therapy pumps (L11489). Baltimore (MD): Centers for Medicare and Medicaid Services (CMS); 10 p. | | | ✓ | Not part of report
(945) | LCD for negative pressure wound therapy pumps (L11500). Baltimore (MD): Centers for Medicare and Medicaid Services (CMS); 10 p. | | | ✓ | Not part of report
(946) | LCD for negative pressure wound therapy pumps (L27025). Baltimore (MD): Centers for Medicare & Medicaid Services; 10 p. | | | ✓ | Not part of report
(947) | LCD for negative pressure wound therapy pumps (L5008). Baltimore (MD): Centers for Medicare & Medicaid Services; 11 p. | | | ✓ | Not part of report
(259) | Llanos S, Danilla S, Barraza C, Armijo E, Pineros JL, Quintas M, Searle S, Calderon W. Effectiveness of negative pressure closure in the integration of split thickness skin grafts: a randomized, double-masked, controlled trial. Ann Surg 2006 Nov;244(5):700-5. | | | ✓ | Homemade device
(948) | Lovelace L. Antimicrobial dressing intervention associated with reduction in surgical site infection rate. Mansfield (MA): Tyco Healthcare; 2008 Jun. 1 p. | | | ✓ | Not a NPWT study
(949) | Material safety data sheet for DeRoyal Solidifier, MSDS-002. Product numbers 71-1200, 71-1500, 71-2500, 71-3000, 71-9000, 71-18000, 71-0500, 71-1000. Powell (TN): DeRoyal Industries, Inc.; 2005 Dec 9. 2 p. | | | ✓ | Not part of report
(950) | Material safety data sheet for Flexible polyurethane foam. CAS # 9009-54-5. 2008. 4 p. | | | ✓ | Not part of report
(951) | Material safety data sheet for Kerlix AMD super sponges, Kerlix AMD rolls, Excilon AMD sponges, Telfa AMD sponges. Product numbers 6662,6665, 6660, 3331,3332,7088,7089,7662,7663,7665,7666,7667,7668. Mansfield (MA): Tyco Healthcare / Kendall; 2004 May 14. 6 p. | | | ✓ | Not part of report
(952) | Material safety data sheet for Medical Adhesive Tape Technologies, product # 09-9000 blue tape. St. Hubert, Quebec: Medical Adhesive Tape Technologies; 2008 Sep 3. 2 p. | | | ✓ | Not part of report
(953) | Material safety data sheet for negative pressure non-adherent gauze. Toronto (ON): Derma Sciences, Inc.; 2008 May 2. 4 p. | | | ✓ | Not part of report
(954) | Material safety data sheet for Skin Prep Wipes. Largo (FL): Smith & Nephew, Inc.; 2003 Dec 8. 3 p. | | | ✓ | Not part of report
(955) | Material safety data sheet for sodium chloride solution, 0.85% MSDS. Catalog code: SLS2752. Houston (TX): Sciencelab.com, Inc.; 2008 Nov 6. 6 p. | | | ✓ | Not part of report
(956) | Material safety data sheet for Styrene-acrylonitrile copolymer (SAN). CAS registry number: 9003-54-7. IRPC Public Company Limited; 2006 Dec. 4 p. | | | ✓ | Not part of report
(142) | McCord SS, Naik-Mathuria BJ, Murphy KM, McLane KM, Gay AN, Bob Basu C, Downey CR, Hollier LH, Olutoye OO. Negative pressure therapy is effective to manage a variety of wounds in infants and children. Wound Repair Regen 2007 May-Jun;15(3):296-301. | ✓ | KQ3
(957) | McCullin C. The use of an antimicrobial dressing to help improve outcomes for patients with pressure ulcers in a skilled nursing facility. Mansfield (MA): Tyco Healthcare; 2005 Oct. 1 p. | | | ✓ | Not a NPWT study
(958) | McKendrick C. Impact on surgical dressings on coronary artery bypass graft surgery with resultant influence on patient safety. Mansfield (MA): Covidien; 2008. 4 p. | | | ✓ | Not a NPWT study
(606) | McNulty AK, Schmidt M, Feeley T, Kieswetter K. Effects of negative pressure wound therapy on fibroblast viability, chemotactic signaling, and proliferation in a provisional wound (fibrin) matrix. Wound Repair Regen 2007 Nov-Dec;15(6):838-46. | | | ✓ | In vitro study
(959) | Mertz P, Cazzaniga A, Serralta V, Davis S, Orr R, Eaglstein W. The effect of an antimicrobial gauze dressing impregnated with 0.2% polyhexamethylene biguanide (PHMB) as a barrier to prevent pseudomonas aeruginosa wound invasion. Mansfield (MA): Tyco Healthcare; 2000 May. 7 p. | | | ✓ | Not a NPWT study
(960) | Morehouse T, Hager J. Drainage management of enterocutaneous fistula within an abdominal wound. | | | ✓ | Case study
(33) | Morykwas MJ, Argenta LC, Shelton-Brown EI, McGuirt W. Vacuum-assisted closure: a new method for wound control and treatment: animal studies and basic foundation. Ann Plast Surg 1997 Jun;38(6):553-62. | | | ✓ | Animal study
(626) | Morykwas MJ, David LR, Schneider AM, Whang C, Jennings DA, Canty C, Parker D, White WL, Argenta LC. Use of subatmospheric pressure to prevent progression of partial-thickness burns in a swine model. J Burn Care Rehabil 1999 Jan-Feb;20(1 Pt 1):15-21. | | | ✓ | Animal study
(36) | Morykwas MJ, Faler BJ, Pearce DJ, Argenta LC. Effects of varying levels of subatmospheric pressure on the rate of granulation tissue formation in experimental wounds in swine. Ann Plast Surg 2001 Nov;47(5):547-51. | | | ✓ | Animal study
(961) | Motta GJ, Trigilia D. Impact of antimicrobial drain sponge dressing upon specific bacterial isolates at tracheostomy sites. Mansfield (MA): Tyco Healthcare; 2003 May. 8 p. | | | ✓ | Not a NPWT study
(38) | Moues CM, Vos MC, van den Bemd GJ, Stijnen T, Hovius SE. Bacterial load in relation to vacuum-assisted closure wound therapy: a prospective randomized trial. Wound Repair Regen 2004 Jan-Feb;12(1):11-7. | | | ✓ | Duplicate study(136)
(962) | Mullaney B, Lane C. Antimicrobial efficacy by elution of gauze using methycillin resistant staphlococcus aureus (MRSA). Mansfield (MA): Tyco Healthcare; 2001 Jul. 4 p. | | | ✓ | Not a NPWT study
(963) | Mullaney B, Lane C. Antimicrobial efficacy by elution of gauze using vancomycin resistant enterococcus faecalis. Mansfield (MA): Tyco Healthcare; 2001 Jul. 4 p. | | | ✓ | Not a NPWT study
(964) | Neitzel PJ. Reduction of SSIs during a one year study of CABG procedures in a 393-bed acute care community hospital. Mansfield (MA): Tyco Healthcare; 2007 Jun. 1 p. | | | ✓ | Not a NPWT study
(646) | NPWT Info and history of NPWT. St. Petersburg (FL): Smith & Nephew, Inc.; 2009 Feb. 13 p.; - Review of the history, mode of action, mechanism of action, level of negative pressure, context between vacuum source and clinical outcomes, and clinical evidence relating to the use of V1STA and EZCARE NPWT systems. | ✓ | Relevant clinical evidence(96) included in KQ3
(965) | O’Brien JA, Broderick GB, Lalikos JF, Ignotz R, Strom H, Dunn RM. Negative pressure wound therapy as dressing for split-thickness skin grafts: our experience. 2 p. | | | ✓ | Abstract only
(966) | Orr R, Eggleston T, Shelanski MV. Determination of the irritating and sensitizing propensities of Kerlix A.M.D. antimicrobial gauze dressing on scarified human skin. Mansfield (MA): Tyco Healthcare; 2003 Jan. 4 p. | | | ✓ | Not a NPWT study
(967) | Orr R. In vitro efficacy of Kerlix A.M.D. gauze when used with a primary dressing. Mansfield (MA): Tyco Healthcare; 2001 Nov. 1 p. | | | ✓ | Not a NPWT study
(968) | PDAC Medicare pricing, data analysis and coding for EZCARE system. Model 66800187. [internet]. Fargo (ND): Noridian Adminstrative Services, Ltd.; 2008 [accessed 2009 Feb 4]. [1 p]. Available: https://www.dmepdac.com/dmecsapp/do/productdetail?hcpcs_product_id=18187. | | | ✓ | Not part of report
(969) | PDAC Medicare pricing, data analysis and codinng for VERSATILE 1 model number: 100.010. [internet]. Fargo (ND): Noridian Administrative Services, Ltd.; 2008 [accessed 2009 Feb 4]. [1 p]. Available: http://www.dmepdac.com/dmecsapp/do/productdetail?hcpcs_product_id=8929. | | | ✓ | Not part of report
(970) | Penn RG, Vyhlidal SK, Roberts S, Miller S. The reduction of vascular surgical site infections with the use of antimicrobial gauze dressing. Mansfield (MA): Tyco Healthcare; 2 p. | | | ✓ | Not a NPWT study
(971) | Product data sheet for PerfecForm 35858-W, Ionomer-based thermoforming film. Perfecseal, a Bemis Company; 2005 Dec 14. 2 p. | | | ✓ | Not part of report
(972) | Published pricing for EZCare, V1STA, RENASYS-EZ, RENASYS-F, Supply kits. 2009 Jan 1. 1 p. | | | ✓ | Not part of report
(55) | Reitsma AM, Rodeheaver GT. Effectiveness of a new antimicrobial gauze dressing as a bacterial barrier. Mansfield (MA): Tyco Healthcare; 2001 Sep. 4 p. | | | ✓ | Not a NPWT study
(973) | RENASYS EZ negative pressure wound therapy. Smith & Nephew, Inc.; 22 p. | ✓ | Background
(974) | Russell F. The use of V1STA in open abdominal wounds and to facilitate fistulae management. 3 p. | | | ✓ | Case study
(34) | Saxena V, Hwang CW, Huang S, Eichbaum Q, Ingber D, Orgill DP. Vacuum-assisted closure: microdeformations of wounds and cell proliferation. Plast Reconstr Surg 2004 Oct;114(5):1086-96; discussion 1097-. | | | ✓ | Not a clinical study
(35) | Scherer SS, Pietramaggiori G, Mathews JC, Prsa MJ, Huang S, Orgill DP. The mechanism of action of the vacuum-assisted closure device. Plast Reconstr Surg 2008 Sep;122(3):786-97. | | | ✓ | Animal study
(975) | Shah CB. Comparison of efficacy and safety of a new antimicrobial packing strip with PHMB to the current industry standard iodoform and plan packing strips. Mansfield (MA): Tyco Healthcare; 3 p. | | | ✓ | Not a NPWT study
(976) | Shah CB. Testing of antimicrobial efficacy of wound dressing by in vitro elution model. Mansfield (MA): Tyco Healthcare; 4 p. | | | ✓ | Not a NPWT study
(977) | Smith & Nephew labeling information. Smith & Nephew, Inc.; 33 p. | | | ✓ | Not part of report
(978) | Smith & Nephew, Inc. 510(k) premarket notification of intenet to market Renasys-F NPWT foam dressing kits. K082211. Rockville (MD): U.S. Food and Drug Administration (FDA); 2008 Nov 14. 2 p. | ✓ | Background
(979) | Smith & Nephew, Inc. 510(k) premarket notification of intent to market RENASYS EZ. K082426. Rockville (MD): U.S. Food and Drug Administration (FDA); 2008 Sep 5. 3 p. | ✓ | Background
(980) | Sutterfield R. Resolution of araplegic pressure ulcer within a challenging home setting. | | | ✓ | Not a NPWT study
(981) | V1STA negative pressure wound therapy. User guide. Smith & Nephew, Inc.; 33 p. | ✓ | Background
(40) | Wackenfors A, Sjogren J, Gustafsson R, Algotsson L, Ingemansson R, Malmsjo M. Effects of vacuum-assisted closure therapy on inguinal wound edge microvascular blood flow. Wound Repair Regen 2004 Nov-Dec;12(6):600-6. | | | ✓ | Animal study
(37) | Weed T, Ratliff C, Drake DB. Quantifying bacterial bioburden during negative pressure wound therapy: does the wound VAC enhance bacterial clearance. Ann Plast Surg 2004 Mar;52(3):276-9; discussion 279-80. | ✓ | KQ3
(982) | Werthen M, Davoudi M, Sonesson A, Nitsche P, Morgelin M, Blom K, Schmidtchen A. Pseudomonas aeruginosa-induced infection and degradation of human wound fluid and skin proteins ex vivo are eradicated by a synthetic cationic polymer. J Antimicrob Chemother 2004;54(4):772-9. | | | ✓ | Not a NPWT study
(983) | Zanotti EA, Rosenbloom RD. Use of negative pressure wound therapy over matrix regeneration grafts. | | | ✓ | Case study

KQ Key question

Figure 14 Disposition of Submission by Talley Group Ltd.

Note: Language has been corrected to reflect screening of meeting abstracts, poster presentations and other documents in addition to abstracts and full articles.

Figure 14 is an attrition diagram that depicts the status of documents that Talley Group Ltd. submitted for possible inclusion in the report. The diagram begins with a box outlining the total submission of three documents. Several boxes ensue which are connected by arrows going from top to bottom which follow the submissions as they are being screened for possible inclusion in the report. In the first frame, we compare Talley Group’s submission to submissions by other interested stakeholders and remove any duplicates. Tally Group had zero duplicate submissions. An arrow leads from the three Unique Submissions to the Initial Screening Phase where documents may be excluded, used in our Background Section or passed to the next level. In this instance, two documents were identified as case reports and excluded. One documents was identified for inclusion in our Background Section. Due to the exclusion of all three submissions at this level, zero submissions remained for possible inclusion in the report. Note: Language has been corrected to reflect screening of meeting abstracts, poster presentations and other documents in addition to abstracts of full articles.

Table 55 Status of Submission by Talley Group Ltd.

Reference Number | Reference | Included | Placement in Report | Disposition in Report
(984) | Spruce P. (Clinical Director, TVRE Consulting). AHRQ submission on behalf of Talley Group Ltd. 2009 Feb 5. 1 p.; - A list of 8 case reports or case series was provided. The reports were either published as meeting presentations or available on the company Web site. | | | Case reports were not included in this report. The case-series studies did not report outcomes of interest to this report
(985) | Submission of clinical evidence for the VENTURI negative pressure wound therapy system. United Kingdom: Talley Group Ltd.; 2009. 31 p.; - An outline of studies, primarily case reports but also animal and in vitro studies, was provided. | | | Case reports were not included in this report The case-series studies did not report outcomes of interest to this report Animal and in vitro studies were not considered in this report
(986) | Venturi advanced vacuum system for negative pressure wound therapy. United Kingdom: Talley Group Ltd.; 2 p. – product brochure | ✓ | Background