# Evidence Tables

## Key Question 1

Table 16 Comparison Trials of NPWT Devices Used to Treat Chronic Wounds

Reference | Wound Type | Comparator | Number of Patients Enrolled | Quality Score^*^
Blume et al. 2008(108) | Diabetic Foot Ulcer | Advanced Moist Wound Therapy (AMWT) | 342 | Moderate
Armstrong et al. 2007(109) | Diabetic Foot Ulcer | Standard wound therapy (SWT) | 162 | Moderate
Lavery et al. 2007(341) | Diabetic Foot Ulcer | Wet-to-moist | 1,721 | Low
McCallon et al. 2000(120) | Diabetic Foot Ulcer | Saline-moistened gauze | 10 | Low
Schwien et al. 2005(126) | Pressure Ulcer | Any other wound care modality | 2,348 | Low
Wanner et al. 2003(118) | Pressure Ulcer | Gauze soaked with Ringer’s solution | 22 | Low
Ford et al. 2002(110) | Pressure Ulcer | Healthpoint System (HP) | 28 | Moderate
Joseph et al. 2000(113) | Pressure Ulcer | Saline wet-to-moist | 24 | Moderate
Denzinger et al. 2007(135) | Complex Inguinal | Saline moistened gauze | 16 | Low
Moues et al. 2007(136) | Full-thickness | Standard moistened gauze | 54 | Low
Siegel et al. 2007(119) | Radiation-associated | Standard of care | 41 | Low
Braakenburg et al. 2006(114) | Chronic and acute | Hydrocolloid dressings, alginates, acetic acid or Eusol (sodium hypochlorite) | 65 | Moderate
Bickels et al. 2005(134) | Soft tissue defects | Standard of care | 38 | Low
Page et al. 2004(1) | Open foot | Standard of care | 47 | Low

* ECRI Institute study quality assessment instrument

[underlined: Diabetic Foot Ulcers]: The quality of the studies of diabetic foot ulcers was moderate (2 studies) and low (2 studies). Methodological study flaws included lack of appropriate randomization, high attrition and funding from a potentially biased source. Of the four studies, only one study indicated an appropriate randomization method. This study, however, reported the highest attrition rate of over 30% of the patient population.(108) One low-quality study,(120) reported “flip of a coin” followed by an alternate allocation as a randomization method. Finally, all of the studies were funded by one manufacturer which increases the potential for bias in reporting of results.

All four studies evaluated V.A.C.® (KCI, USA Inc.) a powered suction pump system, for the treatment of diabetic foot ulcers; one study evaluated diabetic foot amputation wounds. (Table 23). Comparator treatment for two studies was moistened gauze.(120,341) Two other studies assessed advanced moist wound therapy (hydrogels, hydrocolloids and alginates).(108,109) Patients averaged 58 years of age; average duration of ulcers was over 200 days. Complete patient and wound characteristics are presented in Table 24.

V.A.C.® foam dressings were changed every 48 hours as per the manufacturer’s recommendations in three studies(108,109,120) and control treatments were closely monitored with two studies adhering to standardized guidelines.(108,109) Wound measurements were assessed as frequently as every dressing change or up to 10 times in one 112-day study.(108) Treatment related characteristics are presented in Table 25.

Individual study results for four diabetic foot ulcer studies are presented in Table 26. Outcome reporting varied across studies but each study reported some measure of ulcer size reduction or time to complete wound healing. Small sample size (n = 10) precluded the determination of any statistically significant benefit in one low-quality study.(120) A 28.4% average decrease (V.A.C.®) and 9.5% average increase (control) was reported, however, one V.A.C.® (20%) wound increased in size and healed by “secondary intention.” Satisfactory healing was achieved in an average of 22.8 (±17.4) days for V.A.C.® and 42.8 (±32.5) days for control.

One moderate-quality study of 342 diabetic foot wounds;(108) reported a mean change in wound size in favor of NPWT (−4.32 cm^2^ versus −2.53 cm^2^, p = 0.021) as well as a higher proportion of V.A.C.®-treated patients achieving complete wound closure (43% vs. 28.9%). Data, however, were reported for day 28 during the “active treatment phase” although both 3 and 9 month follow-up assessments were completed for patients achieving ulcer closure. In addition, 40 patients (13% V.A.C.®) discontinued treatment due to adverse events (Table 6).

Armstrong et al.(109) reported results of a secondary analysis of a 16-week study of 164 diabetic foot amputation wounds. Results for this evaluation of wound chronicity indicated no significant difference for proportion of acute and chronic patients achieving complete wound closure or time to complete closure. In addition, there was no significant difference in the proportion of acute or chronic wounds that achieved complete closure between NPWT and SWT groups (acute P = 0.072, chronic P = 0.320). Lastly, a low-quality study by Lavery et al.(341) reported wounds healed at 12 and 20 week assessments with results favoring NPWT over standard of care (39.5% vs. 23.9%, week 12; 46.3% vs. 32.8%, week 20).

[underlined: Pressure Ulcers]: Quality of the four pressure ulcer studies was moderate(110,113) and low.(118,126) Of the four studies, three included small study populations ranging in size from 22 to 28 patients. One of two RCTs did not report randomization methods.(118) One study indicated that outcome assessors were blinded to treatment.(113) Studies did not indicate concealment of group allocation, and underreported patient characteristics which increases the likelihood that study patients were not comparable at baseline. All four studies either reported funding by one manufacturer or failed to report a conflict of interest.

Three studies strictly included only pressure ulcer wounds while one study involved patients with other types of wounds.(113) Comparator treatments included traditional and non-traditional treatments. Primary outcomes varied across studies and ranged from wound healing outcomes (i.e., change in wound volume) to quality of life issues (i.e., rates of hospitalization and emergent care). Two studies reported time to satisfactory wound healing(110,118) while one study stated “complete wound closure was not a realistic end point since wounds were of variable sizes and anatomic locations.”(113)

Three studies showed a favorable effect in the group that received NPWT, however this was only significant in one study.(113) Results for one moderate-quality study included increased rates of wound healing, superiority in decreasing inflammation at the wound site, and increased number of capillaries (suggesting the promotion of formation of granulation tissue) compared to HealthPoint System.(110) In this 6 week study, complete healing was reported for only 4 wounds; 2 (10%; V.A.C.®) and 2 (13% HP).

A similar length study(113) evaluated 24 patients with 36 chronic non-healing wounds (79% pressure ulcers). Average initial wound volume was larger for V.A.C.® wounds (38 cubic centimeters (cc) vs 24 cc) however a significant reduction in wound volume was still demonstrated (78% vs 30% control). A significantly greater reduction in wound depth (66% vs. 20% control; p <0.00001) and width was reported however improvement did not extrapolate to wound length.

One low-quality study evaluated 2348 patients (60 V.A.C.®) identified from a search of 1.94 million start-of-care assessments.(126) The purpose of this study was to determine whether NPWT was associated with positive quality outcomes. Instances of hospitalization for wound problems (5% versus 14%, control) and instances of emergent care for wound problems were lower (0% versus 8% control) for V.A.C.®. Ulcer size, treatment duration and treatment comparators were not indicated by study authors.

Wanner et al.(118) evaluated pressure ulcers of 22 paraplegics or tetraplegic patients. Authors concluded that gauze soaked with Ringer’s solution was equally effective as NPWT in “time needed to form granulation tissue” (27 days vs. 28 days control).

[underlined: Miscellaneous Chronic Wounds]: Six studies included chronic wounds from miscellaneous diagnoses. Five of the studies were rated of low quality(112,119,134–136) and one was rated moderate.(114) Descriptions of study designs may be found in Table 19. Comparator treatments for five of the six trials were standard of care. Control treatment for the sixth study was “modern dressings” which includes hydrocolloid dressings, alginates, acetic acid or Eusol (sodium hypochlorite).(114) Table 20 and Table 21 list additional patient and treatment-related characteristics.

Three of the six studies reported a comparable benefit to time to satisfactory healing in comparison to control treatments.(1,114,136) One moderate-quality study, Braakenburg et al.(114), evaluated 65 patients with chronic and acute wounds. Similar results were reported for overall change in wound area (0.1 cm^2^/day), time to satisfactory healing (median 16 [V.A.C.®] vs. 20 [control]) and overall change in the amount of granulation. Two patients discontinued V.A.C.® due to pain during dressing changes; one patient refused to cooperate (V.A.C.®); one amputation and 6 early dismissals were reported for the control group.

Moues et al.(136) reported similar “time to surgical readinesses” for 54 patients treated with V.A.C.® or SOC. Two V.A.C.® patients discontinued treatment due to sepsis of unknown origin. Two control patients registered wound surface area increase. Postoperative complications were high, reported in 32% of V.A.C.® and 43% of control groups (Table 5). Page et al.(1) reported no difference in “time to closure” and “wound cavity filling” for 47 patients with open foot wounds (Table 22).

Three remaining studies concluded that NPWT was more effective for time to wound closure than the control treatments.(119,134,135) Denzinger et al.(135) studied treatment of 16 complex inguinal wounds; 6 wounds treated with V.A.C.®. Median duration until complete wound closure was significantly shorter for V.A.C.® treated (38.9 days versus 69.8 days, control).

In one study of 41 patients with radiation-associated wounds, a significant improvement was reported for success of wound closure with the need for soft tissue transposition, hospital stay and length of overall treatment.(119) Mean change in wound area for V.A.C.® was reported at -329 cm3; however, the authors failed to report data for the control group. Amputations were reported in both both groups (V.A.C.® [1] and control [3]).

Bickels et al.(134) studied 62 patients with soft tissue defects. V.A.C.® patients had significantly greater rates of primary wound closure with or without skin graft; and significantly shorter hospital stays than non-V.A.C.® patients. Authors failed to report baseline wound size for controls; three control patients required lower extremity amputation.

## Acute Wounds

The evidence base for comparison trials of NPWT used to treat acute wounds includes 16 low-quality studies (Table 17).

Table 17 Comparison Trials of NPWT Used to Treat Acute Wounds

Reference | Wound Type | Comparator | Number of Patients Enrolled | Quality Score^*^
Timmers et al. 2009(106) | Post-traumatic osteomyelitis | SOC | 124 | Low
Simek et al. 2008(123) | Deep sternal | Conventional | 62 | Low
Yang et al. 2006(72) | Fasciotomy | SOC | 68 | Low
Stannard et al. 2006(125) | Study1: hematoma | Study 1: Pressure dressing | Study 1: 44 | Low
Stannard et al. 2006(125) | Study 2: fracture | Study 2: Post-operative dressing | Study 2: 44 | Low
Fuchs et al. 2005(23) | Deep sternal | Conventional | 68 | Low
Immer et al. 2005(130) | Deep sternal wound infection | Sternal excision and primary musculocutaneous flap | 55 | Low
Segers et al. 2005(122) | Post-sternotomy mediastinitis (PM) | Closed drainage | 63 | Low
Sjogren et al. 2005(139) | PM | Conventional | 101 | Low
Domkowski et al. 2003(129) | PM | SOC | 102 | Low
Song et al. 2003(124) | Surgical | Standard of care (SOC) | 35 | Low
Doss et al. 2002(128) | Post-sternotomy osteomyelitis | SOC | 42 | Low
Catarino et al. 2000(137) | PM | Closed drainage and irrigation | 17 | Low
Shilt et al. 2004(138) | Traumatic | SOC | 31 | Low
Kamolz et al. 2003(343) | Burn | Silver sulphadiazine | 7 | Low
Gabriel et al. 2008(339) | Infected | SOC | 30 | Low
Ozturk et al. 2008(117) | Fournier’s gangrene | SOC | 10 | Low
Rinker et al. 2008(121) | Open tibia fracture | SOC | 55 | Low
Huang et al. 2006(127) | Limb | SOC | 24 | Low
Labler et al. 2004(71) | Soft tissue | Epigard® dressing | 23 | Low

* ECRI Institute study quality assessment instrument

[underlined: Surgical Wounds]: The evidence base for studies evaluating NPWT treatment of sternal wounds (Table 31) included one randomized controlled trial and one retrospective review. Stannard et al.(125) evaluated two small study populations: (1) trauma patients with hematomas and (2) patients with high-risk fractures. Results for both studies included a significant difference in mean days to drainage favoring V.A.C.® (hematoma study: 1.6 days (d) versus 3.1; fracture study: 1.8 d versus 4.8). A higher infection rate for non-NPWT patients was reported in the hematoma study, while similar rates of infection and complications were reported in the fracture study.

The retrospective review by Song et al.(124) reported no significant differences for average days between debridement and definitive closure of the sternal wound (6 ±1.3 d versus 8 ±2.9 d, control). Results for all studies evaluating acute wounds can be found in Table 34.

[underlined: Surgical Site Infections (SSI)]: Eight low-quality studies evaluated V.A.C.® for the treatment of surgical site infections (SSI). Interventions included conventional treatments (2 studies), closed drainage (3 studies), and standard of care (2 studies). Some studies reported similar results for wound healing(23,128,137,139), while two reported significant benefit(123) or modest benefit to NPWT.(122)

In a study of 62 patients with sternal wound infections, Simek et al.(123) reported significant findings for failure rate (5.8% versus 39.2%, control) and 1-year mortality (14.7% versus 39.2%, control) in favor of V.A.C.®.

In a similar-sized study, Fuchs et al.(23) retrospectively evaluated 68 patients and reported similar time to primary or secondary wound healing (21 days (IQR: 15 to 26d) versus 28 days (IQR: 18 to 54d), control). A total of 5 deaths occurred in this study; one death from vacuum-related perforation.

Segers et al.(122) evaluated 63 post-sternotomy (PM) patients treated by V.A.C.® or closed drainage technique (CDT). Duration of therapy (22.8 days versus 16.5, NS) and mean SSI hospital stay (46.1 versus 35.7) were longer with V.A.C.®. A high morbidity rate was reported (29%) with 9 deaths reported in each patient group. Mortality caused by SSI was lower for V.A.C.® (4 [13.8%]) versus control (7 [20.6%]). See Table 8 for a further description of acute study complications.

Sjogren et al.(139) examined 101 PM patients treated by V.A.C.® or conventional treatment which included open dressings, closed irrigation, pectoral muscle flaps, or omentum flaps. 61 patients underwent V.A.C.® as a single-line therapy followed by sternal rewiring. Results were similar for treatment duration, length of stay, and rate of infection, however, overall survival was significantly better in the V.A.C.® (97% versus 84% [6 months], 93% versus 82% [1 year], and 83% versus 59% [5 years]).

Standard of care was evaluated as a comparator treatment for two studies evaluating treatment of SSI. In a study of 102 PM patients, Domkowski et al.(129) reported four deaths overall (2 from multisystem organ failure and 2 from overwhelming sepsis). Doss et al.(128) reported similar results for reduction in wound size (4.63 cm^2^/day versus 3.2 cm^2^, control) and mortality (1 in each group) in a study of 42 PM patients.

A smaller study of 17 PM patients(137) reported similar time to wound closure (11 d median versus 13 d) although a significantly higher treatment failure for patients treated with closed drainage and irrigation (0 versus 5, control). See Table 32 and Table 33 for additional information on patient and treatment characteristics, respectively.

Lastly, Immer et al.(130) assessed 55 patients with deep sternal wound infections (DSWI) after cardiac surgery. Study population was divided into three groups: (1) NPWT (2) NPWT plus secondary sternal excision and musculocutaneous flap and (3) sternal excision and primary musculocutaneous flap. Survival was significantly better in Group 1 (NPWT only) who also scored significantly higher on a quality-of-life assessment, SF-36, for aspects of physical function, general health and vitality.

[underlined: Traumatic Wounds]: In 2004, Shilt et al.(138) examined 31 pediatric patients for treatment of lawnmower injuries. Length of hospital stay was longer in V.A.C.® treated (16.8 versus 10.2, control). Similar results were reported when a questionnaire (Vosburgh et al.), was administered to evaluate post-treatment functional outcomes (23.0 versus 22.6, control).

Standard of care was compared to V.A.C.® in one low-quality study.(72) Yang et al. compared 68 patients with fasciotomy wounds for traumatic compartment syndrome. Results indicated a significant reduction in overall time to definitive wound closure by either delayed primary closure with sutures or STSG for V.A.C.®-treated (6.7 days versus 16.1 days, p = 0.0001).

Timmers et al.(106) recently assessed treatment of 124 post-traumatic osteomyelitis patients by negative pressure instillation therapy (NPIT) versus SOC. The median duration of the first hospital stay did not differ (36 days (V.A.C.®) vs. 27.3 days), however due to the high number of recurrences of osteomyelitis (58.5%) and subsequent rehospitalizations, the cumulative duration of hospital stay was significantly higher in the control group (73 days versus 36 days (V.A.C.®) (p <0.0001).

[underlined: Burn Wounds]: One low-quality study examined treatment of burn wounds for 7 patients (used as their own controls).(343) Wounds with more intense injury received V.A.C.® while the other less injured hand received silver sulphadiazine (SSD) crème. Results indicate a greater reduction of edema formation within the V.A.C.® treated hand.

[underlined: Miscellaneous Acute Wounds]: Traditional treatments were compared to V.A.C.® in five low-quality studies examining miscellaneous acute wound.(71,117,121,127,339) Results were similar for two(117,127) while three studies found benefit from V.A.C.® treatment.(71,121,339)

A subgroup of 55 sub-acute patients underwent a free muscle flap for treatment of a Gustilo grade IIIB or IIIC tibia fracture(121) (overall n = 105). Time to bony union was significantly less for V.A.C.® treated (4.9 months versus 7.2 months). Length of hospital stay was similar (20.8 ±10.5 versus 20.2 ±8.5, control).

Gabriel et al.(339) evaluated 30 patients with infected trunk and extremity wounds treated with NPWT with instillation. NPWT patients (n = 15) experienced significantly fewer days to wound closure (13.20 ±6.75 versus 29.6 ±6.54, control) and significantly shorter days to patient discharge (14.67±9.18 versus 39.2 ±12.07, control). 100% of wounds were healed with NPWT with instillation versus 66.7% of the traditional group.

In 2004, Labler et al.(71) compared 23 patients with severe open fractures treated by V.A.C.® or Epigard® dressing. Wounds were “healed uneventfully” for 11 of 13 (85%) V.A.C.® versus five of ten (50%) control wounds. Rate of infection was higher for Epigard® treated (6 of 11 (55%) versus 2 of 13 (15%), V.A.C.®).

In a small study (n = 10) of patients with Fournier’s gangrene, similar results were shown for “time to satisfactory healing” (9 days vs 10d (control); and “hospital stay”(14 days vs 13 days (control).(117) Pain assessment measured by the visual analog scale (VAS) indicated less pain in V.A.C.® group (2.4 and 6.8, control). Patients scored need for analgesics, number of times per day mobile, and number of additional dressing changes per day.

Results for hospital stay and wound volume were similar in a study of 24 patients with limb wounds.(127) Mean days for hospital stay (32.1d vs. 34.3) and reduction in dimension (47% vs. 41% control) and reduction in volume (49% vs. 39% (control)) were all similar for V.A.C.® and control groups. Adverse events resulting in discontinuation of treatment included 1 death and 2 amputations in V.A.C.® (25% of group). One death and two amputations were reported in SOC group as well.

[underlined: Skin Graft:] The evidence base for comparison trials of NPWT devices used to secure skin grafts includes two moderate-quality and five low-quality studies (Table 18).

Table 18 Comparison Trials of NPWT Devices Used to Secure Skin Graft

Reference | Wound Type | Comparator | Number of Patients Enrolled | Quality Score*
Korber et al. 2008(340) | Chronic leg | Standard of care (SOC) | 54 | Low
Vuerstaek et al. 2006(111) | Chronic leg | Conventional (hydrocolloids, alginates) | 60 | Moderate
Vidrine et al. 2005(342) | Skin grafted radial forearm | Bolster dressing plus splint | 44 | Low
Moisidis et al. 2004(112) | Clinically ready for skin graft | Bolster dressing | 22 | Moderate
Stone et al. 2004(133) | STSG | Cotton bolster dressing | 40 | Low
Scherer et al. 2002(132) | STSG | Cotton bolster dressing | 61 | Low
Genecov et al. 1998(131) | STSG | Opsite | 10 | Low

STSG Split thickness skin graft

Seven studies evaluated the use of NPWT to secure skin grafts (split-thickness, mesh and punch). Quality of the studies was moderate (k = 2) and low (k = 5). Comparators included bolster dressings (k = 4), standard of care (k = 1), Opsite dressing (k = 1) and conventional treatments (i.e., hydrocolloids, alginates) (k = 1). Study populations were small, ranging from 10 to 61 patients (Table 27).

Two moderate-quality studies randomized patients to NPWT or conventional and bolster dressings.(112,115) Vuerstaek et al.(115) evaluated 60 patients with chronic leg ulcers randomized to treatment by V.A.C.® or alginates/hydrocolloids. Time to complete healing was significantly reduced in the NPWT group (29 d (95% CI, 25.5 to 32.5) versus 45 d(95%CI, 36.2 to 53.8)). Results for secondary outcomes included a greater relapse at 1 year follow-up (52% of all healed V.A.C.® ulcers relapsed compared with 42%, control). Both groups reported significant increases in quality of life and similar decreases in pain. See Table 30 for further details on measures of outcome.

Moisidis et al.(112) enrolled 22 patients (used as their own controls) with wounds clinically ready for skin graft. Total negative pressure (TNP) was used on the superior half of the wound in ten patients and inferior half in the remaining ten. At 2 weeks, a quantitative assessment by a clinician blinded to treatment reported the degree of epithelialization similar in both groups.

One low-quality study(340) evaluated 54 patients with 74 chronic leg ulcers of comparable size (Table 28). Complete healing of mesh grafts was significantly higher for V.A.C.® treated compared to standard of care (92.9% versus 67.4%). Age older than 70 years, diabetes mellitus and dermatoliposclerosis were strong predictors to poor graft take.

Three low-quality studies evaluated a bolster dressing as a comparator treatment. A four week assessment of 45 radial forearm donor sites indicated overall complete split-thickness skin graft (STSG) take rate higher in negative pressure dressing group compared to management by bolster dressing and splint.(342) Stone et al.(133) evaluated 40 trauma patients who received 46 STSGs. Similar results were reported for duration of dressing (4.8d versus 5.2d, control), mean hospital stay (20.9 ±10 versus 15.3 ±7.5, control), and graft failure. No grafts failed in the NPWT group while one graft failure was reported in the control group (Table 7).

Improved graft survival was reported by Scherer et al.(132) in an assessment of graft take when placed for burn (52%), soft tissue loss (44%) and fasciotomy-site coverage (3%). Repeated STSG to same site was significantly higher in controls compared to V.A.C.® (5 (19%) versus 1 (3%)). Although grafts were significantly larger in the control group (984 ±996 cm^2^ versus 387 ±573 cm^2^) the 6 repeated grafts were of small or moderate size.

In a seven day study, Genecov et al.(131) evaluated 10 patients who served as their own controls. Blinded assessors analyzed biopsies to measure degree of reepithelialization (Table 29). Results indicated faster reepithelialization with V.A.C.® (n = 7); no difference (n = 2); and more rapid reepithelialization with Opsite (n = 1).

## Chronic Wounds

Table 19 Key Study Design Characteristics of Comparison Studies of NPWT Devices^*^ Used to Treat Miscellaneous Chronic Wounds

Reference | Study Type | Wound Type | Number of Patients Enrolled | Comparison Treatment | Inclusion Criteria | Exclusion Criteria | Length of Study | Attrition
Moues et al. 2007(136) | RCT^*^ | Full-thickness | 54 | Standard moist gauze | From July 1998 to October 2002, patients with a full-thickness wound that could not be closed immediately because of severely crushed tissue, infection or chronic character | Malignant disease, superficial bare blood vessels, deep fistulae, necrotic tissue, an unstable skin around the wound, sepsis, untreated Osteomyelitis, active bleeding, uncontrolled diabetes and psychiatric disorders | Ready for surgical readiness | V.A.C.® – 3 Control – 2
Braakenburg et al. 2006(114) | RCT^*^ | Acute and chronic | 65 | Conventional therapy Hydrocolloid dressings, alginate, acetic acid, or Eusol (sodium hypochlorite) | Consecutive patients with any type of wound, acute or chronic, throughout all patient departments at the Rijnstate Hospital, Arnhem, The Netherlands between March 2002 and May 2004. | Steroid drugs, residual malignant cells in the wound, radiotherapy, deep fistulae, sepsis, underlying osteomyelitis, active bleeding, patients younger than 18 years, and psychiatric patients. | Complete granulated wound or a wound ready for skin grafting or healing by secondary intention | NR
Denzinger et al. 2007(135) | Non-RCT^*^ | Inguinal wounds | 16 | Saline-moistened gauze | Patients with inguinal regions subjected to lymphadenectomy for penile cancer between 2000 and 2006. | NR | Complete wound closure | NR
Siegel et al. 2007(119) | Non-RCT^*^ | Radiation-associated | 41 | SOC | NPWT: 22 patients treated with V.A.C.® between Jan 2003 and Jan 2006 with soft tissue sarcomas treated with both surgical intervention and radiation therapy and developed either superficial or deep wound (16) complications: SOC: 19 patients with soft tissue sarcomas treated from Jan 2001 and Jan 2003 with similar history of radiation treatment, chemotherapy, wound size and patient age | NR | Until wound healing by either primary or secondary intention, skin grafting or soft tissue transposition | NR
Bickels et al. 2005(134) | Non-RCT^*^ | Soft tissue defects | 62 | SOC | V.A.C.®: 23 consecutive patients with large defects after tumor resection treated in 2002 and 2003. Control: 39 patients with similar defects treated between May 1999 and May 2002 | Patients with gross infection or residual tumor at the surgical site were excluded from V.A.C.® | Wound is covered with viable and thick granulation tissue allowing for primary closure, skin grafting or healing by secondary intention F/U 12–27 months (median 19 months) | NR
Page et al. 2004(1) | Non-RCT^*^ | Open foot | 47 | Saline-soaked gauze | Patients identified in a surgical log at Carl Hayden VA Medical Center aged 18 to 75 with an open foot wound of any etiology requiring surgical intervention, no presence of infection in the wound when therapy was initiated, a soft tissue defect at least 2 cm deep following surgical intervention (debridement/amputation) and wound treatment with either NPWT or wet-to-moist dressings after surgical intervention | Persistent wound infection, necrotic tissue in the wound bed, and interruption in treatment or use of alternative therapies during the wound cavity filling time | NR | NR

NR Not Reported

RCT Randomized controlled trial

* All studies reported using V.A.C.® (KCI, USA Inc.)

Table 20 Patient Characteristics in Comparison Studies of NPWT Devices* Used to Treat Miscellaneous Chronic Wounds

Reference | Study Type | Number of Patients | Mean (SD) Age (years) | Sex | Comorbidities | Number of Wounds | Mean (SD) Baseline Wound Area (cm^2^) or Volume (cm^3^) | Severity of Wounds | Mean (SD) Duration of Ulcer
Moues et al.(136) | RCT | V.A.C.®: 29 | 47.7 ±19.6 | NR | Diabetes – 6 Vascular compromised – 8 Osteomyelitis – 8 | 29 | NR | 12 early treated, 17 late treated | NR
Moues et al.(136) | RCT | Standard moist: 25 | 47.9 ±17.0 | NR | Diabetes – 6 Vascular compromised – 8 Osteomyelitis – 8 | 29 | NR | 12 early treated, 17 late treated | NR
Moues et al.(136) | RCT | Standard moist: 25 | 47.9 ±17.0 | NR | Diabetes – 1 Vascular – 3 Osteomyelitis – 4 Spinal cord lesion – 5 | 25 | NR | 8 early treated, 17 late treated | NR
Braakenburg et al.(114) | RCT | V.A.C.®: 32 | 65.5 median | M20 F12 | Diabetes – 12 (37%) Vascular surgery – 9 (28%) Cardiovascular disease – 11 (34%) Smoking – 8 (29%) | 32 | 29.5 cm^2^ (median) Range: 3 to 600 cm^2^ | Chronic – 64% Acute – 11% Subacute – 23 | NR
Braakenburg et al.(114) | RCT | Control: 33 | 69.2 median | M16 F17 | NR | 33 | 30 cm^2^ (median) Range: 6 to 152 cm^2^ | NR | NR
Denzinger et al.(135) | Non-RCT | V.A.C.®: 5 | 64 | M5 | No difference reported | 6 | 34 cc Range: 24–54 | NR | NR
Denzinger et al.(135) | Non-RCT | SOC: 9 | 67 | M9 | No difference reported | 10 | 37 cc Range: 24–84
Siegel et al.(119) | Non-RCT | V.A.C.®: 22 | 41 (24–78) | NR | NR | 22 | 111 cm^3^ Range: 2.5–3,660 | NR | NR
Siegel et al.(119) | Non-RCT | SOC: 19 | 46 (19–67) | | NR | 19 | 410 cm^3^ Range: 4–3,800cm^3^ | NR | NR
Bickels et al.(134) | Non-RCT | V.A.C.®: 23 | Median: 46.5 Range: 36–72 | M8 F15 | NR | 23 | Mean: 345 cm^2^ Range: 64 cm^2^ to 520 cm^2^ | NR | NR
Bickels et al.(134) | Non-RCT | SOC: 39 | | M21 F18 | NR | NR | NR | NR | NR
Page et al.(1) | Non-RCT | V.A.C.®: 22 | 66 (±12) | M22 | Diabetes – 17 (77%) | 22 | Wound dimensions were not consistently recorded Wounds were divided into small, medium and large Small 2 (9%) Med 6 (27%) Lg 14 (64%) | NR | NR
Page et al.(1) | Non-RCT | Control: 25 | 60 (±11) | M25 | Diabetes – 14 (56%) | 25 | Small 8 (32) Med 7 (28%) Lg 10 (40%)
Moues et al.(136) | RCT | V.A.C.®: 29 | 47.7 ±19.6 | NR | Diabetes – 6 Vascular compromised – 8 Osteomyelitis – 8 | 29 | NR | 12 early treated, 17 late treated | NR
Moues et al.(136) | RCT | Standard moist: 25 | 47.9 ±17.0 | NR | Diabetes – 1 Vascular – 3 Osteomyelitis – 4 Spinal cord lesion – 5 | 25 | | 8 early treated, 17 late treated
Braakenburg et al.(114) | RCT | V.A.C.®: 32 | 65.5 median | M20 F12 | Diabetes – 12 (37%) Vascular surgery – 9 (28%) Cardiovascular disease – 11 (34%) Smoking – 8 (29%) | 32 | 29.5 cm^2^ (median) Range: 3 to 600 cm^2^ | Chronic – 64% Acute – 11% Subacute – 23 | NR
Braakenburg et al.(114) | RCT | Control: 33 | 69.2 median | M16 F17 | | 33 | 30 cm^2^ (median) Range: 6 to 152 cm^2^
Denzinger et al.(135) | Non-RCT | V.A.C.®: 5 | 64 | M5 | No difference reported | 6 | 34 cc Range: 24–54 | NR | NR
Denzinger et al.(135) | Non-RCT | SOC: 9 | 67 | M9 | No difference reported | 10 | 37 cc Range: 24–84
Siegel et al.(119) | Non-RCT | V.A.C.®: 22 | 41 (24–78) | NR | NR | 22 | 111 cm^3^ Range: 2.5–3,660 | NR | NR
Siegel et al.(119) | Non-RCT | SOC: 19 | 46 (19–67) | | | 19 | 410 cm^3^ Range: 4–3,800 cm^3^
Bickels et al.(134) | Non-RCT | V.A.C.®: 23 | Median: 46.5 Range: 36–72 | M8 F15 | NR | 23 | Mean: 345 cm^2^ Range: 64 cm^2^ to 520 cm^2^ | NR | NR
Bickels et al.(134) | Non-RCT | SOC: 39 | | M21 F18
Page et al.(1) | Non-RCT | V.A.C.®: 22 | 66 (±12) | M22 | Diabetes – 17 (77%) | 22 | Wound dimensions were not consistently recorded Wounds were divided into small, medium and large Small 2 (9%) Med 6 (27%) Lg 14 (64%) | NR | NR
Page et al.(1) | Non-RCT | Control: 25 | 60 (±11) | M25 | Diabetes – 14 (56%) | 25 | Small 8 (32) Med 7 (28%) Lg 10 (40%)

RCT Randomized controlled trial

Table 21 Treatment-Related Characteristics in Comparison Studies of NPWT Devices^*^ Used to Treat Miscellaneous Chronic Wounds

Reference | Study Type | Treatments | Treatment Change | Wound Assessment | Frequency of Measurements | Treatment Duration | Prior Treatments | Concurrent Treatments
Moues et al.(136) | RCT | V.A.C.® Continuous pressure of 125 mmHg Polyurethane foam dressing with a pore size of 400–600 µm (V.A.C.® pack) | 48 hrs | Trace of wound onto clear polyethylene film; after photocopying the tracing onto paper, the wound surface areas were scanned and calculated; tissue biopsies taken every 2-3d throughout treatment | Every 48 hrs | Ready for surgical readiness or 30 days or prior to 30 days if treatment terminated | NR | - Initially, surgical debridement: V.A.C.® 97%, control 88%; - Secondly, surgical debridement: 4 V.A.C.®, 3 control; - Thirdly, chemical debridement was clinically indicated in 20 out of 25 control wounds (80%); - Topical antimicrobial treatment used for 11 out of 25 control wounds (44%); - Special pressure relieving mattresses if bedridden
Moues et al.(136) | RCT | Standard moist-saturated in either 0.9% saline, 0.2% nitrofuralam, 1% acetic acid or 2% sodium hypochlorite | 2x/day minimum | Trace of wound onto clear polyethylene film; after photocopying the tracing onto paper, the wound surface areas were scanned and calculated; tissue biopsies taken every 2-3d throughout treatment | Every 48 hrs | Ready for surgical readiness or 30 days or prior to 30 days if treatment terminated | NR
Braakenburg et al.(114) | RCT | V.A.C.® CNP: −125 mmHg Black polyurethane foam dressing with a pore size of 400 to 600 µm | 3x/wk | Photos and bacteriologic swabs – 1x/wk Wound surface measured with a standardized drape – 2x/wk Pain assessed with visual analogue scale – 3x/wk | 3x/wk | NR | NR | Surgical debridement
Braakenburg et al.(114) | RCT | Conventional | 1 or more times/day | Photos and bacteriologic swabs – 1x/wk Wound surface measured with a standardized drape – 2x/wk Pain assessed with visual analogue scale – 3x/wk | 3x/wk | NR | NR | Surgical debridement
Denzinger et al.(135) | Non-RCT | V.A.C.® Continuous negative pressure (125 mmHg) Foam dressing | Every 3d | NR | NR | Complete wound closure | Inguinal lymphadenectomy for penile cancer | - Surgical debridement; - Secondary surgical debridement; - Adjuvant radiotherapy or chemotherapy: 2 V.A.C.® and 3 SOC
Denzinger et al.(135) | Non-RCT | SOC + hydrogel (n = 3) + hydrocolloid (n = 2) | Every other day | NR | NR | Complete wound closure | Inguinal lymphadenectomy for penile cancer | - Surgical debridement; - Secondary surgical debridement; - Adjuvant radiotherapy or chemotherapy: 2 V.A.C.® and 3 SOC
Siegel et al.(119) | Non-RCT | V.A.C.® Continuous 125 mmHg Sponge | Every 2-3d | NR | NR | Average: 41d over a 3 year period | Surgical resection and radiation | - Surgical debridement; - Post-operative brachytherapy; - Rotational soft tissue transposition (n = 6); - Free vascularized flap (n = 1); - Split thickness skin graft (n = 8)
Siegel et al.(119) | Non-RCT | SOC and/or additional soft tissue coverage procedures | | | | | Surgical resection and radiation | - Surgical debridement; - Post-operative brachytherapy; - Rotational soft tissue transposition (n = 6); - Free vascularized flap (n = 1); - Split thickness skin graft (n = 8)
Bickels et al.(134) | Non-RCT | V.A.C.® Continuous negative pressure: −125 mmHg Polyurethane foam dressing | 48 hours for 7 to 19 days | NR | NR | When wound is covered with viable and thick granulation tissue, which allows primary closure, skin grafting, or healing by secondary intention Average 14.5d Range: (7-19d) Average: 9.5d for patients who did not have radiation (n = 7) or exposed bone or tendon (n = 6) | Chemotherapy – 9 Radiation – 7 | - Surgical debridement; - Skin graft – 14; - Healing by secondary intention – 2
Bickels et al.(134) | Non-RCT | SOC | Daily | NR | NR | NR | NR | - Surgical debridement (second surgical debridement for 24 patients); - Skin graft – 10; - Free flap transfer – 3; - Healing by secondary intention – 15; - Lower extremity amputation – 3
Page et al.(1) | Non-RCT | V.A.C.® | NR | NR | NR | NR | NR | NR
Page et al.(1) | Non-RCT | Saline moistened gauze | NR | NR | NR | NR | NR | NR

NR Not Reported

RCT Randomized controlled trial

* All studies reported using V.A.C.® (KCI, USA Inc.)

Table 22 Results for Outcome Measures Reported in Comparison Studies of NPWT Devices^*^ Used to Treat Miscellaneous Chronic Wounds

Reference | Study Type | Treatments | N | Wounds Healed | Mean (SD) Change in Wound Area (cm^2^) or Volume (cm^3^) | Satisfactory Healing | Other Important Outcomes | Adverse Events Resulting in Discontinuation of Treatment
Moues et al.(136) | RCT | V.A.C.® | 29 | | 3.8 ±0.5%/day (n = 15; reduction observed in 100%) Subgroup | Time to surgical readiness: 6.00 ±0.52 days | NR | 2 (sepsis with unknown origin, ischaemic pain with increased tissue necrosis)
Moues et al.(136) | RCT | Standard moist | 25 | | 1.7 ±0.6%/day (n = 13; reduction observed in 77%) | 7.00 ±0.81d
Braakenburg et al.(114) | RCT | V.A.C.® | 32 | 26 | Overall change: 0.1 cm^2^/day | Median time in days (95% CI): 16 (9–23) | Overall change in the amount of granulation was not different between the two groups. | 2 (due to pain during dressing changes)
Braakenburg et al.(114) | RCT | Conventional | 33 | 21 | Overall change: 0.1 cm^2^/day | Median time in days (95% CI): 20 (16–24) | Overall change in the amount of granulation was not different between the two groups.
Denzinger et al.(135) | Non-RCT | V.A.C.® | 5 | 6 | NR | 38.9d (median) | Hospital stay: 13.2d (8–27) | NR
Denzinger et al.(135) | Non-RCT | SOC | 9 | 10 | NR | 69.8d | 28.4 (16–39) | NR
Siegel et al.(119) | Non-RCT | V.A.C.® | 22 | 21 | −329 cm^3^ | Split thickness graft – 8 Soft tissue transposition – 6 Free vascularized flap – 1 Primary closure – 2 Secondary intention – 4 Healed post-amputation – 1 | Hospital stay: 3.1d (portable V.A.C.®) 41d (1 patient in hospital) | NR
Siegel et al.(119) | Non-RCT | SOC | | | NR | Split thickness graft – 3 Rotational flaps – 7 Free vascularized flap – 4 Secondary intention – 5 | 42d
Bickels et al.(134) | Non-RCT | V.A.C.® | 23 | 23 (covered with viable) | Average 25% reduction (range, 10%–35%): 20 patients Wounds from 3 patients showed no reduction in size (2 soft tissue around leg and 1 sacral) | NR | Hospital stay: 4–30d (Mean: 18.5; Median: 20d) | NR
Bickels et al.(134) | Non-RCT | SOC | 39 | 39 | NR | | Hospital stay: 15–72d (Mean: 37d; Median: 39d)
Page et al.(1) | Non-RCT | V.A.C.® | 22 | NR | Median time of wound filling: 38d (95% CI: 26 to 70) | NR | Median time to closure: 110d (79, 184) | NR
Page et al.(1) | Non-RCT | SOC | 25 | | 80d (95% CI: 55 to 98) Wilcoxon chi-square suggests a difference between groups during the earlier part of follow-up (p = 0.040); the likelihood ratio chi-square indicates no overall difference in wound cavity filling time between groups (p = 0.41) | | 124d (105,284) No difference in time to closure between groups (Wilcoxon chi-square, P = 0.29

NR Not reported

RCT Randomized controlled trial

SOC Standard of care

VAS Visual analogue scale

* All studies reported using V.A.C.® (KCI, USA Inc.)

Table 23 Study Design Characteristics of Comparison Studies of NPWT Devices^*^ Used to Treat Diabetic Foot and Pressure Ulcers

Reference | Study Type | Wound Type | Number of Patients Entrolled | Comparison Treatment | Inclusion Criteria | Exclusion Criteria | Length of Study | Attrition
Blume et al. 2008(108) | RCT^*^ | Diabetic foot ulcers (DFU) | 342 | Advanced moist wound therapy (AMWT) [underlined: AMWT:] Hydrogel 47% Alginates 31% Other 16.9% Saline 10.2% Collagen 6.6% Hydrocolloid 0.6% | Diabetic adults ≥18 years with a stage 2 or 3 (Wagner’s scale) calcaneal, dorsal, or plantar foot ulcer ≥2 cm^2^ in area after debridement | Recognized active Charcot disease or ulcers resulting from electrical, chemical, or radiation burns and those with collagen vascular disease, ulcer malignancy, untreated osteomyelitis, or cellulitis; uncontrolled hyperglycemia (A1C >12%) or inadequate lower extremity perfusion; ulcer treatment with normothermic or hyperbaric oxygen therapy; concomitant medications such as corticosteroids, immunosuppressive medications or autologous growth factor products; skin and dermal substitutes within 30 days of study start; or use of any enzymatic debridement treatments; pregnant or nursing mothers. | Incidence of complete ulcer closure or 112d | [underlined: NPWT:] n = 55 1 lost to f/u 54 discontinued [underlined: AMWT:] n = 48 5 lost to f/u 43 discontinued
Armstrong et al. 2007(109) | RCT^*^ | Diabetic foot amputation | 162 | Standard wound therapy (SWT) [underlined: SWT:] Alginates Hydrocolloids Foams Hydrogel | Individuals aged ≥18 years, presence of a diabetic foot amputation wound up to the tarso-metatarsal level of the foot and evidence of adequate perfusion. | Active Charcot arthropathy of the foot, wounds resulting from burns or venous insufficiency; patients presenting with untreated cellulitis or osteomyelitis (following amputation), collagen vascular disease, malignancy in the wound or uncontrolled hyperglycaemia; treated with corticosteroids, immunosuppressive medications or chemotherapy; treated with V.A.C.® within the past 30 days, present or previous treatment with growth factors, normothermic therapy, hyperbaric medicine or bioengineered tissue products within the past 30 days. | Until wound closure or 112 days | 19 NPWT and 19 SWT withdrew before wound closure
Wanner et al. 2003(118) | RCT^*^ | Pressure sores of the pelvic region | 22 | Gauze soaked with Ringer’s solution | Consecutive patients with pressure sores (deeper than grade 2 as described by Daniel et al.) of the pelvic region admitted to the Swiss Paraplegic Centre, Nottwil, Switzerland between January 1998 and May 1999. Patient population consisted of paraplegics or tetraplegics | NR | NR | NR
Ford et al. 2002(110) | RCT^*^ | Full-thickness decubitus ulcers | 28 | Healthpoint System (HP) | Patients recruited from the plastic surgery clinic and inpatient referral at Boston Medical Center with one to three full-thickness ulcers present for a minimum of 4 weeks; albumin ≥2.0; age 21–80; ulcer volume after debridement = 10–150 ml | Fistulae to organs or body cavities, malignancy in the wound, pregnant or lactating female, Hashimoto’s thyroiditis, Graves’ disease, iodine allergy, systemic sepsis, electrical burn, radiation exposure, chemical exposure, cancer, connective tissue disease, chronic renal or pulmonary disease, uncontrolled diabetes, corticosteroids or immunosuppressive agents, cardiac pacemaker, ferromagnetic clamps, recent placement of orthopedic hardware | 6 weeks | 6
Joseph et al. 2000(113) | RCT^*^ | Chronic non-healing | 24 | Saline wet-to-moist (WM) dressings | Patients with chronic non-healing wounds defined as an open wound in any anatomic location that had failed to close or show signs of healing within four weeks or greater; enrolled between January 1998–May 1999 at Boston Medical Center | Infection (urinary tract, pneumonia, wound infection); albumin <3.0 gm/dl; renal, pulmonary, or other chronic disease requiring ongoing therapy for stabilization; uncontrolled diabetes mellitus, thyroid disease, or hypertension; systemic steroids, other immunosuppressive therapy or anticoagulants; pregnant or breast feeding; Osteomyelitis as determined by bone biopsy; uncooperative or unsuitable candidates for participation in dressing changes; malignant or neoplastic diseases in wound margin; fistulae | 6 weeks | NR
Lavery et al. 2007(341) | Non-RCT^*^ | Diabetic Foot Ulcer | 1,721 | Wet-to-moist | [underlined: NPWT:] Data from a proprietary database maintained by KCI from patients treated for wound care between 1996 and 2004; presence of wound categorized as diabetic/ulcer neuropathic ulcer, wound treated with NPWT, wound of chronic nature, debridement of necrotic tissue performed, comprehensive diabetes management included with the case plan, reduction in pressure of affected ulcer, as needed and description of the wound size and duration prior to NPWT. [underlined: Control:] Patients from 5 RCTs published between 1992 and 1998 and included in a meta-analysis by Margolis et al.; chronic wounds categorized as diabetic/neuropathic ulcers, appropriate offloading, as needed, the presence of adequate perfusion, infection control (if present) and debridement of necrotic tissue. | [underlined: NPWT:] If untreated osteomyelitis or cancer was present within the wound, if there was no record of treatment termination or no reason was given for treatment termination, or if multiple treatment termination entries were present | [underlined: NPWT:] If closure through secondary intention or through a surgical intervention or if adequate granulation for closure by these methods was documented. [underlined: Control:] Wound was completely healed | NR
Schwien et al. 2005(126) | Non-RCT^*^ | Pressure Ulcer | 2,348 (60 V.A.C) | Any other wound care modality | Data from 1.94 million OASIS start-of-care assessments; start of care and end of care between July 1, 2002 and September 30, 2004; One stage III or one Stage IV pressure ulcer; primary diagnosis of 707.0 decubitus chronic skin ulcer | Patients who died at home; enteral or parenteral nutrition therapy; high risk factors or heavy smoking, alcohol dependency, or drug dependency; poor or unknown overall prognosis; secondary diagnosis of uncontrolled diabetes, cancer, systemic infections, or related to malnutrition/anemias/proteinemia | NR | NR
McCallon et al. 2000(120) | Non-RCT^*^ | Diabetic Foot | 10 | Saline-moistened gauze | Patients selected from the Diabetic Foot Clinic at Louisiana State University Health Science Center aged 18 to 75 years of age with a non-healing foot ulceration which had been present for longer than 1 month | Patients presenting with venous disease, patients with active infections not resolved by initial debridement; and patients with coagulopathy | Until satisfactory healing | NR

NR Not Reported

RCT Randomized controlled trial

* All studies reported using V.A.C.® (KCI, USA Inc.)

Table 24 Patient Characteristics in Comparison Studies of NPWT Devices^*^ Used to Treat Diabetic Foot and Pressure Ulcers

Reference | Study Type | Number of patients | Mean (SD) Age (years) | Sex | Comorbidities | Number of Wounds | Mean (SD) Baseline Wound Area (cm^2^) or Volume (cm^3^) | Severity of Wounds | Mean (SD) Duration of Ulcer
Blume et al.(108) | RCT | V.A.C.®: 172 | 58 ±12 | M141 F28 | Smoker: 34 Uses alcohol: 37 Diabetes (type1): 15 Diabetes (type2): 154 | 169 | 13.5 ± 18.2 | NR | 198.3 ± 323.5d
Blume et al.(108) | RCT | Advanced Moist Wound Therapy: 169 | 59 ± 12 | M122 F44 | Smoker: 32 Uses alcohol: 45 Diabetes (type1): 14 Diabetes (type2): 152 | 166 | 11.0 ± 12.7 | | 206.0 ± 365.9d
Armstrong et al.(109) | RCT | 77 V.A.C.® | 57.2 ±13.4^**^ 56 ± 12.3 65 ± 12.2 | M66^*^ F11 | Diabetes, alcohol and tobacco use | 63 acute 14 chronic | 22.8 ± 21.0 14.1 ± 17.9 | Acute and chronic | Acute: 0.4 (0.22) months Chronic: 5.0 (9.3) months
Armstrong et al.(109) | RCT | 85 Standard Wound Therapy | 60.1 ± 12.2^*^ 56 ± 12.3 65 ± 12.2 | M66^*^ F19 | Diabetes, alcohol and tobacco use | 59 acute 26 chronic | 22.8 ± 21.0 14.1 ± 17.9 | Acute and chronic | Acute: 0.4 (0.22) months Chronic: 5.0 (9.3) months
Wanner et al.(118) | RCT | 11 V.A.C.® | 49 (25–73) | 7M 4F | Vascular disorders - 0 Zinc depletion - 5 Hypoalbuminaemia - 3 Hypoproteinaemia - 5 Anemia - 8 Nicotine - 3 | 11 | 50 (33) Wound volume (ml) Range: 3–132 | Deeper than Grade 2 (at least a penetration in the subcutaneous fat) | NR
Wanner et al.(118) | RCT | 11 gauze soaked with Ringer's | 53 (34–77) | 8M 3F | Vascular disorders - 2 Zinc depletion - 5 Hypoalbuminaemia -1 Hypoproteinaemia - 3 Anemia - 5 Nicotine - 2 | 11 | 42(16) Wound volume (ml) Range: 5–68 | Deeper than Grade 2 (at least a penetration in the subcutaneous fat) | NR
Ford et al.(110) | RCT | N = 22 V.A.C.®-NR | 41.7 average | NR | NR | 20 | NR | Stage III or IV | NR
Ford et al.(110) | RCT | Healthpoint system - NR | 54.4 average | | | 15 | | Stage III or IV | NR
Joseph et al.(113) | RCT | N = 24 V.A.C.®NR | 56 | M 66% | NR | 18 Pressure -18 Dehiscence -1 Trauma -1 Venous insufficiency -2 Radiation -1 | 38 cm^3^ | NR | NR
Joseph et al.(113) | RCT | Saline wet-to-moist: NR | 49 | M 44% | | 18 Pressure-14 Dehiscence - 3 Trauma -1 Venous insufficiency -0 Radiation - 0 | 24 cm^3^ | NR | NR
Lavery et al.(341) | Non-RCT | V.A.C: 1,135 | 58.5 ± 9.4 | M 64.5% | NR | 1,135 | 13.8 ± 15.8 | NR | 26.5 ± 24.7 (wks)
Lavery et al.(341) | Non-RCT | Wet-to-moist: 586 | 58 | M 73.2% | | | 1.61 | | 30 (wks)
Schwien et al.(126) | Non-RCT | V.A.C.®: 60 | 65 ±18.27 | M28 F32 | Obesity-13 (22%) No. of secondary diagnosis-6 (10%) Diabetes as first secondary diagnosis - 5 At least one secondary diagnosis - 54 | NR | NR | Stage III or IV | NR
Schwien et al.(126) | Non-RCT | Control: 2,288 | 71.4 ± 18.14 | M961 F 1,327 | Obesity-290 (13%) No. of secondary diagnosis-264 (12%) Diabetes as first secondary diagnosis -138(6%) At least one secondary diagnosis-2,024 | NR | NR | Stage III or IV | NR
McCallon et al.(120) | Non-RCT | V.A.C.®: 5 | 55.4 (±12.8) | NR | Hemoglobin, albumin, and blood glucose levels comparable at baseline | 5 | NR | Non-healing | NR
McCallon et al.(120) | Non-RCT | Control: 5 | 50.2 (±8.7) | | | 5 | NR | Non-healing | NR

NR Not reported

RCT Randomized controlled trial

* All studies reported using V.A.C.® (KCI, USA Inc.)

** Patient characteristics retrieved from primary study(195)

Table 25 Treatment-Related Characteristics in Comparison Studies of NPWT Devices^*^ Used to Treat Diabetic Foot and Pressure Ulcers

Reference | Study Type | Treatments (include type of NPWT dressing) | Treatment Change | Wound Assessment | Frequency of Measurements | Treatment Duration | Prior Treatments | Concurrent Treatments
Blume et al.(108) | RCT | V.A.C.® CNP: mmHg NR Foam dressing | Every 48–72 h No less than 3x/wk | Wound examination and tracings | Weekly for 4 weeks then every other week until day 112 or ulcer closure | Complete ulcer closure defined as skin closure (100% re-epithelization) without drainage or dressing requirements OR day 112 | Treated for ulcer infection prior to randomization: 50 | - Surgical debridement; - Standard off-loading therapy; - Wounds for 9.5% of NPWT and 8.4% of AMWT-treated were later surgically closed by split thickness skin graft, flaps, sutures, or amputations
Blume et al.(108) | RCT | Advanced Moist Wound Therapy (AMWT) | As specified by Wound, Ostomy and Continence Nurses Society guidelines and institutional treatment protocols | Wound examination and tracings | Weekly for 4 weeks then every other week until day 112 or ulcer closure | Complete ulcer closure defined as skin closure (100% re-epithelization) without drainage or dressing requirements OR day 112 | Treated for ulcer infection prior to randomization: 45 | - Surgical debridement; - Standard off-loading therapy; - Wounds for 9.5% of NPWT and 8.4% of AMWT-treated were later surgically closed by split thickness skin graft, flaps, sutures, or amputations
Armstrong et al.(109) | RCT | V.A.C.® Foam dressing | Every 48 hrs | Digital photos and tracing | Days 0, 7, 14, 28, 42, 56, 84, and 112 | Until wound closure (100% reepithelialization without drainage) or until completion of 112 day period of assessment | NR | - Off- loading therapy with a pressure relief walker or sandal; - Surgical debridement; - 31 NPWT and 25 SWT had complete wound closure without surgical closure; - 12 NPWT and 8 SWT had complete wound closure with surgical intervention; - 15 NPWT and 33 SWT completed active phase of study without complete wound closure
Armstrong et al.(109) | RCT | Standard Wound Therapy (SWT) | According to standardized guidelines | Digital photos and tracing | Days 0, 7, 14, 28, 42, 56, 84, and 112 | Until wound closure (100% reepithelialization without drainage) or until completion of 112 day period of assessment | NR
Wanner et al.(118) | RCT | V.A.C.® continuous at 125 mmHg Polyvinyl foam and transparent polyurethane dressing | Every 2–7 days | One wound assessor; volume was calculated by covering the ulcer with a transparent, elastic polymer (OpSite, Smith & Nephew). Sheet was punctured at the highest point and 0.9% saline solution was injected through a hypodermic needle until no air was left in the cavity. The injected volume was measured. | Every 7 days after initial measure in the operating room (value considered 100%) | Until wound volume had decreased by 50% (at which time the wound was closed with a flap) | NR | - Surgical debridement; - Ulcers closed with a flap after study treatment
Wanner et al.(118) | RCT | Gauze soaked with Ringer’s solution | 3x/day until clean granulation tissue was observed. Then wound kept wet with Ringer’s and dressing changed 1–3x/day | | Every 7 days after initial measure in the operating room (value considered 100%) | Until wound volume had decreased by 50% (at which time the wound was closed with a flap) | NR | - Surgical debridement; - Ulcers closed with a flap after study treatment
Ford et al.(110) | RCT | V.A.C.® | Mon/Wed/Fri | At 3 weeks, a photograph of the wound site; a plaster wound impression; and measurement of wound dimensions. At 6 weeks, a series of post-treatment tests consisting of a photograph of wound site; a soft-tissue biopsy; a plaster wound impression; and measurement of wound dimensions. Repeat bone biopsy/MRI if performed at pretest. | 3 and 6 weeks | 6 weeks (f/u ranged from 3–10 months) | Patients with osteomyelitis received a 6-week course of systemic antibiotics | - Surgical debridement; - Strict pressure reduction with appropriate beds and positioning; - patients with 3 wounds underwent additional 6 week treatment of opposing treatment; - 6 wounds in the V.A.C.® group (30%) and 6 wounds in the HP group (40%) underwent flap surgery
Ford et al.(110) | RCT | HP | once or twice/daily
Joseph et al.(113) | RCT | V.A.C.® Pressure NR Open-cell foam dressing | Every 48 hours | Photography and measured by volume displacement of alginate impression molds | 3 and 6 weeks or until wound closure | Complete wound closure not a realistic end point since wounds were of variable sizes and anatomic locations | All patients had previously failed multiple medical and surgical wound treatments. Two patients (V.A.C.®) previously had bypass grafting for revascularization. Both eventually required amputation. | - Pressure-relieving surface; - Debridement within 48h of treatment initiation; - Rigorous nutritional assessment
Joseph et al.(113) | RCT | WM – closed system including Bioclusive Transparent Dressing (Johnson and Johnson) | 3x/day plus saline applied 3x/day | Photography and measured by volume displacement of alginate impression molds | 3 and 6 weeks or until wound closure | Complete wound closure not a realistic end point since wounds were of variable sizes and anatomic locations | All patients had previously failed multiple medical and surgical wound treatments. Two patients (V.A.C.®) previously had bypass grafting for revascularization. Both eventually required amputation. | - Pressure-relieving surface; - Debridement within 48h of treatment initiation; - Rigorous nutritional assessment
Lavery et al.(341) | Non-RCT | V.A.C.® NR | Every 48 hrs | NR | 12 and 20 weeks | Successful treatment endpoint if closure through secondary endpoint or through a surgical intervention (i.e., flaps, grafts and primary closure) or if adequate granulation for closure by these methods was documented. | NR | Surgical debridement
Lavery et al.(341) | Non-RCT | Wet-to-moist | well-monitored care – patients from 5 RCTs | | | Successful treatment endpoint when either the wound was completely healed, i.e., wound closure (no drainage) or full epithelialization with no drainage. | | Surgical debridement
Schwien et al.(126) | Non-RCT | V.A.C.® NR | NR | NR | Tracked while NPWT was applied plus 7 days following removal | NR | NR | NR
Schwien et al.(126) | Non-RCT | Control NR | NR | | Tracked start of care through end of care | NR | NR | NR
McCallon et al. 2000(120) | Non-RCT | V.A.C.® Continuous at 125 mmHg for first 48 hours/Intermittent suction (125 mmHg) applied thereafter Foam dressing as provided by the manufacturer | Every 48 hours | Wound border traced with fine-tipped marker onto a piece of clear acetate film. Progress assessed by photography. | Every 48 hours at each dressing change | Until satisfactory healing occurred and defined as:; 1. Delayed primary intention. Split-thickness skin graft, myocutaneous flap, or suture closure; 2. Secondary intention. Granulation tissue formation and epithelialization. | NR | - Surgical debridement; - Strict non-weight bearing or bedrest
McCallon et al. 2000(120) | Non-RCT | Saline-moistened gauze (wounds not allowed to desiccate) | Twice a day | Wound border traced with fine-tipped marker onto a piece of clear acetate film. Progress assessed by photography. | 3x/week | | NR | - Surgical debridement; - Strict non-weight bearing or bedrest

NR Not reported

RCT Randomized controlled trial

* All studies reported using V.A.C.® (KCI, USA Inc.)

Table 26 Results for Outcome Measures Reported in Comparison Studies of NPWT Devices^*^ Used to Treat Diabetic Foot and Pressure Ulcers

Reference | Study Type | Treatments | N | Wounds Healed | Mean (SD) Change in Wound Area (cm^2^) or Volume (cm^3^) | Satisfactory Healing | Other Important Outcomes | Adverse Events Resulting in Discontinuation of Treatment
Blume et al.(108) | RCT | V.A.C.® | 169 | 73 (43.2%) | Reported for day 28 −4.32 (significant difference; P = 0.021) | 63.6 ± 36.57 days (mean ± SD) | NR | 22
Blume et al.(108) | RCT | Advanced Moist Wound Therapy (AMWT) | 166 | 48 (28.9%) | Reported for day 28 −2.53 | 78.1 ± 39.29 days (mean ±SD) | | 18
Armstrong et al.(109) | RCT | V.A.C.® | 63 acute (51.6%) 14 chronic (35%) | 34 acute (54%) 9 chronic (64.3%) | NR | Log-rank test comparing the time-to-event profiles was significant in favor of NPWT group over SWT for acute wounds (P = 0.030) | NR | NR
Armstrong et al.(109) | RCT | Standard Wound Therapy (SWT) | 59 acute (48.4%) 26 chronic (65%) | 22 acute (37.3%) 11 chronic (42.3%) | | Log-rank test comparing the time-to-event profiles was significant in favor of NPWT group over SWT for acute wounds (P = 0.030)
Wanner et al.(118) | RCT | V.A.C.® | 11 | 11 | Decrease over time similar in both groups. Increase in volume was often measured 7d after first measurements in both groups. | 27(10)d mean(SD) | NR | NR
Wanner et al.(118) | RCT | Gauze soaked with Ringer's solution | 11 | 11 | Decrease over time similar in both groups. Increase in volume was often measured 7d after first measurements in both groups. | 28 (7) d mean (SD)
Ford et al.(110) | RCT | V.A.C.® | 20 | 2(10%) | 51.8% - mean % reduction in volume Mean reduction in length, width, and depth respectively were 36.9 cm, 40.0 cm, and 33.6 cm | NR | NR | Coronary artery disease -1 Respiratory arrest secondary to Guillain-Barre -1 Treatment group not reported
Ford et al.(110) | RCT | Healthpoint System (HP) | 15 | 2(13%) | 42.1%- mean % reduction in volume Mean reduction in length, width and depth respectively were 18.7 cm, 19.0 cm, and 31.0 cm (p = 0.10, p = 0.11, p = 0.90 respectively)
Joseph et al.(113) | RCT | V.A.C.® | NR | NR | Percent change in wound volume over time: 78% (p = 0.038) Change in depth: 66% (p<0.00001) Change in width over time: p = 0.02 No significant difference in change in length between groups (p = 0.38) | NR | Granulation tissue formation in 13(64% of wounds) | NR
Joseph et al.(113) | RCT | Moist wound therapy | | | Percent change in wound volume over time: 30% Change in depth: 20% | | An adequate (100%) granulating bed rarely seen | NR
Lavery et al.(341) | Non-RCT | V.A.C.® | 1135 | 39.5% (12 wk) 46.3% (20 wk) | NR | NR | NR | NR
Lavery et al.(341) | Non-RCT | Wet-to-moist | 586 | 23.9% (12 wk) 32.8% (20 wk) | NR | NR | NR | NR
Schwien et al.(126) | Non-RCT | V.A.C.® | NR | | NR | NR | Instances of hospitalization for wound problem (n, %) Stage III-1 (3%) Stage IV-2 (7%) Total - 3 (5%) Instances of emergent care for wound problem (n, %) Stage III-0 Stage IV-0 Total - 0 | NR
Schwien et al.(126) | Non-RCT | Control | NR | | NR | NR | Instances of hospitalization for wound problem (n, %) Stage III-194 (11%) Stage IV-116 (20%) Total-310 (14%) Instances of emergent care for wound problem (n, %) Stage III-126 (7%) Stage IV-63 (11%) Total-189 (8%) | NR
McCallon et al. 2000(120) | Non-RCT | V.A.C.® | 5 | # of wounds decreased in size = 4 (healed by delayed primary intention) # of wounds increased in size = 1 (healed by secondary intention) | 28.4% (±24.3) average decrease | Average: 22.8 (±17.4) days | NR | NR
McCallon et al. 2000(120) | Non-RCT | Saline-moistened gauze | 5 | # of wounds decreased in size = 2 (healed by delayed primary intention) # of wounds increased in size = 3 (healed by secondary intention) | 9.5% (±16.9) average increase | Average: 42.8 (±32.5) days | NR | NR

NR Not reported

RCT Randomized controlled trial

* All studies reported using V.A.C.® (KCI, USA Inc.)

## Skin Graft

Table 27 Key Study Design Characteristics of Comparison Studies of NPWT Devices^*^ Used to Secure Skin Graft

Reference | Study Type | Wound Type | Number of Patients Enrolled | Comparison Treatment | Inclusion Criteria | Exclusion Criteria | Length of Study | Attrition
Vuerstaek et al. 2006(115) | RCT | Chronic leg | 60 | Conventional (hydrocolloids, alginates) | All patients hospitalized with chronic, venous, combined venous and arterial, or microangiopathic (arteriolosclerotic) leg ulcers of >6 month’s duration; after surgical treatment options had been exhausted and extensive ambulatory treatment (>6 months) in an outpatient clinic according to the Scottish Intercollegiate Guideline Network (SIGN) had failed | Ulcer chronicity <6 months duration, age >85 years old, the use of immune suppression, allergy to wound products, malignant or vasculitis origin, or ABI <0.60 | 12 months | 11
Moisidis et al. 2004(112) | RCT | Split-thickness skin graft (STSG) | 22 (patients used as own controls) | Bolster dressing | Adults admitted to Liverpool Hospital from July 2001 to July 2002 with wounds 25 cm^2^ or larger and clinically ready for skin grafting | NR | 2 weeks | 2
Korber et al. 2008(340) | Non-RCT | Chronic leg ulcer | 54 | SOC | Mesh grafts transplanted in the Department of Dermatology, Essen, Germany from April 2003 to April 2005 | NR | NR | NR
Vidrine et al. 2005(342) | Non-RCT | STSG | 44 | Bolster dressing plus splint | Consecutive skin-grafted radial forearm donor sites treated between October 2003 and November 2004 | NR | 4 weeks | NR
Stone et al. 2004(133) | Non-RCT | STSG | 40 | Cotton bolster dressing | Trauma patients admitted between January 2001 and January 2003 to Charleston Area Medical Center, WV who received STSG | 2 burn patients with heavily contaminated and extremely large wounds | Grafts considered completely successful or total failures
Scherer et al. 2002(132) | Non-RCT | STSG | 61 | Cotton bolster dressing | Identified all patients on the trauma surgery service who required STSG during an 18-month period | NR | NR | NR
Genecov et al. 1998(131) | Non-RCT | STSG | 10 (patients used as own controls) | OpSite | Patients requiring coverage of denuded surfaces | NR | 7 days | NR

NR Not reported

RCT Randomized controlled trial

* All studies reported using V.A.C.® (KCI, USA Inc.)

Table 28 Patient Characteristics in Comparison Studies of NPWT Devices^*^ Used to Secure Skin Graft

Reference | Study Type | Number of Patients | Mean (SD) Age (years) | Sex | Comorbidities | Number of Wounds | Mean (SD) Baseline Wound Area (cm^2^) or Volume (cm^3^) | Severity of Wounds | Mean (SD) Duration of Wound
Vuerstaek et al.(115) | RCT | V.A.C.®: 30 | Median: 74 Range: 53–81 | M7 F23 | Smoking: 6 (21%) Diabetes mellitus type II: 5 (17%) Immobility: 12 (41%) Hypertension: 13 (45%) Infection signs: 8 (28%) | NR | Median: 33 Range: 2–150 | [underlined: Ulcer type] Venous origin: 13 Combined venous/arterial origin: 4 Arteriolosclerotic origin: 13 | 8 Median (Range: 6–24)
Vuerstaek et al.(115) | RCT | Control: 30 | Median: 72 Range: 45–83 | M7 F23 | Smoking: 9 (30%) Diabetes mellitus type II: 5 (17%) Immobility: 13 (43%) Hypertension: 12 (40%) Infection signs: 6 (20%) | | Median: 43 Range: 3–250 | Venous origin: 13 Combined venous/arterial origin: 4 Arteriolosclerotic origin: 13 | 7 Median (Range: 6–12)
Moisidis et al.(112) | RCT | 20 | Median: 64 Range: 27–88 | M12 F8 | NR | 20 | 128 cm^2^ Range: 35 to 450 cm^2^ | Acute: 10 Subacute or chronic (>5d): 10 | 18d (Range: 0 to 90d)
Korber et al.(340) | Non-RCT | Total: 54 V.A.C.®: NR | 66.1 | M23 F31 | Diabetes: 15 | 28 | Comparable | NR | NR
Korber et al.(340) | Non-RCT | Control: NR | 69.8 | M23 F31 | Diabetes: 15 | 46 | Comparable | NR | NR
Vidrine et al.(342) | Non-RCT | V.A.C.®: NR | 62 | M16 to F19 ratio | NR | 20 | 59 (21) | NR | NR
Vidrine et al.(342) | Non-RCT | Control: NR | 60 | M18 to F25 ratio | | 25 | 56 (27) | | NR
Stone et al.(133) | Non-RCT | V.A.C.®: 17 | 35.4 ±14 | NR | NR | 21 | 105.6 (88) | Wound Site: Face:1 Torso: 3 Extremity: 17 | NR
Stone et al.(133) | Non-RCT | Control: 23 | 39.0 ±16.7 | | | 25 | 150.2 (78) | | NR
Scherer et al.(132) | Non-RCT | V.A.C.®: 34 | 33 ±23 | NR | NR | NR | Graft size, cm^2^ 387 ±573 | NR | NR
Scherer et al.(132) | Non-RCT | Control: 27 | 41 ±20 | | | | 984 ±996 | | NR
Genecov et al.(131) | Non-RCT | 10 | Range: 39 to 81 | M4 F6 | Paraplegia: 2 Diabetes mellitus: 4 Systemic infections: 2 Hemodialysis dependence: 3 Traumatic wounds: 3 | 10 | 32–380 cm^2^ | NR | NR

NR Not Reported

RCT Randomized controlled trial

* All studies reported using V.A.C.® (KCI, USA Inc.)

Table 29 Treatment-Related Characteristics in Comparison Studies of NPWT Devices^*^ Used to Secure Skin Graft

Reference | Study Type | Treatments | Treatment Change | Wound Assessment | Frequency of Measurements | Treatment Duration | Prior Treatments | Concurrent Treatments
Vuerstaek et al.(115) | RCT | V.A.C.® Continuous Negative Pressure (CNP): −125 mmHg Foam dressing | Day 4 | NR | Twice a week until wound closure | [underlined: Wound healing]; 1. Wound bed preparation defined as the time between debridement and application of the punch skin grafts; 2. Time to complete healing (primary end point) defined as the period between debridement and 100% epithelialization (wound closure). | Ambulatory conservative local treatment (6 months) | - Debridement; - Post-graft all patients received treatment with a non-adhesive dressing and compression bandage
Vuerstaek et al.(115) | RCT | Control SOC according to SIGN guideline and compression therapy | Day 4 | | Twice a week until wound closure | | Ambulatory conservative local treatment (6 months) | - Debridement; - Post-graft all patients received treatment with a non-adhesive dressing and compression bandage
Moisidis et al.(112) | RCT | V.A.C.® CNP: −100 mmHg Foam sponge | Left intact for 5d Patients used as own controls NPWT used on superior half in 10 patients and inferior half in remaining 10 | At 2 weeks | NR | Graft take was recorded both quantitatively (expressed as a percentage of epithelialization (recorded by gross inspection) and qualitatively (rated as poor, satisfactory, good or excellent) | 3 patients experienced prior graft failure | - If grafts were placed on lower limbs, patients were immobilized with leg elevation and deep venous thrombosis prophylaxis; - Once dressing was removed, the entire graft was treated with daily petroleum gauze, saline-soaked gauze and crepe.
Moisidis et al.(112) | RCT | Control Mepitel, Acriflavice wool and foam sponge | Left intact for 5d Patients used as own controls NPWT used on superior half in 10 patients and inferior half in remaining 10 | At 2 weeks | NR | Graft take was recorded both quantitatively (expressed as a percentage of epithelialization (recorded by gross inspection) and qualitatively (rated as poor, satisfactory, good or excellent) | 3 patients experienced prior graft failure
Korber et al.(340) | Non-RCT | V.A.C.® Black sponge −125 mmHg | 1^st^ between postoperative day 5 or 7 | NR | Between day 10 and 14 | Mesh graft take | NR | Postoperative compression therapy for patients with venous leg ulcer or a mixed ulcer
Korber et al.(340) | Non-RCT | Control | 1^st^ between postoperative day 5 or 7 | | | | | Postoperative compression therapy for patients with venous leg ulcer or a mixed ulcer
Vidrine et al.(342) | Non-RCT | V.A.C.®/Control | Removed between day 4 and 6 | Senior author | Day 7 (1 week) and week 4 | 4 weeks | NR | NR
Stone et al.(133) | Non-RCT | V.A.C.®/control | NR | NR | NR | Completely successful graft take | NR
Scherer et al.(132) | Non-RCT | V.A.C.® CNP: −125 mmHg | 4^th^ postoperative day unless signs suggested infection | NR | NR | Successful graft take | NR | Bed rest, a sling, or a splint
Scherer et al.(132) | Non-RCT | Control | 4^th^ postoperative day unless signs suggested infection | NR | NR | Successful graft take | NR | Bed rest, a sling, or a splint
Genecov et al.(131) | Non-RCT | V.A.C.® | Days 4 and 7 | Blinded assessor analyzed biopsies | | Degree of reepithelialization | NR | NR
Genecov et al.(131) | Non-RCT | Control | Days 4 and 7 | Blinded assessor analyzed biopsies | | Degree of reepithelialization | NR | 3.33

CNP Continuous negative pressure

NR Not reported

RCT Randomized controlled trial

SOC Standard of care

* All studies reported using V.A.C.® (KCI, USA Inc.)

Table 30 Results for Outcome Measures Reported in Comparison Studies of NPWT Devices^*^ Used to Secure Skin Graft

Reference | Study Type | Treatments | N | Wounds Healed | Mean (SD) Change in Wound Area (cm^2^) or Volume (cm^3^) | Satisfactory Healing | Other Important Outcomes | Adverse Events Resulting in Discontinuation of Treatment
Vuerstaek et al.(115) | RCT | V.A.C.® | 30 | 29 | NR | Primary endpoint Time to complete healing: 29d(95% CI: 25.5 to 32.5) Secondary endpoint Median percentage skin graft survival: 83% | Ulcer relapse at 1 year follow-up: 52% QOL measured by EQ-5D: 77 Pain measured by SF-MPQ: 1 | NR
Vuerstaek et al.(115) | RCT | Control | 30 | 29 | | Time to complete healing: 45d (95% CI: 36.2 to 53.8) Median percentage skin graft survival: 70% | Ulcer relapse at 1 year follow-up: 42% QOL measured by EQ-5D: 76 Pain measured by SF-MPQ: 1 | NR
Moisidis et al.(112) | RCT | V.A.C.® | 20 patients used as own controls | 20 | NR | Quantitative (degree of epithelization): not significant Greater degree: 6 (30%) Same degree: 9 (45%) Less: 5 (25%) Qualitative Graft take: Subjectively determined to be significantly better: Better: 10 (50%) Equivalent: 7 (35%) Worse: 3 (15%) | NR | NR
Korber et al.(340) | Non-RCT | V.A.C.® | NR (28 wounds) | 26 | NR | Mesh graft take rate: 92.9% | NR | NR
Korber et al.(340) | Non-RCT | Control | NR (46 wounds) | | 31 | 67.4% | | NR
Vidrine et al.(342) | Non-RCT | V.A.C.® | NR (20 wounds) | 20 | Average graft take at 1 wk: 99% Average graft take at 4 wk: 92% | Overall complete STSG take rate: 60% | NR | NR
Vidrine et al.(342) | Non-RCT | Control | NR (25 wounds) | 25 | Average graft take at 1 wk: 97% Average graft take at 4 wk: 81 | Overall complete STSG take rate: 52% | | NR
Stone et al.(133) | Non-RCT | V.A.C.® | 17 (21 grafts) | Graft take: 100% | n/a | Duration of dressing: 4.8 ±0.8 | Mean hospital stay: 20.9 ±10 | NR
Stone et al.(133) | Non-RCT | Control | 23 (25 grafts) | 1 graft failure | | 5.2 ±2.4 | 15.3 ±7.5 | NR
Scherer et al.(132) | Non-RCT | V.A.C.® | 34 | NR | NR | Graft take, % 96 ±6 | Repeat STSG to same site 1 (3%) Total LOS, d 27 ±16 | NR
Scherer et al.(132) | Non-RCT | Control | 27 | | | 89 ±20 | Repeat STSG to same site 5 (19%) Total LOS, d 32 ±25 | NR
Genecov et al.(131) | Non-RCT | V.A.C.®/Control | 10 (used as own controls) | 10 | NR | V.A.C.® re-epithelialize faster than control: 7 No difference in rate of reepithelialization: 2 More rapid reepithelialization with OpSite: 1 | NR | NR

EQ-5D EuroQol group quality-of-life instrument

NR Not reported

RCT Randomized controlled trial

SF-MPQ Short Form-McGill Pain Questionnaire

* All studies reported using V.A.C.® (KCI, USA Inc.)

## Acute Wounds

Table 31 Key Study Design Characteristics of Comparison Studies of NPWT Devices^*^ Used to Treat Acute Wounds

Reference | Study Type | Wound Type | Number of Patients Enrolled | Comparison Treatment | Inclusion Criteria | Exclusion Criteria | Length of Study | Attrition
Stannard et al. 2006(125) | RCT | Postoperative wounds | Study 1: 44 Study 2: 44 | Study 1: pressure dressing Study 2: post-operative dressing | [underlined: Hematoma study]: Age >18 years; involvement in traumatic injury with subsequent surgical incision which drained a minimum of 5d after surgery; and willingness to comply with the protocol. [underlined: Fracture study]: Patients with one of three high-risk fractures after high-energy trauma-calcaneus, pilon, and tibial plateau (Schatzker IV through VI); age >18 yrs; and willingness to comply with the study protocol. | [underlined: Hematoma study]: Surgical incisions that did not have at least moderate drainage for 5d after surgery; infection of the wound; neoplasm involving the wound; pregnancy; or the presence of a fistula. [underlined: Fracture study]: Low-energy fracture pattern tibial plateau fractures’ nonoperative, percutaneous treatment, or external fixation as the primary form of stabilization; open fractures that require repeat debridement; skin or soft tissue neoplasm involving the incision site; and pregnancy. | NR | NR
Timmers et al.(106) | Non-RCT | Post-traumatic osteomyelitis | 124 | SOC | Consecutive patients with osteomyelitis with one recurrence who presented at the Leiden University Medical Center between March 1999 and February 2003. | NR | Until either two consecutive culture swabs taken within a few days had become sterile or when enough new granulation tissue had formed to permit surgical wound closure. | NR
Simek et al. 2008(123) | Non-RCT | Deep sternal | 62 | Conventional (debridement, chest rewiring, closed irrigation) | Patients undergoing treatment for deep sternal wound infection from March 2002 to December 2007 | NR | 1 year follow up | NR
Yang et al.(72) | Non-RCT | Fasciotomy | 68 | Saline-soaked wet-to-dry dressings | Patients who underwent two-incision fasciotomies for documented, traumatic compartment syndrome of the leg with the release of all four compartments | NR | Time to definitive closure by either delayed primary closure with sutures or split-thickness skin graft coverage | NR
Fuchs et al. 2005(23) | Non-RCT | Deep sternal | 68 | Conventional | Incidence of deep sternal wound infections from bypass or heart valve replacements from 1998 to 2000 treated with conventional treatment and from 2000 to 2003 treated with V.A.C.®; sternal infections met the criteria of the Centers for Disease Control and Prevention | NR | Follow up at least until the sternum was rewired (primary wound healing), until wound healing was achieved without rewiring (secondary wound healing), or until the patient died with an open sternum | NR
Immer et al. 2005(130) | Non-RCT | Deep sternal wound infection (DSWI) | 55 | Sternal excision and musculocutaneous flap | Patients with DSWI (El Oakley class 2B) from sternotomies performed between January 1998 and December 2003; diagnosis based on sternal dehiscence and positive bacteriologic culture of the sternum or the anterior mediastinum. | NR | NR | NR
Segers et al. 2005(122) | Non-RCT | Post-sternotomy mediastinitis (PM) | 63 | Closed drainage technique (CDT) | All patients treated from PM after cardiac surgery at the Academic Medical Center between 1/1/92 and 12/31/03 | NR | NR | 29% (18 deaths; 9 NPWT, 9 control)
Sjogren et al. 2005(139) | Non-RCT | PM | 101 | Conventional (open dressings, closed irrigation, pectoral muscle flaps or omentum flaps) | At least one of the following CDC criteria for PM:; 1. an organism isolated from culture of mediastinal tissue or fluid;; 2. evidence of mediastinitis was seen during operation;; 3. one of the following conditions, chest pain, sterna instability, or fever (>38° C) was present and there was either purulent discharge from the mediastinum or an organism isolated from blood culture or culture of drainage of the mediastinal area. | Patients presenting signs of infection but with negative substernal tissue cultures; patients with sterile dehiscences or superficial sternal wound infections | NR | NR
Domkowski et al. 2003(129) | Non-RCT | PM | 102 | Standard of Care (SOC) | Between 1997 and 2002, patients from Duke University Hospital, The Durham VA Hospital | Patients with superficial wound infections or fat necrosis | NR | NR
Song et al. 2003(124) | Non-RCT | Sternal | 35 | SOC | 35 consecutive patients who suffered complications of their cardiac procedure resulting in a sternal wound from March 1999 to March 2001; all patients had a median sternotomy and all sternal wounds involved the tissues superficial and deep to the sternum | NR | NR | NR
Doss et al. 2002(128) | Non-RCT | Post-sternotomy Osteomyelitis | 42 | SOC | Patients treated for post-sternotomy Osteomyelitis (SOM) between 1998 and 2000 | NR | NR | NR
Catarino et al. 2000(137) | Non-RCT | Post-sternotomy mediastinitis (PM) | 17 | Closed drainage and irrigation (CDI) | Patients with post-sternotomy mediastinitis (PM) occurring from September 1998 to August 1999 (group A) and from September 1997 to August 1998 (group B). All patients had sternal dehiscence and an infected mediastinum. | Superficial sternal wound infections, suture and wire abscesses, chronic sternal osteomyelitis, and sterile sternal dehiscences | Until wound closure | NR
Shilt et al. 2004(138) | Non-RCT | Traumatic Wounds | 31 | Standard of care (SOC) | Medical records of patients <18 years admitted to Wake Forest University School of Medicine, Winston-Salem, NC between 1992 and 2001 for treatment of lower extremity lawnmower injuries | Largest diameter of the wounds was <2 cm or if wound care consisted of primary closure | Upon wound healing or further reoperation | 1 control lost to f/u
Kamolz et al. 2003(343) | Non-RCT | Burn | 7 | Silver sulphadiazine crème | All patients of the last 5 months with bilateral partial thickness hand burns | Patients not admitted within the time interval of 6h after trauma; children <20 years of age, pregnant, and patients with a history of allergic reactions | Upon further reoperation or wound heal | NR
Gabriel et al. 2008(339) | Non-RCT | Infected | 30 | SOC | Trunk and extremity wounds with documented qualitative cultures with >10^5^ organisms, age >40 yrs, and documented necrotic tissue. V.A.C.®: patients with a diagnosis of complex, open, infected wounds treated with NPWT instillation between January 2005 and April 2006 Control: treated between January 2004 and December 2005 | NR | Until wound closure | NR
Ozturk et al. 2008(117) | Non-RCT | Fournier’s gangrene | 10 | SOC | Between January 2006 and August 2007 patients with Fournier’s gangrene and treated at the Dept of General Surgery, Uludag University School of Medicine, Bursa, Turkey | NR | Time to wound closure | NR
Rinker et al. 2008(121) | Non-RCT | Open Tibia Fracture | 105 (55 subacute analyzed) | SOC | Hospital and clinic records of 105 consecutive patients who underwent a free muscle flap for treatment of a Gustilo grade IIIB or IIIC tibia fracture between 1991 and 2005. | NR | NR | NR
Huang et al. 2006(127) | Non-RCT | Limb | 24 | SOC (gauze soaked with saline) | A diagnosis of acute necrotizing fasciitis | NR | NR | NR
Labler et al. 2004(71) | Non-RCT | Soft-tissue | 23 | Epigard® dressing | Patients with severe open fractures of the lower extremity classified as type IIIA or IIIB (Gustilo) and admitted as an emergency; all fractures result of a high-energy trauma | All type IIIC fractures due to associated valcular injuries | 12 months after definitive soft-tissue coverage

NR Not reported

RCT Randomized controlled trial

* All studies reported using V.A.C.® (KCI, USA Inc.)

Table 32 Patient Characteristics in Comparison Studies of NPWT Devices^*^ Used to Treat Acute Wounds

Reference | Study Type | Number of Patients | Mean (SD) Age (years) | Sex | Comorbidities | Number of Wounds | Mean (SD) Baseline Wound Area (cm^2^)or Volume (cm^3^) | Severity of Wounds | Mean (SD) Duration of Wound
Stannard et al.(125) | RCT | Hematoma study: 44 V.A.C.®: 13 | 48 yrs (21–96) | M36 F8 | NR | 44 | NR | Injury Severity Scores (ISS) 14.1 | <5d
Stannard et al.(125) | RCT | Control: 31 | 48 yrs (21–96) | M36 F8 | NR | 44 | NR | 13.9 | <5d
Stannard et al.(125) | RCT | Fracture study: V.A.C.®: 20 | 41 yrs (19–78) | M32 F12 | NR | 20 | NR | ISS 11.1 | NR
Stannard et al.(125) | RCT | Control: 24 | 41 yrs (19–78) | M32 F12 | NR | 24 | NR | 10.1 | NR
Timmers et al.(106) | Non-RCT | V.A.C.®: 30 | 52 (26–81) | M14 F16 | 18 (60%) diabetes mellitus, smoker, cardiovascular disease, pulmonary disease | 30 | NR | NR | NR
Timmers et al.(106) | Non-RCT | Control: 94 | 47 (9–85) | M58 F36 | 54 (57.4%) diabetes mellitus, smoker, cardiovascular disease, pulmonary disease | 94 | NR | NR | NR
Simek et al.(123) | Non-RCT | V.A.C.®: 34 | 66.4 ± 9.8 | M 52% F 48% | Diabetes mellitus: 52.9% COPD: 32.4% Immunosuppressive therapy: 14.7% Renal impairment: 23.5% | 34 | NR | NR | NR
Simek et al.(123) | Non-RCT | Control: 28 | 71.2 ± 7.9 | M 68% F 32% | Diabetes mellitus: 60.7% COPD: 25% Immunosuppressive therapy: 10.7% Renal impairment: 35.7% | 28 | NR | NR | NR
Yang et al.(72) | Non-RCT | V.A.C.®: 34 | NR | NR | NR | 68 | NR | NR | NR
Yang et al.(72) | Non-RCT | Control: 34 | NR | NR | NR | 70 | NR | NR | NR
Fuchs et al.(23) | Non-RCT | V.A.C.®: 35 | 68.5 (63.9–74.5) | M 76% | Diabetes - 55% Coronary heart disease - 97% | 35 | NR | Type I:0 Type II: 9 Type IIIa: 12 Type IIIb: 10 Type V: 4 | NR
Fuchs et al.(23) | Non-RCT | Control: 33 | 68.5 (64.4–74.9) | M 85% | Diabetes - 59% Coronary heart disease - 97% | 33 | NR | Type I:4 Type II: 1 Type IIIa: 17 Type IIIb: 4 Type V: 7 | NR
Immer et al.(130) | Non-RCT | V.A.C.® only: 19 | 60.1 ±11.8 | M13 F6 | COPD: 1 (5.3%) Diabetes: 7 (36.8) Immunosuppression: 2 (10.5%) Arterial hypertension: 13(68.4%) | 19 | NR | NR | Diagnosis DSWI (days) 17.5 ± 5.1
Immer et al.(130) | Non-RCT | V.A.C.® plus Excision and flap: 19 | 66.6 ± 7.2 | M14 F5 | COPD: 3 (15.8%) Diabetes 10 (52.6%) Immunosuppression: 1 (5.3%) Arterial hypertension: 14(73.7%) | 19 | NR | NR | 71.7 ± 213.7
Immer et al.(130) | Non-RCT | Excision plus flap: 17 | 69.5 ± 8.1 | M10 F7 | COPD: 6 (35.3%) Diabetes: 7 (41.2%) Immunosuppression: 0 Arterial hypertension: 17(100%) | 17 | NR | NR | 36.7 ±46.5
Segers et al.(122) | Non-RCT | V.A.C.®: 29 | 65.9 (38–81) | M17 F12 | Diabetes: 11 (37.9%) COPD:10(34.5%) | 29 | NR | Type I:4 (13.8%) Type II: 2 (6.9%) Type IIIa: 3 (10.3%) Type IIIb: 9 (31%) Type IVa: 9(31%) Type V: 2 (6.9%) | Presenting within 6 weeks after operation
Segers et al.(122) | Non-RCT | Control: 34 | 66.7 (20–81) | M30 F4 | Diabetes: 8 (23.5%) COPD:6(17.6%) | 34 | NR | Type I:7 (20.6%) Type II: 2 (5.9%) Type III: 8 (23.9%) Type IVa: 6 (17.6%) Type V: 1 (2.9%) | NR
Sjogren et al.(139) | Non-RCT | V.A.C.®: 61 | 67.3 (10.1) | M44 F17 | Diabetes: 26 (43%) Obesity: 23 (38%) LVEF <0.30: 14 (23%) COPD: 12 (20%) | 61 | NR | Type I:12 (20%) Type II: 7 (11%) Type IIIa: 13 (21%) Type IIIB: 26 (43%) Type IVa: 1 (2%) Type V: 2 (3%) | NR
Sjogren et al.(139) | Non-RCT | Control: 40 | 68.9 (7.8) | M38 F2 | Diabetes: 12 (30%) Obesity: 12 (30%) LVEF <0.30: 4(10%) COPD: 4(10%) | 40 | | Type I:10 (25%) Type II: 3 (8%) Type IIIa: 7(18%) Type IIIb: 7 (18%) Type IVa: 9 (23%) Type IVb: 2 (5%) Type V: 2 (5%)
Domkowski et al.(129) | Non-RCT | Data only reported for total study population | | NR | NR | NR | NR | NR | NR
Song et al.(124) | Non-RCT | V.A.C.®: 17 | 63(31–88) | M10 F7 | CABG: 14 Valve: 1 Aortic dissection: 3 Mediastinitis: 15 Chronic infection: 2 Sterile wound: 1 | 17 | NR | NR | Up to 6 weeks
Song et al.(124) | Non-RCT | Control: 18 | 63 (23–77) | M14 F4 | CABG: 13 Valve: 2 Heart transplant: 1 Pericardiectomy: 1 Mediastinitis: 13 Chronic infection: 3 Sterile wound: 1 | 18 | NR | | Up to 6 weeks
Doss et al.(128) | Non-RCT | V.A.C.®: 20 | Median: 66 (45–82) | M9 F11 | Bilateral internal mammary artery: 5 Diabetes: 9 COPD: 4 Overweight: 7 | 20 | NR | NR | Postoperative presentation: day 7 to 21
Doss et al.(128) | Non-RCT | Control: 22 | 66 (50–83) | M19 F3 | Bilateral internal mammary artery: 9 Diabetes: 9 COPD: 6 Overweight: 8 | 22 | | | day 5 to 31
Catarino et al.(137) | Non-RCT | V.A.C.®: 7 | 68 (64–74) | M5 F2 | Coronary heart disease; diabetes; and high BMI | 7 | NR | NR | NR
Catarino et al.(137) | Non-RCT | Control: 10 | 66 (46–75) | M7 F3 | Coronary heart disease; diabetes; and high BMI | 10 | NR
Shiltet al.(138) | Non-RCT | V.A.C.®: 16 | 3.9(1–8) | M10 F6 | NR | 16 | NR | With fractures-12 | NR
Shiltet al.(138) | Non-RCT | Standard of Care (SOC): 15 | 8.5(2–18) | M8 F7 | NR | 15 | NR | With fractures - 8 | NR
Kamolz et al.(343) | Non-RCT | V.A.C.®: 7 Patients used as their own controls | 44.2 (22.4) | NR | NR | 14 | NR | Partial thickness | <6h
Kamolz et al.(343) | Non-RCT | Silver sulphadiazine crème(SSD):7 | 44.2 (22.4) | NR | NR | 14 | NR | Partial thickness | <6h
Gabriel et al.(339) | Non-RCT | V.A.C.®: 15 | 57.13 ± 11.64 | NR | Necrotizing fasciitis - 3 Pressure ulcer - 2 Open joint-5 Surgical wound-1 Lower extremity wound -1 Soft tissue loss of lower extremity - 2 Abdominal surgical wound dehiscence -1 | 15 | 127.33 ± 137.87 | NR | NR
Gabriel et al.(339) | Non-RCT | Standard of Care (SOC): 15 | 59.40 ± 10.29 | | Necrotizing fasciitis - 4 Pressure ulcer - 5 Open joint-6 | 15 | 173.00 ± 123.73
Ozturk et al.(117) | Non-RCT | V.A.C.®: 5 | 56 (33–77) | M4 F1 | NR | 5 | NR | 3 local 2 disseminated | NR
Ozturk et al.(117) | Non-RCT | Control: 5 | 56(31–64) | M3 F3 | | 5 | | 3 local 2 disseminated
Rinker et al.(121) | Non-RCT | V.A.C.®: 17 | Median: 40 (Range: 11–64) | | NR | 60 flaps | NR | NR | Subacute wounds had flap performed on post-injury days 8 to 42
Rinker et al.(121) | Non-RCT | Control: 38 | Median: 40 (Range: 11–64) | | NR | 60 flaps | NR | NR | Subacute wounds had flap performed on post-injury days 8 to 42
Huang et al.(127) | Non-RCT | V.A.C.®: 12 | 57.75 | M7 F5 | Diabetes - 6 Fever - 6 Leukocytosis - 7 Shock - 3 Trauma - 3 Infection- 9 | 12 | Wounds varied between 30 and 15 cm in length and 13 and 3 cm in width | NR | NR
Huang et al.(127) | Non-RCT | SOC: 12 | 62.58 | M9 F3 | Diabetes - 9 Fever - 9 Leukocytosis -6 Shock - 2 Trauma - 4 Spontaneous infection - 8 | 12 | Wounds varied between 32 and 12 cm in length and 12 and 4 cm in width
Labler et al.(71) | Non-RCT | VAC®: 12 | Range: 18–68 | M8 F4 | NR | 14 | NR | Mangled Extremity Severity Score: 2(n = 1);3(2);4(3); 5 (4); 6 (2); 7 (2)
Labler et al.(71) | Non-RCT | Control: 11 | Range: 20–89 | M8 F3 | NR | 12 | NR | Mangled Extremity Severity Score: 2(1); 3 (3); 4 (3); 5 (3); 6(1); 9(1)

COPD Chronic obstructive pulmonary disease

LVEF Left ventricular ejection fraction

NR Not reported

NS Not significant

RCT Randomized controlled trial

* All studies reported using V.A.C.® (KCI, USA Inc.)

Table 33 Treatment-Related Characteristics in Comparison Studies of NPWT Devices^*^ Used to Treat Acute Wounds

Reference | Study Type | Treatments | Treatment Change | Wound Assessment | Frequency of Measurements | Treatment Duration | Prior Treatments | Concurrent Treatments
Stannard et al.(125) | RCT | Hematoma study: V.A.C.® | At least every other day | NR | NR | Until cessation of drainage of hematoma | NR | If drainage continued at day 10, patients returned to the OR for an evacuation of the hematoma with irrigation and debridement
Stannard et al.(125) | RCT | Dressing | Daily | | | Until cessation of drainage of hematoma | NR | If drainage continued at day 10, patients returned to the OR for an evacuation of the hematoma with irrigation and debridement
Stannard et al.(125) | RCT | Fracture study: V.A.C.® | NR | NR | NR | Wound drainage had dropped to grade 3 or below | NR | NR
Stannard et al.(125) | RCT | Control | | | | Wound drainage had dropped to grade 3 or below | NR | NR
Timmers et al.(106) | Non-RCT | V.A.C.® Polyvinyl alcohol (PVA) foam (instilled 2–3x/day) and pressures ranging from −300 mmHg to −600 mmHg | First day after debridement and subsequently every 3–4 days | Wound cultures | Each dressing change | Until two consecutive swabs taken a few days apart were either sterile or showed skin bacteria only, or when enough granulation tissue had grown into the wound to permit surgical wound closure. Alternatively, if spontaneous wound closure occurred during therapy, NPIT was ended. | NR | - Debridement; - Antibiotic therapy for a minimum of six weeks
Timmers et al.(106) | Non-RCT | Control | NR | NR
Simek et al.(123) | Non-RCT | V.A.C.® | NR | NR | NR | Wound bed was free of infection, covered by well-vascularized granulation tissue and the C-reactive protein level dropped to 50 mg/l, the chest was reclosed | NR | NR
Simek et al.(123) | Non-RCT | Control | NR | NR | NR | Wound bed was free of infection, covered by well-vascularized granulation tissue and the C-reactive protein level dropped to 50 mg/l, the chest was reclosed | NR | NR
Yang et al.(72) | Non-RCT | V.A.C.® CNP: −125 mmHg | Every 48 hours | NR | NR | Until wound closure by delayed primary fashion or covered with STSG | NR | Irrigation and debridement
Yang et al.(72) | Non-RCT | Control | NR | NR | NR | Until wound closure by delayed primary fashion or covered with STSG | NR | Irrigation and debridement
Fuchs et al.(23) | Non-RCT | V.A.C.® CNP: −125 to −150 mmHg With severe pain, −75 mmHg 3 polyurethane foam sponges | 3–7d | NR | NR | Freedom of the sternal wound from microbiological cultures | NR | - Wound Incision and removal of sternal wires; - aggressive debridement
Fuchs et al.(23) | Non-RCT | Control | NR | NR | NR | Freedom of the sternal wound from microbiological cultures | | - Wound Incision and removal of sternal wires; - aggressive debridement; - irrigation; - wound drainage; - packing/delayed closure
Immer et al.(130) | Non-RCT | V.A.C.® Pressure between −75 mm and −125 mm | 48–72 hrs | Bacteriologic cultures | NR | NR | NR | - Intravenous antibiotics; - Debridement every 48–72 hours
Immer et al.(130) | Non-RCT | V.A.C.® plus secondary sternal excision and musculocutaneous flap | 48–72 hrs | Bacteriologic cultures | NR | NR | NR | - Intravenous antibiotics; - Debridement every 48–72 hours
Immer et al.(130) | Non-RCT | Sternal excision + flap | 48–72 hrs | Bacteriologic cultures | NR | NR | NR | - Intravenous antibiotics; - Debridement every 48–72 hours
Segers et al.(122) | Non-RCT | V.A.C.® Continuous Negative Pressure (CNP): −125 mmHg Foam dressing | Initially after 48h; thereafter every 4–5d | NR | NR | A well-vascularized wound completely covered by granulation tissue, C-reactive protein levels were <50 mg/l and cultures did not show pathogenic bacteria, sternal closure was performed | NR | - Aggressive debridement
Segers et al.(122) | Non-RCT | Control | nr | NR | NR | A well-vascularized wound completely covered by granulation tissue, C-reactive protein levels were <50 mg/l and cultures did not show pathogenic bacteria, sternal closure was performed | NR | - Aggressive debridement
Sjogren et al.(139) | Non-RCT | V.A.C.® | | NR | NR | Wound considered clean including a bed of fresh granulation tissue, the sternum was rewired or, when necessary, additional wound-healing measures, i.e., omentoplasty and pectoralis flap | NR | - Surgical debridement
Sjogren et al.(139) | Non-RCT | Control | Several times daily | NR | NR | Wound considered clean including a bed of fresh granulation tissue, the sternum was rewired or, when necessary, additional wound-healing measures, i.e., omentoplasty and pectoralis flap | NR | - Surgical debridement
Domkowski et al.(129) | Non-RCT | V.A.C.® | NR | NR | NR | NR | NR | - Debridement
Domkowski et al.(129) | Non-RCT | SOC | NR | NR | NR | NR | NR | - Debridement
Song et al.(124) | Non-RCT | V.A.C.® CNP: −75 to −125 mmHg Foam dressing | Every other day | Plastic surgery and physical therapy staff | NR | Definitive closure determined by the gross appearance of the wound and hemodynamic stability of the patient | NR | - Surgical debridement; - Antimicrobial layer of Acticoat^*^ (Smith & Nephew)
Song et al.(124) | Non-RCT | Control | Twice a day | Plastic surgery and physical therapy staff | NR | Definitive closure determined by the gross appearance of the wound and hemodynamic stability of the patient | NR | - Surgical debridement; - Topical antimicrobial agent
Doss et al.(128) | Non-RCT | V.A.C.® −125 mmHg Foam dressing | Every 2–3d | NR | NR | Primary closure after granulation tissue filled the defect and all microbiological cultures were negative | NR | - Debridement
Doss et al.(128) | Non-RCT | Control | NR | NR | NR | Primary closure after granulation tissue filled the defect and all microbiological cultures were negative | NR | - Debridement
Catarino et al.(137) | Non-RCT | V.A.C.® CNP 125 mmHg Foam dressing | 48–72 hrs | NR | NR | Until wound closure; evident granulation tissue and negative microbiological cultures | NR | - Debridement; - broad-spectrum antibiotics
Catarino et al.(137) | Non-RCT | Control | | NR | NR | Until wound closure; evident granulation tissue and negative microbiological cultures | NR | - Debridement; - broad-spectrum antibiotics
Shilt et al.(138) | Non-RCT | V.A.C.® | Every 72 hours | NR | NR | 16.7d | Amputation 11 | Oral antibiotics (9) Intravenous antibiotic (15)
Shilt et al.(138) | Non-RCT | Control | | NR | NR | | 14
Kamolz et al.(343) | Non-RCT | V.A.C.® Open-cell polyurethane foam | Controlled daily | Use of Indocyanine Green (ICG) video angiographies | Daily | NR | NR | Intravenous injections of 0.2 mg/kg ICG
Kamolz et al.(343) | Non-RCT | Control | Controlled daily | Use of Indocyanine Green (ICG) video angiographies | Daily | NR | NR | Intravenous injections of 0.2 mg/kg ICG
Gabriel et al.(339) | Non-RCT | V.A.C.® Continuous Negative Pressure (CNP): −125 mmHg Foam dressing IV bag containing normal saline, sterile water or silver nitrate solution for instillation | NR | NR | Weekly | Until wound closure | NR | - Repeatedly sharply debrided
Gabriel et al.(339) | Non-RCT | Control | NR | NR | NR | Until wound closure | NR | - Repeatedly sharply debrided
Ozturk et al.(117) | Non-RCT | V.A.C.® CNP 125 mmHg GranuFoam® large dressing | Every 72 hrs in the OR | NR | NR | After wounds were clinically healed or wound cultures were negative, tertiary wound closure or split thickness grafting was performed | NR | - Surgical debridement
Ozturk et al.(117) | Non-RCT | Control | Daily or more if needed | NR | NR | After wounds were clinically healed or wound cultures were negative, tertiary wound closure or split thickness grafting was performed | NR | - Surgical debridement; - Taken into OR every 48 hours for dressing changes and jet lavage
Rinker et al.(121) | Non-RCT | V.A.C.® Intermittent: −125 mmHg; Petrolatum-impregnated gauze was placed between any exposed bone and the foam dressing | Every 48 hours | NR | NR | NR | NR | NR
Rinker et al.(121) | Non-RCT | Control (wet-to-dry gauze or a moist occlusive dressing) | NR
Huang et al.(127) | Non-RCT | V.A.C.® Intermittent: −125 mmHg | 48–72 hrs | NR | NR | Healed completely or when a minor procedure for closure was required, i.e., simple wound stitching or skin grafting | | Mean debridement per patient: 4.41
Huang et al.(127) | Non-RCT | Control | 3–6x/d | NR | NR | Healed completely or when a minor procedure for closure was required, i.e., simple wound stitching or skin grafting | | 3.33
Labler et al.(71) | Non-RCT | VAC® Foam CNP: −125 mmHg | Every 48 hours depending on wounds and patient’s condition | Bacterial cultures | Every 48 hours | Until primary or secondary closure | NR | - 3 debridements and primary immobilization of the fracture; - “Second-look” operations carried out every 48 hours which included subsequent thorough debridements, fracture, redislocation and repeated irrigation with normal saline.; - 3^rd^ generation cephalosporin
Labler et al.(71) | Non-RCT | Control | Every 48 hours depending on wounds and patient’s condition | Bacterial cultures | Every 48 hours | Until primary or secondary closure | NR

CNP Continuous negative pressure

NPIT Negative pressure instillation therapy

NR Not reported

RCT Randomized controlled trial

STSG Split-thickness skin graft

* All studies reported using V.A.C.® (KCI, USA Inc.)

Table 34 Results for Outcome Measures Reported in Comparison Studies of NPWT Devices^*^ Used to Treat Acute Wounds

Reference | Study Type | Treatments | N | Wounds Healed | Mean (SD) Change in Wound Area (cm^2^) or Volume (cm^3^) | Satisfactory Healing | Other Important Outcomes | Adverse Events Resulting in Discontinuation of Treatment
Stannard et al.(125) | RCT | Hematoma study: V.A.C.® | 13 | 13 | NR | Drainage (Mean) 1.6 (Range: 0–5) | Need for surgical evacuation: 1 (8%) | NR
Stannard et al.(125) | RCT | Control: | 31 | 31 | NR | 3.1 (Range: 0–11) | 5 (16%) | NR
Stannard et al.(125) | RCT | Fracture study: V.A.C.® | 20 | 20 | NR | Drainage (Mean): 1.8 (0–6) | No significant difference in rates of infection or wound dehiscence | NR
Stannard et al.(125) | RCT | Control | 24 | 24 | NR | 4.8 (0–24) | No significant difference in rates of infection or wound dehiscence | NR
Timmers et al.(106) | Non-RCT | V.A.C.® | 30 | 30 | NR | 7 (11.9%) of wounds failed to become sterile however due to the amount of new granulation tissue, surgical closure of the wound was undertaken. | Median duration of hospital stay (days)(Range) 36 (15–75) Recurrence of osteomyelitis: 3 (10%) Median duration of total hospital stay per patient (days)(Range) 36 (15–75) | NR
Timmers et al.(106) | Non-RCT | Control | 94 | | NR | NR | Median duration of hospital stay (days)(Range) 27.3 (3 –196) (p = 0.624) Recurrence of osteomyelitis: 55 (58.5%) (p < 0.0001) Median duration of total hospital stay per patient (days)(Range) 73 (6–419) (p < 0.0001) | NR
Simek et al.(123) | Non-RCT | V.A.C.® | 34 | NR | NR | 5.8% failure rate | Overall length of therapy:14.9 ±7.9d In-hospital mortality 5.8% 1-year mortality: 14.7% | NR
Simek et al.(123) | Non-RCT | Control | 28 | | NR | 39.2% failure rate | Overall length of therapy:14.3 ±11.9d In-hospital mortality 21.4 1-year mortality: 39.2%
Yang et al.(72) | V.A.C.® | 34 | Wounds healed (68 (100%)) Ratio of wound closure to skin-grafted wounds: 49:19 | NR | | Overall time to definitive wound closure by either delayed primary closure with sutures or STSG: 6.7 days(V.A.C.®) and 16.1 days (non- V.A.C.®) (p = 0.0001) | NR | NR
Yang et al.(72) | Control | 34 | Wounds healed (70 (100%)) Ratio of wound closure to skin-grafted wounds: 45:25 | | | Overall time to definitive wound closure by either delayed primary closure with sutures or STSG: 6.7 days(V.A.C.®) and 16.1 days (non- V.A.C.®) (p = 0.0001) | NR | NR
Fuchs et al.(23) | Non-RCT | V.A.C.® | 35 | 34 | NR | Primary or secondary wound healing achieved: 21d (IQR:15 to 26d) | Time from diagnosis of sternal infection until freedom from infection: Significantly shorter: 16d (IQR: 10 to 26d) 1-year mortality rate: 2.9% | Death due to vacuum-related perforation: 1
Fuchs et al.(23) | Non-RCT | Control | 33 | 29 | NR | 28d (IQR: 18 to 54d) | Time from diagnosis of sternal infection until freedom from infection: 26d (IQR: 19 to 51d) 1-year mortality rate: 25.3% | Deaths: 4 2 due to bleeding 2 due to septic shock
Immer et al.(130) | Non-RCT | V.A.C.® | 19 | NR | NR | NR | Survival: significantly better in Group 1 (V.A.C.® only) than Group 2 or Group 3 SF-36: Patients from groups 2 and 3 scored significantly lower in the aspects of physical function, general health and vitality than Group 1. | NR
Immer et al.(130) | Non-RCT | V.A.C.® plus excision plus flap | 19 | | NR
Immer et al.(130) | Non-RCT | Excision plus flap | 17 | | NR
Segers et al.(122) | Non-RCT | V.A.C.® | 29 | 21 (73%) | NR | Therapy duration (d): 22.8 (4–68) | Hospital stay SSI (mean): 46.1 (Range: 10–74) | Mortality caused by SSI: 4 (13.8%)
Segers et al.(122) | Non-RCT | Control | 34 | 14 (41%) | NR | Therapy duration(d): 16.5 (2–38) | 35.7 (Range: 10–165) | 7 (20.6%)
Sjogren et al.(139) | Non-RCT | V.A.C.® | 61 | 61 | NR | Treatment duration: 12 ±9d (Range: 2–66) Total length of stay (LOS): 25 ±17d (Range: 7–103) | 90-day mortality (significantly lower) 0 (p <0.01) Overall survival (significantly better) 97% at 6 mos. 93% at 1 year 83% at 5 years | NR
Sjogren et al.(139) | Non-RCT | Control | 40 | 40 | NR | Treatment duration: 10 ±14d (Range: 1–53) Total LOS: 25 ±20 (Range: 1–87) | 90-day mortality: 6 (15%) Overall survival: 84% at 6 mos. 82% at 1 year 59% at 5 years
Domkowski et al.(129) | Non-RCT | V.A.C.® | 96 | NR | NR | Omental transposition: 33 Pectoralis flap: 10 Secondary closure: 53 | NR | Multisystem organ failure: 2 Overwhelming Sepsis: 2
Domkowski et al.(129) | Non-RCT | Control | 6 | NR | NR | | NR
Song et al.(124) | Non-RCT | V.A.C.® | 17 | 15 (14 by definitive closure; 1 by secondary intention (V.A.C.®)) | NR | Average days between initial debridement and definitive closure of the sternal wound (not significant) 6 ±1.3d | NR | Mortality: 3 (2 from aspiration pneumonia and 1 from multisystem organ failure)
Song et al.(124) | Non-RCT | Control | 18 | 17 | NR | 8 ±2.9d | NR | Mortality: 1 patient died due to aspiration pneumonia
Doss et al.(128) | Non-RCT | V.A.C.® | 20 | NR | Reduction in wound size: 4.63 cm^2^/day (Range: 2.9–6.5) | NR | Duration of treatment: Mean: 17.2 ±5.8 Total hospital stay: Mean: 27.2 ±6.5d | Hospital mortality: 1 (5%)
Doss et al.(128) | Non-RCT | Control | 22 | | 3.2 cm^2^/day (Range: 2.7–3.6) | NR | Duration of treatment: Mean: 22.9 ±10.8 Total hospital stay: Mean: 33.0 ±11.0d | Hospital mortality: 1 (4.5%)
Catarino et al.(137) | Non-RCT | V.A.C.® | 7 | 7 | NR | 11d median (6–26d) | LOS: 27d median (22–49) Treatment failure: none (significantly greater for Control) | NR
Catarino et al.(137) | Non-RCT | Control | 10 | | NR | 13d median (8–20) | LOS: 50d median (27–98) Treatment failure: 5 | NR
Shilt et al.(138) | Non-RCT | V.A.C.® | 16 | 16 | NR | Free flap: 3 Split thickness: 8 Cross-foot flaps: 3 Full-thickness: 1 1 lost to f/u | LOS – 16.8 (5–47) Modified Loder grade Excellent:10; Good: 1; Fair: 1; Poor: 4 Outcomes Loder Satisfactory: 11; Unsatisfactory: 5 Vosburgh (a functional outcome questionnaire): 23.0 (19–24) # of procedures: 4.6 (2–10) | None
Shilt et al.(138) | Non-RCT | Standard of Care (SOC) | 15 | 15 | NR | Free flap: 8 Split thickness: 5 Cross-foot flaps: 1 Full-thickness: 1 | LOS – 10.2 (3–24) Modified Loder (a functional outcome classification) grade Excellent: 6; Good: 1; Fair: 0; Poor: 7 Outcomes Loder Satisfactory: 7; Unsatisfactory: 7 Vosburgh: 22.6 (21–24) # of procedures: 3.4 (1–7) | None
NR Kamolz et al.(343) | Non-RCT | V.A.C.® | 7 patients used as own controls | 14 | NR | Skin grafts – 2; No operation – 3; Keratinocytes – 2 | A massive reduction of edema formation (up to 50 ml) within the burn wound | NR
NR Kamolz et al.(343) | Non-RCT | Silver sulphadiazine crème | | | NR | Skin grafts – 4; No operation – 3 | | NR
Gabriel et al.(339) | Non-RCT | V.A.C.® | 15 | 100% | NR | Days to wound closure: 13.20 ±6.75 | Days to patient discharge: 14.67 ±9.18 | NR
Gabriel et al.(339) | Non-RCT | Control | 15 | 66.7% | NR | 29.60 ±6.54 | 39.20 ±12.07 | NR
Ozturk et al.(117) | Non-RCT | V.A.C.® | 5 | 5 | NR | 9d (Range: 7–15) | VAS 2.4 LOS: 14d; Range: 11–19 | NR
Ozturk et al.(117) | Non-RCT | Control | 5 | 5 | NR | 10d (8–16) | VAS 6.8 LOS: 13d;10–18 | NR
Rinker et al.(121) | Non-RCT | V.A.C.® | 17 (17 flaps) | 17 (100%) | NR | Time to bony union (Significantly less) 4.9 months | LOS, days 20.8 ±10.5 | NR
Rinker et al.(121) | Non-RCT | Control | 38 (43 flaps) | 36 (84%) | NR | 7.2 months | 20.2 ±8.5 | NR
Huang et al.(127) | Non-RCT | V.A.C.® | 12 | NR | Reduction: 47% in dimension and 49% in volume | NR | Hospital stay: 32.1d (mean) | Deaths: 1 (8%) Amputation: 2
Huang et al.(127) | Non-RCT | Control | 12 | | Reduction: 41% in dimension and 39% in volume | NR | 34.3d (mean) | Deaths: 1 (8%) Amputation: 2
Labler et al.(71) | Non-RCT | VAC® | 12 | 11 | NR | 11 of 13 healed uneventfully | Rate of infection: 2 of 13 | Early amputation: 1
Labler et al.(71) | Non-RCT | Control | 11 | 5 | NR | 5 of 10 healed uneventfully | Rate of infection: 6 of 11 | Early amputation: 1

LOS Length of hospital stay

NR Not reported

RCT Randomized controlled trial

SSI Surgical site infection

* All studies reported using V.A.C.® (KCI, USA Inc.)

## Key Question 3

Table 35 Characteristics of Patients with Acute Wounds

Reference | Patient Population (n) | Age (yrs) | Sex | Comorbidities | Wound Type | Number of Wounds | Wound Area (cm^2^) or Volume (cm^3^) | Severity of Wounds
Bannasch et al. 2008(344) | 5 | Mean 37.8 Range: 8–58 | 4 M 1 F | 1: DM | Pretibial bone exposure, exposure of calcaneus and Achilles tendon, exposure of all extensor tendons of the foot, exposed tibias and hardware (secondary to plate osteosynthesis), posterior aspect of lower leg | 5 | NR | NR
Bendewald et al. 2007(82) | 5 | Median: 21 Range: 16–63 | 3 M 2 F | NR | Complex pilonnidal disease underwent wide excision | 5 | Mean: 205 cm^3^ Range: 90 cm^3^–410 cm^3^ | NR
Bendo et al. 2007(76) | 13 | Mean: 58 Range: 34–83 | 5 M 8 F | 6: diabetes 1: atrial fibrillation 1: HIV | Posterior lumbar wound drainage management of the spine prior to debridement | 13 | NR | NR
Brandi et al. 2008(345) | 18 | Avg: 56 Range: 45–78 | NR | 12: Peripheral vascular disease (PVD) and 4 of these with type 2 DM | Traumatic loss of tissue in the lower limbs involving exposure of bone and tendon structures | 18 | NR | NR
Dhir et al. 2008(346) | 19 | Mean: 63.2 Range: 48–75 | 17 M 2 F | 16: hypertension 4: IDDM 9: malnutrition 7: CAD 7: PVD 4: NIDDM | Complex head and neck wounds | 33 | Larger cutaneous defects >10 cm^2^ | Neck and facial abscesses
Rhode et al. 2008(347) | 5 | Mean: 41.2 Range: 33–59 | 5 F | BMI Range: 24.4–36.1 2: smokers | Patients had radical excisional therapy for stage III vulvar hidradenitis suppurativa | 5 | NR | NR
Rozen et al. 2008(348) | 9 | Mean: 69 Range: 32–99 | 9 F | 5: hypertension 1: asthma 5: smoking history 1: ESRF on dialysis 1: type II DM 2: COPD 2: AS 1: AF 3: stroke 2: IHD 3: hypercholesterolaemia 1: hyperparathyroidism 1: CCF 1: granulomatous hepatitis 1: anemia | Lower limb split skin grafts | 9 | NR | NR
Steiert et al. 2008(349) | 42 | Mean: 46 Range: 15–84 | 29 M 13 F | NR | Open extremity fractures | 33 lower extremity 10 upper extremity | NR | Severe extremity trauma
Svensson et al. 2008(149) | 28 | Median: 75 Range: 48–88 | Of the 33 wounds, 21 M 12 F | 10: ≥80 yrs 12: women 14: DM 23: lower limb ischemia | Perivascular surgical site infections in groin | 33 | NR | Infected groins
Bhattacharyya et al. 2007(350) | 38 | Infected Mean: 39 ±8.8 Non-infected Mean: 39 ±10.5 | 32 M 6 F | 7: smokers 1: DM | Gustilo grade III B open fractures | 38 | 10 cm or larger | 11 wounds infected; 27 non-infected
Bollero et al. 2007(141) | 35 | Avg: 40, Range: 14–72 | 29 M 6 F | NR | Acute complex traumas of lower limbs | 13 foot 5 ankle 15 leg 1 knee 3 thigh | NR | NR
Dedmond et al. 2007(27) | 49 | Avg: 36.8, Range: 18–70 | 40 M 10 F | NR | Grade/type III open tibial shaft fractures | 24 IIIA 24 IIIB 2 IIIC | NR | NR
Helgeson et al. 2007(351) | NR | NR | NR | NR | Exposed tendon and/or bone Combat-related wounds | 16 wounds treated 18 times: 6 leg 1 shoulder 6 foot 2 forearm 2 thigh 1 hip | Avg: 87 cm^2^ Range: 15–275 cm^2^ Median: 47 cm^2^ | NR
Labler and Trentz 2007(352) | 13 | Range: 13–71 | 10 M 3 F | NR | Severe soft tissue injuries as a result of high energy pelvic trauma | 13 | NR | NR
Machen 2007(74) | Over 50 patients | NR | NR | NR | Traumatic war wounds | Over 50 wounds | NR | NR
Peck et al. 2007(353) | 192 | Range: 4–68 | NR | NR | Major vascular injuries | 134 extremity 33 neck and vessel 25 torso | NR | NR
Rao et al. 2007(163) | 29 | Median: 60, Range: 31–80 | 14 M 15 F | NR | Open abdominal wounds | 29 | NR | NR
Segers et al. 2007(354) | 5 | NR | NR | NR | Open window thoracostomy | 5 | NR | NR
Senchenkov et al. 2007(355) | 17 | Mean: 65 Range: 42–82 | 9 M 8 F | 17: soft tissue sarcoma 2: DM 1: smoker | Irradiated extremity wounds reconstructed w/split thickness skin grafts | 17 | Skin graft size: Mean: 118 cm^2^ Range: 23–240 cm^2^ | NR
Andrews et al. 2006(88) | 12 | Avgerage: 61.8 Range: 34–86 | 8 M 4 F | 66.6%: Cardiac disease 66.6%: Cancer 58.3%: Pulmonary disease 58.3%: Hypertension 16.6%: Diabetes 8.3%: Liver and kidney disease | Complicated head and neck wounds | 13 | All in cm: 8×6 10×5 7×6 9×6 5×4 9×6 16×8 8×9 21×14 14×8 10×9 10×7 | 9: Bone exposure
Cothren et al. 2006(356) | 14 | Men: Mean: 41 ±5.7 | 79% M, 21% F | NR | Open abdomen | 14 | NR | NR
DeFranzo et al. 2006(156) | 100 | Range: infancy to 78 | 48 M 52 F | NR | Partial thickness and complete full-thickness abdominal wounds | 63 partial thickness 37 complete full-thickness | Avg: 200 cm^2^ Range: 30 cm^2^ – 700 cm^2^ | 45 of partial: contaminated/infected 19 of full: contaminated/infected
Heller et al. 2006(87) | 21 | Mean: 48 Range: 5–75 | 11 M 10 F | 10: Morbid obesity 11: Diabetes 4: Steroid use 6: Smoking 8: Hypertension 4: Preoperative chemotherapy | Abdominal wound dehiscence | 21 | NR | NR
Leininger et al. 2006(111) | 77 | NR | NR | NR | High-energy soft tissue wounds (trauma, deployed wartime environment) | 39 lower extremity 12 back 7 chest 20 upper extremity 6 abdomen 4 buttock/perineum | Only reported size of 33 wounds: Mean: 45.3 cm^2^ SD: 30.6 cm^2^ Median: 32 cm^2^ Range: 12–160 cm^2^ | NR
Labler et al. 2005(357) | 18 | Range: 13–69 | 16 M 2 F | NR | Open abdomen after laparotomy | 18 | NR | NR
Rosenthal et al. 2005(89) | 23 | Average: 59 | 17 M 6 F | 4: Diabetes requiring insulin therapy during wound management | Head and neck reconstruction | 23 | NR | NR
Stoeckel et al. 2005(358) | 18 | Mean: 52 | 18 F | 2: smokers 4: previous radiation therapy to affected breast | Complex breast wounds | 15 | NR | NR
Savolainen et al. 2004(359) | 36 | Median: 72, Range: 46–98 | 21 M 15 F | NR | Inguinal wound in vascular surgery | 36 | NR | 13 frank infection 11 non-infected 12 clinically contaminated
Stone et al. 2004(90) | 48 | NR | NR | NR | Abdominal trauma | 48 | NR | NR
Herscovici et al. 2003(360) | 21 | Avg: 45.9, Range: 16–83 | 12 M 9 F | NR | High energy soft tissue injuries | 6 tibial 10 ankle 1 forearm 1 elbow 1 femur 1 pelvis 1 below knee stump | Tibial: 73 cm^2^, Range: 5–261 ankle & foot: 38 cm^2^, Range: 8–52 forearm: 65 cm^2^ elbow: 60 cm^2^ femur: 156 cm^2^ pelvis: 264 cm^2^ below knee stump: 400 cm^2^ | NR
Stonerock et al. 2003(77) | 15 | NR | 12 M 3 F | NR | Abdominal wounds | 15 | NR | Abdominal compartment syndrome, inability for abdominal closure at initial operation, or inability to close the abdomen upon re-exploration
Suliburk et al. 2003(166) | 29 | Men: Mean: 38 ±3 | 20 M 9 F | NR | Open abdomen after severe trauma | 29 | NR | NR
Garner et al. 2001(86) | 14 | Mean: 40.1 ± 4.7 | 4 M 10 F | NR | Open abdomens | 14 | NR | NR
DeFranzo et al. 2000(157) | 75 | NR | NR | NR | Lower extremity wounds w/ exposed bone | 29 motor vehicle accidents 9 gunshot 11 other assorted trauma 13 dehisced or infected orthopedic surgical wounds 3 pressure sores 5 failed flaps 5 miscellaneous | NR | NR
Avery et al. 2000(92) | 15 | NR | NR | NR | Radial forearm donor site with split skin graft | 15 | Mean: 36 cm^2^ | NR

Table 35a Characteristics of Patients with Chronic Wounds

Reference | Patient Population (n) | Age (yrs) | Sex | Comorbidities | Wound Type | Number of Wounds | Wound Area (cm^2^) or Volume (cm^3^) | Severity of Wounds
Bapat et al. 2008(153) | Group A: 23 superficial sternal infection received V.A.C.® as definitive treatment | Group A: 69 ±13 | Group A: 20 M, 3 F | Group A: BMI 30.9 ±3.7 9 DM | Superficial sternal infections and deep sternal infections | 28 superficial 21 deep | NR | NR
Bapat et al. 2008(153) | Group B: 5 superficial sternal infection received V.A.C.® followed by surgical closure | Group B: 69 ±12.1 | Group B: 4 M, 1 F | Group B: BMI 30.3 ±2.9 1 DM
Bapat et al. 2008(153) | Group C: 12 deep sternal infection received V.A.C.® as definitive treatment | Group C: 69 ±11.4 | Group C: 11 M, 1 F | Group C: BMI 31.8 ±4.6 3 DM
Bapat et al. 2008(153) | Group D: 9 deep sternal infection received V.A.C.® and surgery | Group D: 67 ±12 | Group D: 8 M, 1 F | Group D: BMI: 30.7 ±5.1 4 DM
Baharestani et al. 2008(93) | 11 | Avg: 54 Median: 57 Range: 18–82 | 7 M, 4 F | 7 DM 1 Malnourished 3 periperal vascular disease 2 Obesity | Necrotizing Fascitis | 16 | NR | NR
Chen et al. 2008(160) | 26 | Mean: 69, Range: 49–82 | 21 M 5 F | | Deep sternal wound infections | 26 | NR | NR
Ennker et al. 2008(361) | 45 | Avg: 68 | 29 M 16 F | 16: IDDM 35: hyperlipidemia 40: hypertension 19: COPD 7: Peripheral arterial disease 9: Carotid artery stenosis | Deep sternal wound infections | 45 | 2 cm × 2 cm to 2 cm × 18 cm | NR
Fleck et al. 2008(362) | 22 | Mean: 61.5 ±15, Range: 8–79 | 15 M 7 F | NR | Open chest | 22 | NR | NR
Gdalevitch et al. 2008(154) | 36 | Median: 67.1, Range: 49–88 | 22 M 14 F | 66.7% hyperlipidemia 64% smoking 58.3% DM 55.6% hypoalbuminemia 38.9% positive blood culture 25% CLD 22% high degree bony exposure and sternal instability 11.1% CKD 8.3% PVD 5.6% immunocompromised | Superficial and deep sternal wounds | 36 | Depth: 19.4% ≥4 cm 80.6% ≤4 cm | NR
Ha et al. 2008(140) | 74 | Median: 65.5, Range: 19–95 | 40 M 34 F | 60.8% DM 86.7% of DM had PVD, Stroke, retinopathy, dialysis | Surgical wounds | 25 foot 13 toe 13 groin 9 leg 9 thigh 7 trunk 1 neck | Median: 18.7 cm^2^ Range: Length 0.5–20 cm, Width 0.5–15 cm | 29 surgical incision breakdown 42 infected secondary to causes other than surgery 6 infected that dehisced after initial closure
Hamed et al. 2008(363) | 10 | Mean: 65 ±16 | 5 M 5 F | 6: DM 7: hypertension | Lymphatic fistulae (LFs) and lymphoceles: 9 patients groin lymphatic complications 1 patient neck lymphatic complication | 10 | NR | NR
Horch et al. 2008(155) | 21 | Mean: 69.8, Range: 46–80 | 12 M 9 F | 17: PAOD with or without concomitant renal insufficiency 2: autoimmune disease with immuno suppressive medication 10: diabetes 2: acute pancreatitis | Severe lower limb soft tissue loss and infection with exposed bone, infected ulcers of lower leg with exposed bones and joints | 21 | NR | All patients presented with necrotic tendons and or affected and exposed tibia or fistula bones
Labanaris et al. 2008(364) | 80 | Men: Mean: 63, Range: 53–84 Women: Mean: 66, Range: 50–82 | 64 M 16 F | NR | Chronic wounds | 26 pressure ulcers 17 wound trauma 24 diabetic ulcer 13 venous stasis ulcer | NR | NR
Lopez et al. 2008(365) | 8 with 10 V.A.C.® applications | Age at V.A.C.® application: 84.5 ±51 days | 6 M 2 F | NR | Complex abdominal wounds | 8 | Mean: 13.6 ±6 cm^2^ Range: 8.5–25 cm^2^ | Wound infection and dehiscence
Mokhtari et al. 2008(366) | 38 | Mean: 69 ±SD 10.6 | 29 M 9 F | 15: DM 10: BMI >30 9: COPD 16: recent MI 3: Renal Failure | Deep sternal wound infection | 38 | NR | NR
Ploumis et al. 2008(80) | 73 | Average: 58.4 Range: 21–82 | 34 M 39 F | Chronic leukocytic leukemia, lupus anticoagulant, chronic renal failure, alcohol abuse, metastatic colon cancer, obesity, malnutrition, diabetes, splenectomy, hodgkin disease, radiation exposure, rheumatoid arthritis, and smoking | Spinal wound infections | 79 | NR | NR
Wondberg et al. 2008(161) | 30 | Avg: 63, Range: 27–86 | 21 M | NR | Open abdomen caused by abdominal sepsis; origin of sepsis: 21 colon 3 stomach 5 stomach or bowel 1 unclear | 30 | NR | NR
Horn et al. 2007(78) | 11 | Range: 7–19 | 6 M 5 F | 2: Myelomeningocele 2: Cerebral Palsy 1: Scoliosis after paraplegia from chemotherapy for acute myelogenous leukemia 1:Fusion for kyphotic deformity secondary to collapse of veterbral bodies from an aneurysmal bone cyst 4: Moderate to severe developmental delay | Infected spinal wounds | 11 | NR | Range of time of onset of infection: 2 weeks-5 years
Jones et al. 2007(150) | 13 | Mean: 50.2, Range: 14–76 | NS | Malignant disease, anemia | Deep infections of the spine | 13 | NR | 6 Staph 1 complicated Candida 4 mixed bacterial infections 2 Pseudomonas aeruginosa infections 1 Serratia marcescens infection
Kotsis and Lioupis 2007(73) | 8 | Range: 24–74 | NR | 4: Hypertension 4: Morbid obesity 3: Diabetes mellitus II 2: Renal failure 1: Hepatitis C 1: Malignancy 1: Pulmonary insufficiency | Vascular graft infection confined to the groin | 8 | NR | NR
McCord et al. 2007(142) | 68 | Mean: 8.5 yrs Range: 7 days-18 yrs | 36 M 32 F | NR | Pressure ulcers, extremity wounds, dehisced surgical wounds, open sternal wounds, wounds w/fistulae, complex abdominal wall defects | 13 pressure ulcers 18 extremity wounds 19 dehisced surgical wounds 10 open sternal wounds 3 wounds w/fistulae 6 complex abdominal wall defects | NR | NR
Perez et al. 2007(95) | 37 | Avg: 58 Range: 34–86 | 18 M 19 F | 1: Gallbladder cancer 2: Pancreatic cancer 5: Stomach cancer 2: Colon Cancer 10: Diverticulitis 10: Bowel obstruction 3: Pancreatitis 2: Ulcer | 21: Severe abdominal sepsis 16: Abdominal compartment syndrome | 37 | NR | NR
Shrestha et al. 2007(367) | 9 | Range: 30–67 | 5 M 4 F | NR | Deep wound infection after renal transplantation | 9 | NR | Dehiscence, associated with copious discharge
Strecker et al. 2007(318) | 63 patients, 34 treated with V.A.C.® | 63 patients: Avg: 68.5, Range: 29–83 | 63: 61.9% M, 38.1% F | 63: 49.2% DM 90.5% arterial hypertension 19% COPD 27% smokers 23.8% Renal Failure | Deep sternal wound infections | 34 | NR | NR
van Rhee et al. 2007(368) | 6 | Avg: 12.6 | 3 M 3 F | NR | Deep wound infection after instrumented spinal fusion in pediatric neuromuscular scoliosis | 6 | NR | Wound dehiscence
Gorlitzer et al. 2006(369) | 5 | Avg: 69, Range: 24–72 | 3 M 2 F | 1: DM 1: colon cancer, CRF, COPD, heart failure | Descending necrotizing mediastinitis | 5 | NR | NR
Labler et al. 2006(370) | 15 | Mean: 48, Range: 18–75 | 4 M 11 F | 2: Nicotine 3: alcohol 2: tumor 2: radiation before surgery 2: arterial hypertension 3: DM 3: CRF 2: Chronic Heart Disease (CHD) 1: COPD BMI’s (kg/m^2^) 36, 39, 28, 34, 32, 59 | Deep subfascial infection after dorsal spinal surgery | 15 | NR | NR
Morgan et al. 2006(164) | 9 | Range: 56–85 | 7 M 2 F | 7: DM 3: hypertension 2: MI 2: Renal disease 1: smoker 1: kidney transplant 3: Coronary artery disease (CAD) 2: Congestive heart failure (CHD) 1: CRF 1: Peripheral arterial disease (PAD) | Chronic lower extremity wounds | 12 | All cm: 3×3 3×4 3×3 3×4 3×3 3×3 3×3 3×3 3×5 | Non-healing ulcerations
Pelham et al. 2006(371) | 10 | Mean: 52, Range: 13–76 | 4 M 6 F | DM, obesity, hypertension and a history of smoking (number of patients not specified) | Chronic infected wounds with exposed orthopedic implants: 6 chronic wounds (present for more than 6 weeks) 4 subacute wounds (present for 1–4 weeks) All wounds classified as complex, defined as having exposed bone, exposed tendon, or exposed orthopedic implants and/or open joint space with stripped bone | 10 | 8 patients had a wound exceeding 20 cm^2^ | Skin breakdown distal tibia; large anterior skin slough with exposed hardware; long-standing draining sinus with partially exposed lateral plate; long-standing exposed total knee arthroplasty hardware with large anterior skin and soft-tissue slough; long-standing exposed hardware; Infected total knee arthroplasty with skin breakdown; infected open reduction internal fixation; open wound exposed hardware, infected open reduction internal fixation, infected open reduction internal fixation
Sartipy et al. 2006(151) | 5 | Range: 58–79 | 2 M 3 F | 1: DM 2: COPD, obesity | Deep sternal wound infection | 5 | NR | NR
Agarwal et al. 2005(372) | 103 | Avg: 52, Range: 3–91 | 67 M 36 F | Pulmonary: 2 congenital 16 COPD Cardiovascular: 17 congenital 6 endocarditis/pericarditis 5 myopathy 65 CAD 14 CHF Renal: 6 insufficiency/failure 11 End-stage renal disease (ESRD) Autoimmune: 11 transplant 5 connective tissue 42 hypertension 37 DM | Sternal wounds | 103 | NR | 16 superficial infections 21 sterile 66 mediastinitis
Cowan et al. 2005(373) | 22 | Mean: 67.9 ±10.9 | 68.2% M | BMI 30.9 ±7.8 40.9% smokers 54.6% DM 36.4% RF 31.8% CHF 58.1% hypertension 18.2% COPD | Deep sternal wounds with or without bony involvement | 22 | NR | 82% dehiscence 59% sternal instability 73% fluid collection by computed tomography 41% osteomyelitis 50% staphylococcus aureus
Lee et al. 2005(374) | 9 | Range: 47–73 | NR | NR | Refractory sternal infection: 2 patients type IVA mediastinitis after one failed therapeutic trial 7 patients type IVB mediastinitis after more than one failed therapeutic trial | 9 | NR | NR
Mendonca et al. 2005(375) | 15 | Avg: 49.3, 22–80 | 9 M 6 F | 10: DM 2: chronic osteomyelitis 2: Peripheral vascular disease (PVD) 1: spina bifida 11: peripheral neuropathy, RF, and wound dehiscence | Chronic, non-healing wounds on foot and ankle | 18 | Avg: 7.41 cm^2^, Range: 2–10 cm^2^ | 11 clinical evidence of active infection 5 stage II wounds 10 stage III wounds (stages are based on Wagner-Meggitt classification)
Sjogren et al. 2005(179) | 46 | Mean: 68.5 ±SD 10.3 | 32 M 14 F | 11: DM 22: BMI >30 2: preoperative dialysis 23: recent MI 8: COPD 14: HF 6: RF | Post sternotomy mediastinitis | 46 | NR | NR
Mehbod et al. 2004(376) | 20 | Avg: 55, Range: 31–81 | 12 M 8 F | 3: DM 3: previous splenectomy 10: smokers 1: lupus 1: Hodgkin lymphoma 1: HIV | Deep spine infections w/exposed instrumentation | 20 | NR | 16 draining wound 4 presented back pain & temperature
O’Conner et al. 2004(377) | 17 | Avg: 43.5, Range: 24–76 | 11 M 6 F | Group I: 1 DM and ESRD and steroids 1 chronic lymphocytic leukemia and prostate cancer 2 HIV positive | Chest wounds | Group I: 7 primary chest wall process | Avg 16×7 cm, Range: 7×3 cm to 21×11 cm | Group I: 4 necrotizing soft-tissue infections 3 penetrating trauma resulting in large contaminated wounds w/significant loss of chest wall integrity
O’Conner et al. 2004(377) | 17 | Avg: 43.5, Range: 24–76 | 11 M 6 F | Group II: 1 multiple sclerosis and PVD and steroids 1 closed head injury 1 DM and morbid obesity 1 cerebral abscess 1 DM and COPD and CAD 1 cerebral vascular accident 1 cardiomyopathy | Chest wounds | Group II: 10 with empyema with extension to chest wall | Avg 16×7 cm, Range: 7×3 cm to 21×11 cm | Group II: 2 with empyema necessitates 6 with postpneumonic empyema 4 with postoperative empyema
Routledge et al. 2004(378) | 6 | Range: 22–65 | 3 M 3 F | NR | Deep wound infections after heart and lung transplantation | 6 | NR | NR
Scholl et al. 2004(81) | 13 | Mean: 61 Range: 43–73 | 11 M 2 F | 4: History of diabetes mellitus 5: History of CABG | Postoperative deep sternal wounds | 13 | NR | 7: Acute purulent sternal infections 6: chronic sternal osteomyelitis
Demaria et al. 2003(145) | 7 | Mean: 74, 71–80 | 6 M 1 F | 4: DM All: cardiopulmonary bypass | Non-healing infected sternal surgical wound | 7 | NR | Wound dehiscence w/local inflammation followed by cloudy discharge some had low grade fever
Gustafsson et al. 2003(146) | 40 | Median: 68, Range: 49–87 | 26 M 14 F | NR | Deep sternal wound infections | 40 | NR | NR
Isago et al. 2003(91) | 10 | Mean: 61.2 ± 4.5 Range: 43–88 | 7 M 3 F | All paralyzed or bedridden | Pressure ulcers | 10 | Mean area: 62.6 cm^2^ Mean depth: 1.9 cm | Stage IV - penetration into the deep fascia with involvement of muscle and bone
Wongworawat et al. 2003(75) | 14 | Average: 48 Range: 21–66 | NR | NR | Orthopedic infections | 14 | Average: 70 cm^2^ Range: 22.5–288 cm^2^ | NR
Armstrong et al. 2002(85) | 31 | Mean: 56.1 ± 11.7 | 24 M 7 F | Diabetes | Diabetic foot ulcers | 31 | Surface area: 27.9 ± 19.5 cm^2^ | 3.2%: Grade 1 lesions 45.2%: Grade 2 lesions 51.6%: Grade 3 lesions (Grades based on University of Texas’ diabetic foot classification system)
Clare et al. 2002(379) | 17 | Avg: 64.4 | 8 M 9 F | 13: DM 9: IDDM 10: peripheral neuropathy 8: severe PVD | Non-healing wounds of lower extremity | 5 midfoot/forefoot 6 ankle/hindfoot 6 lower limb | NR | 6 postoperative dehiscence of surgical incision
Fleck et al. 2002(380) | 11 | Median: 64.4, Range: 50–78 | 5 M 6 F | NR | Sternal wound infection | 11 | NR | NR
Gustafsson et al. 2001(381) | 16 | Male: Median: 68, Range: 49–82 Female: Median: 67, Range: 63–73 | 13 M 3 F | NR | Deep sternal wound infections | 16 | NR | NR
Hersh et al. 2001(94) | 16 | Range: 45 – 79 | 6 M 10 F | NR | Deep sterna wounds | 16 | NR | NR
De Lange et al. 2000(167) | Group 1: 23 | Group 1: Mean: 46, Range 17–77 | NR | NR | Group 1: stage IV pressure sores | Group 1: 26 | NR | NR
De Lange et al. 2000(167) | Group 2: 42 | Group 2: Mean: 62, Range: 20–89 | NR | NR | Group 2: major postoperative wound infection in abdomen, groin, knee, ankle | Group 2: 42 | NR | NR
De Lange et al. 2000(167) | Group 3: 19 | Group 3: Mean 67, Range: 46–85 | NR | NR | Group 3: chest wall dehiscence after cardiac surgery complicated by mediastinitis | Group 3: 19 | NR | NR
De Lange et al. 2000(167) | Group 4: 13 | Group 4: Mean: 44, Range: 21–80 | NR | NR | Group 4: subacute wounds | Group 4: 13 | NR | NR
De Lange et al. 2000(167) | Group 5: 3 | Group 5: Mean: 67, Range: 59–73 | NR | NR | Group 5: soft tissue defect after radiation therapy, soft tissue defect after subcutaneous leakage chemo, diabetes ulcer on ankle | Group 5: 3 | NR | NR
Deva et al. 2000(382) | 30 | Mean: 50.7, Range: 15.4–88.3 | 20 M 10 F | NR | Wounds unsuitable for surgical closure (pressure sores) | 8 sacral 7 ischial 8 trochanter/hip 7 lower limb | Mean width: 5.7 cm, Range: 1.7–22 cm Mean length: 9.9 cm, Range: 1.9–27 cm Mean depth: 3 cm, Range: 0.5–9 cm Mean volume: 171 cm^3^, Range: 16.1–2,228 cm^3^ | Grade III pressure sores (full thickness ulceration down to but not through deep fascia) Mean pretreatment duration: 418 days, Range: 8–1,650 days
Lang et al. 1999(159) | 82 | NR | 68 M 14 F | NR | Soft tissue lesions of the ankle and foot | 82 | NR | NR

Table 35b Characteristics of Patients with Mixed Wound Types

Reference | Patient Population (n) | Age (yrs) | Sex | Comorbidities | Wound Type | Number of Wounds | Wound Area (cm^2^) or Volume (cm^3^) | Severity of Wounds
Smith & Nephew Wound Management Unpublished Data(96) | 132 | Mean: 57, Range :20 – 92 | 73 M, 58F | NR | 55: Surgical 14: Traumatic 29: Pressure ulcer 11: Diabetic foot ulcer 3: Leg ulcer 19: Graft site 1: Other | 132 | Median area: 25.6 cm^2^ Range: 1 cm^2^–1099.6 cm^2^ Median depth: 1.5 cm Range: 0 cm – 18 cm | 21 clinically infection
Campbell et al. 2008(84) | 30 | Mean: 72.3, Range: 32 – 96 | 9 M, 21 F | 73%: Diabetes 40%: Venous disease 20%: Cancer 23%: RD | 11: Chronic 11: Surgical dehiscence 8: Surgical incision | 30 | Medan volume: 43.9 cm^3^ Area: 20.2 cm^2^ Depth: 1.9 cm^2^ | NR
Gabriel et al. 2008(383) | 58 | Median: 10 yrs, Range: 10 days–16 yrs | 28 M 30 F | NR | Acute and chronic | 18 trauma 17 abnormal 15 surgical soft tissue deficit 5 stage III/IV pressure ulcer 3 fasciotomy | Abdominal 120 cm^3^ Trauma 112 cm^3^ Pressure ulcer 60 cm^3^ Soft tissue 150 cm^3^ Fasciotomy 60 cm^3^ | NR
Baharestani et al. 2007(162) | 24 | Median: 11 yrs, Range: 14 days – 18 yrs | 10 M, 14 F | NR | Leg, lumbar/sacral, abdomen, and chest wounds | 9 leg 7 lumbar/sacral 4 abdomen 4 chest | 6 traumatic: median baseline area 22.4 cm^2^ 4 wounds treated were secondary to abdominal dehiscence: Median baseline area: 16.4 cm^2^ | 12 infected wounds
Ferron et al. 2007(83) | 11 | Mean: 70.5 Range: 50–81 | 11 F | NR | 10: Severe chest wall radionecrosis after breast cancer treatment 1: Locally advanced breast cancer | 11 | Mean: 360 cm^2^ Range: 80–750 cm^2^ | NR
Mendonca et al. 2007(143) | 26 | Mean: 54, Range: 16–91 | 19 M 6 F | 7: DM | Mechanical trauma, debridement of necrotic tissue, chronic | 13 chronic 7 debridement of necrotic tissue 6 mechanical trauma | Mean: 55.23 ±55.24 cm^2^ | NR
Wada et al. 2006(384) | 29 | Mean: 59.8, Range: 29–78 | 18 M 11 F | 13: DM 11: hypertension 10: CD 3: saphenectomy 2: vasculitis | Complex wounds | 19 lower extremities 7 sacral ulcers 1 abdomen 1 breast 1 trunk | NR | NR
Adamkova et al. 2005(152) | 6 | Range: 54–91 | NR | CD hypertension, anemia | Subacute and chronic wounds | 2 varicose ulcer lower extremity 2 loss of skin after an inflammation secondary to infection 1 high risk patient for deep burns 1 deep defect caused by inappropriate medical care | NR | NR
Butter et al. 2005(144) | 16 | Avg: 12.1 yrs, Range: 1 month – 18 yrs | 7 M 9 F | NR | 8 tissue loss after pilonidal sinus excision 3 wound dehiscence of the abdomen 2 sternum 1 back 1 leg 1 after chronic perineal fistula post-abdominoperineal resection | 16 | NR | NR
Caniano et al. 2005(165) | 51 | Group 1: Avg: 16, Range: 10–20 Group 2, 3, 4: NR | NR | Group 1: 67% obese Group 2, 3, 4: NR | Group 1: pilonidal disease Group 2: sacral and extremity ulcers Group 3: traumatic soft tissue wounds Group 4: extensive tissue loss | Group 1: 21 Group 2: 9 Group 3: 9 Group 4: 12 | NR | NR
Antony and Terrazas 2004(385) | 42 | Sternal: 72 Lower extremity: 62 Spinal: 59 | Sternal: 8 M, 4 F Spinal: 5 M, 11 F Lower extremity: NR | Sternal: all DM and CAD Lower extremity: 8 DM, CAD, and PVD Spine: 8 DM, Rheumatoid arthritis (RA), and spinal stenosis | Non-healing sternal, spinal, and lower extremity wounds | 12 sternal with variety of infections 14 lower extremity w/variety of infections 16 spinal | NR | NR
Bihariesingh et al. 2004(386) | 6 | Mean: 60.2, Range: 33–76 | 3 M 3 F | NR | Complex soft-tissue defects following various orthopedic procedures | 6 | NR | NR
Loree et al. 2004(387) | 14 | Median: 73, Range: 54–90 | 6 M, 8 F | NR | Chronic leg ulcers: 9 malleolar 3 foot 2 leg 1 tendon calcaneus | 15 | NR | Ulcer duration: 5 less than 6 months 6 between 6–24 months 4 between 24–360 months
Weed et al. 2004(37) | 25 | NR | NR | DM | [underlined: Acute]: lower extremity, trauma, sternal wound, and elbow trauma [underlined: Chronic]: pressure ulcers and diabetic ulcers | 26 V.A.C.® applications | NR | Serial quantitative cultures
Molnar et al. 2003(388) | 8 | Mean: 40, Range: 2–60 | NR | 6: smokers 1: ovarian cancer, pulmonary embolus, chemo 1: DM and bladder cancer 1: CAD 1: hypertension | Complex wounds | 5 trauma 2 wound dehiscence 1 tumor excision | Mean: 250 cm^2^ | Bone exposed in 62.5% joint exposed in 50% tendon exposed in 37.5% bowel exposed in 25%
Schimp et al. 2003(147) | 27 | Median: 51, Range: 21–77 | 27 F | BMI Median: 36 kg/m^2^, Range: 14–62 6: smokers 8: history of radiation therapy 17: ≥2 abdominal surgeries 9: ≥2 comorbidities | Complex wound failures in gynecologic oncology patients | 27 | Median: 330 cm^3^ Range: 2–4,400 cm^3^ | NR
Mooney et al. 2000(79) | 27 | Range: 3 days – 18 years | 14 M 13 F | NR | Acute extremity wounds, chronic extremity wounds, chronic axial wounds | 27 | NR | Acute extremity: wounds associated with open fractures considered too extensive for acute or delyaed closure Chronic extremity: failed flap coverage, failed primary closure, extensive soft tissue and bony defects Chronic axial: abdominal or sternal dehiscence, myelodysplasia with compromised skin and soft tissue was treated for deep spinal wound infection
Wu et al. 2000(158) | 26 | NR | 17 M 9 F | NR | Chronic, acute, and subacute | 8 acute 7 subacute 11 chronic | NR | NR
Argenta and Morykwas 1997(148) | 300 | NR | NR | NR | Chronic wounds, subacute, and acute | 175 chronic 94 subacute 31 acute | Venous stasis or other vasculitic ulcers: Range: 6–120 cm^3^ | [underlined: Subacute]: 36 dehisced 37 open w/exposed orthopedic hardware or bone, and other misc. wounds [underlined: Acute]: large soft tissue avulsions, contaminated wounds, hematomas, abscesses that were evacuated, gunshot wounds, eviscerations, extensive edema and contamination of exposed tissue
Mullner et al. 1997(389) | Group A: 17 | Group A: Mean: 82, Range: 71–88 | Group A: 5 M, 12 F | NR | Group A: infected sacral pressure ulcers | Group A: 17 | Group A: Mean: 43 cm^3^, Range: 12–72 | Group A: 66% of patients the sacrum was exposed, more than 50% of wounds had active secretions
Mullner et al. 1997(389) | Group B: 12 | Group B: Mean: 35, Range: 24–58 | Group B: 5 M, 7 F | | Group B: acute soft tissue defects | Group B: 12 | Group B: Mean: 20 cm^3^, Range: 6–80 | Group B: 5 patients skin defect secondary to excision of necrotic skin overlying subcutaneous haematoma; 5 patients had deep infection and 30% of these had active secretions
Mullner et al. 1997(389) | Group C: 16 | Group C: Mean: 55, Range: 27–81 | Group C: 10 M, 6 F | | Group C: infected soft tissue defect involving exposed bone and/or implants | Group C: 16 | Group C: Avg: 12 cm^3^, Range: 8–18

AF – Atrial Fibrillation

AS – Aortic Stenosis

CAD – Coronary Artery Disease

CAS – Carotid Artery Stenosis

CCF – Congestive Cardiac Failure

CD – Coronary Disease

CHD – Coronary Heart Disease

CHF – Congestive Heart Failure

CKD – Chronic Kidney Disease

CLD – Chronic Lung Disease

COPD – Chronic Obstructive Pulmonary Disease

CRF – Chronic Renal Failure

DM – Diabetes Mellitus

ESRD – End Stage Renal Disease

ESRF – End Stage Renal Failure

HF – Heart Failure

IDDM – Insulin Dependent Diabetes Mellitus

IHD – Ischaemic Heart Disease

MI – Myocardial Infarction

NIDDM – Non Insulin Dependent Diabetes Mellitus

NR – Not Reported

NS – Not Specified

PA – Peripheral Arteriopathy

PAD – Peripheral Arterial Disease

PAOD – Peripheral Artery Occlusive Disease

PVD – Peripheral Vascular Disease

RD – Renal Disease

RF – Renal Failure

Table 36 Treatment Details for All Wound Types

Reference | Device | Dressing | Prior Treatments | Wound Preparation and Concurrent Treatments | Length of Follow-up (months )
Smith & Nephew Wound Management Unpublished Data(96) | VISTA™ or EZ-Care™ Smith and Nephew systems | Antimicrobial gauze, non-adherent gauze | NR | NR | 7 days post treatment discontinuation
Baharestani et al. 2008(93) | V.A.C.® | GranuFoam® | NR | NR | NR
Bannasch et al. 2008(344) | V.A.C.® | NR | Doppler probe was placed against the drainage vein with the cuff secured around the vessel with nylon sutures, free flaps were split-skin grafted | Doppler probe | NR
Bapat et al. 2008(153) | V.A.C.® | Polyurethane (PU) foam | NR | Debridement and antibiotics | Group A: Median: 23, Range: 12-35 Group B: Median: 17.5, Range: 6–21 Group C: Median: 22.5, Range: 13–34 Group D: Median: 16, Range: 7–22
Brandi et al. 2008(345) | V.A.C.® | PU foam | Debridement, skin graft | Cryo-preserved homologous de-epidermalized dermis (DED) | Avg: 10 months
Campbell et al. 2008(84) | VISTA™, or Versatile-1™, or EZ-Care™ Smith and Nephew systems | Saline moistened antimicrobial gauze | NR | NR | NR
Chen et al. 2008(160) | V.A.C.® | PU foam | NR | Debridement, Median: 2 ±1, Range: 1-6 | Median: 17, Range: 1–43
Dhiret al. 2008(346) | V.A.C.® | Black V.A.C. GranuFoam® and white V.A.C. Vers-Foam® | NR | Incision, drainage, debridement; Hyperbaric oxygen treatment, dermal grafts, salivary diversion, regional flap reconstruction | NR
Ennker et al. 2008(361) | V.A.C.® | NR | NR | Debridement | NR
Fleck et al. 2008(362) | V.A.C.® | NR | NR | NR | NR
Gabriel et al. 2008(383) | V.A.C.® | 38: PU GranuFoam® 14: GranuFoam® silver dressing 6: abdominal dressing system PVA foam under GranuFoam® in 3 fasciotomy cases | NR | NR | Mean: 12, Range: 3–34
Gdalevitch et al. 2008(154) | V.A.C.® | Black PU foam | NR | NR | NR
Ha et al. 2008(140) | V.A.C.® | NR | NR | Antibiotics | Median: 85 days, Range: 14–698 days
Hamed et al. 2008(363) | V.A.C.® | PU foam sponge | Heavy dressings and bed rest | NR | Median: 12, Range: 4–32
Horch et al. 2008(155) | V.A.C.® | PU sponge | Conservative treatment with repeated chemical debridement, 1 biologic debridement, and antibiotic therapy | Serial surgical debridement, general or spinal anesthesia for dressing changes or injection of 1% lidocaine | NR
Labanaris et al. 2008(364) | V.A.C.® | NR | NR | Debridement and intravenous antibiotics | NR
Lopez et al. 2008(365) | V.A.C.® | GranuFoam® | NR | NR | NR
Mokhtari et al. 2008(366) | V.A.C.® | PU foam | NR | Debridement and irrigation | NR
Ploumis et al. 2008(80) | V.A.C.® | NR | NR | Irrigation and debridement for treatment preparartion and Intravenous antibiotics throughout treatment | Average: 14 Range: 12–28
Rhode et al. 2008(347) | V.A.C.® | NR | 4 patients had skin graft approximately 1 week after surgery from lateral thigh | Wound beds irrigated, debrided with sharp curette | Avg: 12.6, Minimum: 7
Rozen et al. 2008(348) | Conventional disposable closed system suction drain w/associated tubing^1^ | Disposable foam base | NR | Antibiotics | NR
Steiert et al. 2008(349) | V.A.C.® | PU sponge | Fracture fixation | Initial debridement of necrotic tissue, perioperative antibiotic therapy minimum of 5 days | NR
Svensson et al. 2008(149) | V.A.C.® | PU sponge | NR | NR | Median: 16
Wondberg et al. 2008(161) | V.A.C.® | PU foam | NR | Antibiotic therapy | 16 patients Median: 20.1, Range: 5–40
Baharestani et al. 2007(162) | V.A.C.® | 18: PU GranuFoam® 5: PVA 1: GranuFoam® silver | NR | 7 chest wounds: white foam, Xeroform (2) and Vaseline gauze (5) 6 total parenteral nutrition (TPN) 3 received enteral feedings systemic antibiotic | NR
Bendewald et al. 2007(82) | V.A.C.® | NR | NR | NR | Range: 6–14
Bendo et al. 2007(76) | V.A.C.® | NR | NR | Antibiotics | NR
Bhattacharyya et al. 2007(350) | V.A.C.® | NR | NR | Serial debridement approximately every 48 hrs, antibiotics from presentation to 48 hrs after definitive wound closure | Infected: 20.6 ±13.2, noninfected: 14 ±5.5
Bollero et al. 2007(141) | V.A.C.® | NR | NR | Debridement | Avg: 265 days, Range: 33–874 days
Dedmond et al. 2007(27) | V.A.C.® | NR | NR | Irrigation, debridement, antibiotics | Avg: 19.6
Ferron et al. 2007(83) | V.A.C.® | PU foam | NR | NR | NR
Helgeson et al. 2007(351) | V.A.C.® | NR | NR | Irrigation and debridement | NR
Horn et al. 2007(78) | V.A.C.® | Vers-Foam® and GranuFoam® if necessary | NR | Debridements between dressing changes, sedation for dressing changes | NR
Jones et al. 2007(150) | V.A.C.® | PU sponge | NR | Debridement & irrigation, antibiotics | At least 90 days
Kotsis and Lioupis 2007(73) | V.A.C.® | NR | NR | NR | Mean: 17.2 Range: 1–28
Labler and Trentz 2007(352) | V.A.C.® | PU foam | NR | Debridement, antibiotics | Avg: 19.8 ±1, Range: 7–38
Machen 2007(74) | V.A.C.® | Black sponges | NR | NR | NR
McCord et al. 2007(142) | V.A.C.® | White and black foam | NR | Debridement, intravenous analgesic or general anesthesia, or conscious sedation for dressing changes | Up to 7 months after negative pressure therapy start
Mendonca et al. 2007(143) | V.A.C.® | NR | Chronic: debridement and topical destroying gels, regular moist wound healing dressing, maggot debridement therapy, compression bandaging for venous ulcers | systemic antibiotics | NR
Peck et al. 2007(353) | V.A.C.® | NR | NR | Debridement, operative washout (during) every 48–72 hours | NR
Perez et al. 2007(95) | V.A.C.® | NR | NR | NR | Avg: 324 days Range: 70–445
Rao et al. 2007(163) | V.A.C.® | GranuFoam® | NR | NR | NR
Segers et al. 2007(354) | V.A.C.® | NR | NR | NR | Mean: 4.3 yrs, Range: 53–3,350 days
Senchenkov et al. 2007(355) | V.A.C.® | NR | Skin grafting | Debridement | NR
Shrestha et al. 2007(367) | V.A.C.® | NS | Percutaneous drainage of localized collections and regular change of dressings and antibiotics | NR | NR
Strecker et al. 2007(318) | V.A.C.® | NR | NR | radical debridement | 23 ±13 months
van Rhee et al. 2007(368) | V.A.C.® | NR | NR | Surgical debridement, antibiotics | Avg: 25 months, Range: 9–42
Andrews et al. 2006(88) | V.A.C.® | PU foam | NR | Sharp debridement between dressings | NR
Cothren et al. 2006(356) | V.A.C.® | Large black sponges and white sponges "Covering bowel with multiple white sponges overlapped like patchwork, and the fascia is placed under moderate tension over the white sponges with number 1-polydioxanone sutures" | Subfascial 1010 Steri Drape (3M healthcare), blue towel, or laparotomy pad coverage, Jackson Pratt (Bard) drain placement and loben (3M) coverage for temporary closure | NR | NR
DeFranzo et al. 2006(156) | V.A.C.® | NR | NR | NR | 28 had 2 yrs follow-up
Gorlitzer et al. 2006(369) | V.A.C.® | NR | NR | Mediastinal necrosectomy | NR
Heller et al. 2006(87) | V.A.C.® | PU and PVA foam | Saline soaked gauze dressings for 1-6 weeks | Debridement prior and during | At least 6
Labler et al. 2006(370) | V.A.C.® | PU foam | antibiotics, surgical interventions, implant removal / change | NR | 14 patients Avg: 28.9, Range: 15–40
Leininger et al. 2006(111) | V.A.C.® | Sponge | NR | Debridement & operative irrigation, pulsatile lavage | All patients scheduled for f/u in outpatient clinic for 1–12 weeks after discharge
Morgan et al. 2006(164) | V.A.C.® | NR | Total contact casting, regular casting, negative pressure therapy, enzymatic debridement, resection of infected bone/soft tissue, mechanical debridement, placement of various biological dressings | NR | Avg: 13, Range: 1–21
Pelham et al. 2006(371) | V.A.C.® | PU foam | NR | Irrigation and sharp surgical debridement; intravenous antibiotics | Mean: 24, Range: 14–32
Sartipy et al. 2006(151) | V.A.C.® | PU foam | NR | NR | NR
Wada et al. 2006(384) | V.A.C.® | NR | NR | NR | NR
Adamkova et al. 2005(152) | V.A.C.® | Black PU sponge | NR | Debridement | NR
Agarwal et al. 2005(372) | V.A.C.® | PU sponge | NR | Debridement, antibiotic | NR
Butter et al. 2005(144) | V.A.C.® | Black or white sponge | 8 pilonidal sinus 24–48 hours wet to dry dressings | NR | Avg: 8
Caniano et al. 2005(165) | V.A.C.® | NR | NR | NR | Group 1: Avg: 13, Range: 8–36 Group 2, 3,4: NR
Cowan et al. 2005(373) | V.A.C.® | PU foam | NR | Irrigation & debridement, antibiotics | NR
Labler et al. 2005(357) | V.A.C.® | PU foam | NR | NR | Range: 5–33
Lee et al. 2005(374) | V.A.C.® | PU sponge | Conventional methods | Debridement | Mean: 35, Range: 5–70
Mendonca et al. 2005(375) | V.A.C.® | Open-cell foam | Surgically debrided and wound dressing, amputation, antibiotics | Debridement | Avg: 6.3, Range: 1–18
Rosenthal et al. 2005(89) | V.A.C.® | NR | NR | NR | Minimum: 5
Sjogren et al. 2005(179) | V.A.C.® | NR | NR | NR | Avg: 2.7 ±1.7 patient years, Range: 0–5.8 patient years
Stoeckel et al. 2005(358) | V.A.C.® | Foam | NR | NR | NR
Antony and Terrazas (2004(385) | V.A.C.® | PU foam | NR | Operative and non-operative debridement, pulse lavage irrigation, antimicrobials | NR
Bihariesingh et al. 2004(386) | V.A.C.® | Open-cell foam | Antibiotics and local wound management | Debridement | Mean: 514.8 days, Range: 246–693 days
Loree et al. 2004(387) | V.A.C.® | PU ether, open-cell foam | Multiple treatment modalities (not specified) and had been treated with at least 3 other modern materials used for debridement | Debridement, analgesia | NR
Mehbod et al. 2004(376) | V.A.C.® | NR | NR | Irrigation and debridement, antibiotic therapy | Avg: 10, Range: 6–24
O'Conner et al. 2004(377) | V.A.C.® | NR | NR | Sedation and analgesia with dressing changes | Avg: 7, Range: 3–21
Routledge et al. 2004(378) | V.A.C.® | PU foam and PVA foam | NR | Debridement and antibiotics | NR
Savolainen et al. 2004(359) | V.A.C.® | Polyvinyl foam | NR | Anesthesia | NR
Scholl et al. 2004(81) | V.A.C.® | PU foam | NR | NR | Mean: 14
Stone et al. 2004(90) | V.A.C.® | NR | NR | NR | NR
Weed et al. 2004(37) | V.A.C.® | NR | NR | Debridement | NR
Demaria et al. 2003(145) | V.A.C.® | PU foam | Conventional therapies, polyvidone-iodine bandages, oral antimicrobial therapy | Surgical debridement, polyvidone-iodine applied & rinsed at dressing changes | NR
Gustafsson et al. 2003(146) | V.A.C.® | PU foam | NR | Antibiotics | Median: 13, Range: 3–41
Herscovici et al. 2003(360) | V.A.C.® | PU ether sterile foam | NR | Surgical debridement | NR
Isago et al. 2003(91) | V.A.C.® | PU foam | NR | NR | NR
Molnar et al. 2003(388) | V.A.C.® | NR | NR | Integra incorporation (artificial skin substitute) | NR
Schimp et al. 2003(147) | V.A.C.® | Black PU foam or white PVA soft foam | NR | NR | Mean: 52 days, Range: 0–270 days
Stonerock et al. 2003(77) | V.A.C.® | PU foam | NR | NR | 6
Suliburket al. 2003(166) | V.A.C.® | PU sponge | NR | Washed out at each dressing | NR
Wongworawat et al. 2003(75) | V.A.C.® | PVA foam | NR | NR | NR
Armstrong et al. 2002(85) | V.A.C.® | NR | NR | Sharp debridement | NR
Clare et al. 2002(379) | V.A.C.® | Foam dressing | 15 serial wound debridement, dressing changes, oral antibiotics 13 operative irrigation and debridement 6 revascularization procedures 5 had amputation | NR | NR
Fleck et al. 2002(380) | V.A.C.® | PU foam | NR | Debridement, irrigation with 1 liter of dilute povidone-iodine solution (dressing changes), antibiotics | NR
Garner et al. 2001(86) | V.A.C.® | PU foam | NR | NR | NR
Gustafsson et al. 2001(381) | V.A.C.® | PU foam | NR | Antibiotics | At least 3 months
Hersh et al. 2001(94) | V.A.C.® | PU sponge | NR | Debridement | NR
DeFranzo et al. 2000(157) | V.A.C.® | Open-cell foam | NR | Debridement | Wounds have been stable from 6 months to 6 yrs
De Lange et al. 2000(167) | V.A.C.® | Open-cell PU foam | NR | Debridement, local or systemic anesthetic (lidocaine 1%) | Range: 2–35
Deva et al. 2000(382) | V.A.C.® | Foam | NR | NR | At least 3
Mooney et al. 2000(79) | V.A.C.® | NR | NR | Conscious sedation or brief general anesthesia for dressing changes | NR
Avery et al. 2000(92) | V.A.C.® | Opsite by Smith and Nephew | NR | NR | NR
Wu et al. 2000(158) | V.A.C.® | PU or PVA foam | NR | Debridement, non steroidal anti-inflammatory drugs or morphine | NR
Lang et al. 1999(159) | Vacuum sealing technique^1^ | PVA | NR | Debridement | Avg: 13, Range: 3–35
Argenta and Morykwas 1997(148) | V.A.C.® | PU ether foam | Dressing changes, topical treatments, surgical procedures | Debridement | NR
Mullner et al. 1997(389) | V.A.C.® | PVA foam | Group A: wet to dry dressings Group B and C: irrigation, debridement & cultured, intravenous aminopenicillin and sulbactam 6.6 g per day for infected wounds or if cultures were positive, and wet to dry dressings | break/>Group B: intravenous antibiotics | NR

Vacuum Assisted Closure (V.A.C.®) manufactured by KCI

1 Manufacturer not specified

NR Not reported

PU Polyurethane

PVA Polyvinyl alcohol

Table 37 Outcomes Reported for All Wound Types

Reference | Duration of Treatment | Time to 50% Reduction of Initial Volume | Percent Change in Volume | Time to Complete Wound Closure | Percent of Wound Completely Healed | Healing of Infected Wounds | Reduction in Sepsis, Edema, or Amputation | Survival | Quality of Life/ Satisfaction with Treatment | Improved Wound Condition | Facilitation of Surgical Closure
Smith & Nephew Wound Management Unpublished Data(96) | X | X | X | X | X | X | X | | | X
Baharestani et al. 2008(93) | X | | | | | X | | X | | X | X
Bannasch et al. 2008(344) | X | | | | X | | X | | | X | X
Bapat et al. 2008(153) | X | | | | | X | | | | X | X
Brandi et al. 2008(345) | X | | | | | | | | | | X
Campbell et al. 2008(84) | X | X | X | | X | | | | | X
Chen et al. 2008(160) | X | | | | X | X | | X | | X | X
Dhir et al. 2008(346) | | | | | X | | | | | | X
Ennker et al. 2008(361) | X | | | | | | | | | | X
Fleck et al. 2008(362) | X | | | X | | | | X | | X | X
Gabriel et al. 2008(383) | X | | | X | | | X | | | X | X
Gdalevitch et al. 2008(154) | X
Ha et al. 2008(140) | X | | | | X | X | | X | | X | X
Hamed et al. 2008(363) | X | | | | X | | | | | X
Horch et al. 2008(155) | | | | X | | X | | | X | X | X
Labanaris et al. 2008(364) | X | | | | | | X | | | | X
Lopez et al. 2008(365) | X | | | X | | | | X | | X
Mokhtari et al. 2008(366) | | | | | | X | | X | | | X
Ploumis et al. 2008(80) | X | | | X | X | X | | | | X
Rhode et al. 2008(347) | X | | | | X | | | | | X | X
Rozen et al. 2008(348) | X | | | | | | | | | | X
Steiert et al. 2008(349) | X | | | X | | | | | | X | X
Svensson et al. 2008(149) | X | | | X | X | X | | X | | X | X
Wondberg et al. 2008(161) | X | | | X | | | X | | X | X | X
Baharestani et al. 2007(162) | X | | | X | X | X | | | | X | X
Bendewald et al. 2007(82) | X | | | X | X | | | | | X
Bendo et al. 2007(76) | X | | | X | | | X
Bhattacharyya et al. 2007(350) | | | | X | | X | | | | X | X
Bollero et al. 2007(141) | X | | | | X | | | | | X | X
Dedmond et al. 2007(27) | X | | | X | X | X | | | | X | X
Ferron et al. 2007(83) | X | | | X | X | X | X | X | X | X | X
Helgeson et al. 2007(351) | | | | X | | | X | | | X | X
Horn et al. 2007(78) | X | | | X | | X | | | | X
Jones et al. 2007(150) | X | | | | | | | | | | X
Kotsis and Lioupis 2007(73) | X | | | | X | | X
Labler and Trentz 2007(352) | X | | | | | X | | | | X | X
Machen 2007(74) | | | | | X | X | X | | | X | X
McCord et al. 2007(142) | X | X | X | | | | X | | | X | X
Mendonca et al. 2007(143) | X | X | X | | X | X | | | X | X | X
Peck et al. 2007(353) | | | | X | | | | | | X | X
Perez et al. 2007(95) | X | | | | | | | X | X | X | X
Rao et al. 2007(163) | X
Segers et al. 2007(354) | X | | | X | | | | X
Senchenkov et al. 2007(355) | X | | | X | X | | | | | X | X
Shrestha et al. 2007(367) | X | | | | X | X | | | | X
Strecker et al. 2007(318) | X | | | | | X | | | | X | X
van Rhee et al. 2007(368) | | | | X | | X | | | | X
Andrews et al. 2006(88) | X | | | | | | | | | X | X
Cothren et al. 2006(356) | | | | X | | | | | | X
DeFranzo et al. 2006(156) | X | | | X | X | X | | X | | X | X
Gorlitzer et al 2006(369) | X | | | | | | | | | X | X
Heller et al. 2006(87) | X | | | | | | X | | | X | X
Labler et al. 2006(370) | X | | | X | X | X | | | | X | X
Leininger et al. 2006(111) | | | | X | | X | | | | X | X
Morgan et al. 2006(164) | | | | | X | | | | | X | X
Pelham et al. 2006(371) | X | | | X | X | X | | | | X | X
Sartipy et al. 2006(151) | X | | | | | | | X
Wada et al. 2006(384) | X | | | X | | | | | | X | X
Adamkova et al. 2005(152) | X | | | X | X | X | X | | | X | X
Agarwal et al. 2005(372) | X | | | | | X | | | | X | X
Butter et al. 2005(144) | X | | | X | X | | | | | X | X
Caniano et al. 2005(165) | X | | | | X | | | | | X | X
Cowan et al. 2005(373) | X | X | X | X | | X | X | X | | X | X
Labler et al. 2005(357) | X | | | X | | X | X | X | | X | X
Lee et al. 2005(374) | X | | | X | X | X | | | | X | X
Mendonca et al. 2005(375) | | | X | | X | X | X | | | X | X
Rosenthal et al. 2005(89) | X | | | | | | | | | X | X
Sjogren et al. 2005(179) | | | | | | | | X
Stoeckel et al. 2005(358) | X | | | | X | | | | | X | X
Antony and Terrazas 2004(385) | X | | | X | | X | | | | X
Bihariesingh et al. 2004(386) | X | | | X | | | | | | X | X
Loree et al. 2004(387) | X | | X | | | | | | | X
Mehbod et al. 2004(376) | X | | | X | | | | | | X | X
O’Conner et al. 2004(377) | X | | | | X | X | | | | X | X
Routledge et al. 2004(378) | X | | | | X | X | | | | X
Savolainen et al. 2004(359) | X | | | | X | X | | | | X | X
Scholl et al. 2004(81) | X | | | X | X | X | | | | X | X
Stone et al. 2004(90) | | | | X | | | X | X | | X | X
Weed et al. 2004(37) | X | | | | X | X | | | | X | X
Demaria et al. 2003(145) | X | | | | X | X | | | | X | X
Gustafsson et al. 2003(146) | X
Herscovici et al. 2003(360) | X | | | | | | | | | | X
Isago et al. 2003(91) | X | | X | | | X | X | | | X | X
Molnar et al. 2003(388) | X | | | | | | | | | X | X
Schimp et al. 2003(147) | X | | X | | X | | | | | X | X
Stonerock et al. 2003(77) | X | | | X | | | X | | | X
Suliburk et al. 2003(166) | X | | | X | | | | | | X
Wongworawat et al. 2003(75) | X | | X | | | | | | | X
Armstrong et al. 2002(85) | X | | | X | | | X | | | X
Clare et al. 2002(379) | X | | | | X | | | | | X | X
Fleck et al. 2002(380) | X | | | | X | X | | X | | X | X
Garner et al. 2001(86) | X | | | | | | | | | X
Gustafsson et al. 2001(381) | X | | | X | | X | | | | X | X
Hersh et al. 2001(94) | X | | | | | X | | X | | X | X
DeFranzo et al. 2000(157) | | | | | | X | X | | | X | X
De Lange et al. 2000(167) | X | | | | X | X | X | | | X | X
Deva et al. 2000(382) | X | X | X | | X | X | | | | X | X
Mooney et al. 2000(79) | | | | | | | | | | X | X
Avery et al. 2000(92) | X | | | | | | | | | X | X
Wu et al. 2000(158) | X | | | | | X | | | | | X
Lang et al. 1999(159) | X | | | X | X | X | | | | X | X
Argenta and Morykwas 1997(148) | X | | X | X | X | X | X | | | X | X
Mullner et al. 1997(389) | X | | X | X | X | X | X | | | X | X

Table 38 Adverse Events Reported for All Wound Types

Reference | Pain | Bleeding | Infection/ Bacterial Load | Mortality | Other Complications
Smith & Nephew Wound Management Unpublished Data(96) | | | X
Baharestani et al. 2008(93)
Bannasch et al. 2008(344)
Bapat et al. 2008(153) | | | X | X
Brandi et al. 2008(345)
Campbell et al. 2008(84)
Chen et al. 2008(160) | | | | | X
Dhir et al. 2008(346)
Ennker et al. 2008(361)
Fleck et al. 2008(362)
Gabriel et al. 2008(383)
Gdalevitch et al. 2008(154) | | | X
Ha et al. 2008(140) | X | | | | X
Hamed et al. 2008(363)
Horch et al. 2008(155) | | | X
Labanaris et al. 2008(364)
Lopez et al. 2008(365)
Mokhtari et al. 2008(366)
Ploumis et al. 2008(80)
Rhode et al. 2008(347)
Rozen et al. 2008(348)
Steiert et al. 2008(349)
Svensson et al. 2008(149) | | X | X | X
Wondberg et al. 2008(161) | | | | | X
Baharestani et al. 2007(162) | | | | | X
Bendewald et al. 2007(82) | | | | | X
Bendo et al. 2007(76)
Bhattacharyya et al. 2007(350)
Bollero et al. 2007(141) | X
Dedmond et al. 2007(27)
Ferron et al. 2007(83)
Helgeson et al. 2007(351)
Horn et al. 2007(78) | X
Jones et al. 2007(150) | | X | X | X
Kotsis and Lioupis 2007(73)
Labler and Trentz 2007(352)
Machen 2007(74)
McCord et al. 2007(142) | X | X | | | X
Mendonca et al. 2007(143) | X
Peck et al. 2007(353)
Perez et al. 2007(95) | | | | | X
Rao et al. 2007(163) | | | | | X
Senchenkov et al. 2007(355)
Segers et al. 2007(354)
Shrestha et al. 2007(367)
Strecker et al. 2007(318)
van Rhee et al. 2007(368)
Andrews et al. 2006(88) | X
Cothren et al. 2006(356)
DeFranzo et al. 2006(156) | | | X
Gorlitzer et al. 2006(369)
Heller et al. 2006(87) | | | | | X
Labler et al. 2006(370)
Leininger et al. 2006(111)
Morgan et al. 2006(164) | | | | | X
Pelham et al. 2006(371)
Sartipy et al. 2006(151) | | X | | X
Wada et al. 2006(384)
Adamkova et al. 2005(152) | | X
Agarwal et al. 2005(372)
Butter et al. 2005(144) | X | | | | X
Caniano et al. 2005(165) | | | | | X
Cowan et al. 2005(373)
Labler et al. 2005(357)
Lee et al. 2005(374)
Mendonca et al. 2005(375)
Rosenthal et al. 2005(89)
Sjogren et al. 2005(179)
Stoeckel et al. 2005(358)
Antony and Terrazas 2004(385)
Bihariesingh et al. 2004(386)
Loree et al. 2004(387)
Mehbod et al. 2004(376)
O’Conner et al. 2004(377)
Routledge et al. 2004(378)
Savolainen et al. 2004(359)
Scholl et al. 2004(81)
Stone et al. 2004(90) | | | | | X
Weed et al. 2004(37) | | | X
Demaria et al. 2003(145) | X
Gustafsson et al. 2003(146) | X | | | | X
Herscovici et al. 2003(360)
Isago et al. 2003(91) | X
Molnar et al. 2003(388)
Schimp et al. 2003(147) | X | X
Stonerock et al. 2003(77) | | | X
Suliburk et al. 2003(166) | | | | | X
Wongworawat et al. 2003(75)
Armstrong et al. 2002(85) | | | X | | X
Clare et al. 2002(379)
Fleck et al. 2002(380)
Garner et al. 2001(86) | | | X
Gustafsson et al. 2001(381)
Hersh et al. 2001(94)
DeFranzo et al. 2000(157) | | | X
De Lange et al. 2000(167) | | | | | X
Deva et al. 2000(382)
Mooney et al. 2000(79) | | X
Avery et al. 2000(92)
Wu et al. 2000(158) | | | X
Lang et al. 1999(159) | | | X
Argenta and Morykwas 1997(148) | X | | X | | X
Mullner et al. 1997(389)

## Systematic Reviews of NPWT Devices

Table 39 Characteristics of Systematic Reviews of NPWT Devices—High Quality Reviews

Citation | Objective | Search Strategy | Key Inclusion/ Exclusion Criteria | Evidence Base/ Method of Assessing Study Quality | Participant Characteristics | Outcomes Assessed | Results and/or Authors’ Conclusions
Gregor et al. 2008(173) Negative Pressure Wound Therapy A Vacuum of Evidence? | To systematically examine the clinical effectiveness and safety of NPWT compared with conventional wound therapy | Searches were completed in MEDLINE, EMBASE, CINAHL, and the Cochrane Central Register of Controlled Trials. Systematic reviews were identified by searching the Cochrane Database of Systematic Reviews, the Database of Abstracts of Reviews of Effects, and the HTA Database thru October 2005. The U.S. F.D.A., other health agencies, clinical experts, and 2 manufacturers were asked to provide clinical data. | Included RCTs and non-RCTs if they had a concurrent control group and evaluated the effect of NPWT versus conventional wound therapy on wound healing. All languages were included. Abstracts were excluded if 2 investigators classified them as not relevant or if not available as full-text articles. | [underlined: Studies:] 7 RCTs 10 non-RCTs [underlined: Comparators:]; - Standard of care; - Healthpoint System; - Bolster dressing; - OpSite; N = 602 Wounds = 667 [underlined: Quality Assessment:] IQWIG Steering Committee Methods (2006) | Patients with the following wound types:; - diabetic foot amputations; - chronic diabetic wounds; - pressure ulcers; - chronic wounds; - skin grafts; - open wounds/abdomen; - infected sternotomy; - acute burns | Included:; - incidence of complete wound closure; - time to wound closure | Authors reported benefit to patients treated with NPWT for surrogate variables of wound healing. Firstly, a significant advantage in favor of NPWT was reported in 4 of 7 studies reporting wound closure. Secondly, pooled data from 6 studies showed a significant reduction in wound size in favor of NPWT. In addition, 1 large RCT (Armstrong) reported a significantly faster rate of generation of granulation tissue in patients treated with NPWT. Despite these favorable results, overall evidence was insufficient to clearly prove an additional clinical benefit of NPWT.
Ubbink et al. 2008^*^(174) Topical negative pressure for treating chronic wounds | To assess the effects of NPWT on chronic wound healing | Studies were identified by searching Cochrane Wounds Group Specialised Register (searched 12/17/07), the Cochrane Central Register of Controlled Trials, Ovid MEDLINE (1950 to November 2007), Ovid EMBASE (1982 to 2007), and Ovid CINAHL (1980 to December 2007) databases. Reference lists of identified studies were searched as well as offer to Kinetic Concepts to submit unpublished or ongoing trials. | All RCTs evaluating the effects of NPWT on patients with chronic wounds and reporting at least one of the following outcomes:; - time to complete healing; - rate of change in wound area and/or volume; - proportion of wounds completely healed; - time to surgical readiness; - survival rate (risk of graft failure) of split-thickness skin grafts | [underlined: Studies:] 7 RCTs [underlined: Comparators:]; - soaked gauze in either 0.9% saline or Ringer’s solution (k = 4); - hydrocolloid gel plus gauze (k = 1); - papain-urea topical (k = 1); - cadexomer iodine or hydrocolloid, hydrogels, alginate and foam (k = 1); N = 205 [underlined: Quality Assessment:] Based on the Dutch Cochrane Collaboration checklist | Patients with the following wound types:; - non-healing ulcers; - diabetic foot ulcers; - wound management before surgical closure; - pressure ulcers; - soft tissue defects; - full-thickness pressure ulcers; - chronic ulcers | Outcomes included:; - Time to complete healing; - Change in wound surface area or volume; - Time to surgical readiness | Authors conclude no significant benefit was shown in the treatment of chronic wounds with NPWT when compared to moistened gauze dressings or other topical agents. The methodological quality of the studies was rated poor due to small study populations, unclear allocation methods, lack in blinding of outcome assessors, and short duration of follow-up. The authors recommend upcoming trials should focus on more patient relevant outcomes such as time to complete wound healing; use validated measures when documenting QOL, pain, or comfort; and include longer term follow-up.
Wasiak and Cleland 2007(172) Topical negative pressure (TNP) for partial thickness burns | To assess the effectiveness of NPWT for those people with partial thickness burns | The Cochrane Wounds Group Specialised Register, the Cochrane Central Register of Controlled Trials, Ovid MEDLINE (1950 to April 2007), Ovid EMBASE (1980 to Week 18 2007) and Ovid CINAHL (1982 to April 2007); and hand searches of retrieved studies were undertaken for identifiable studies. Contact was made with authors of relevant studies to submit details of unpublished or ongoing investigations. | All RCTs and controlled clinical trials involving adults aged 18 years or older with partial thickness burns and evaluating the effectiveness of topical negative pressure (NPWT) were included. | [underlined: Study:] 1 RCT [underlined: Comparator:] Silver sulphadiazine (SSD) N = 20 [underlined: Quality Assessment:] based on the method outlined by Schultz (1995) | Patients aged 20–70 years with total burn surface areas ranging from 5–401% with bilateral thermal hand burns treated less than 24 hours. | Rate of change in wound area and treatment complications | Preliminary data from one study of 20 patients (serving as their own controls). Patients were randomized to receive either a 48 hour treatment of NPWT or silver sulphadiazine. A significant difference in burn size at days 3 and day 5 was reported however no difference was reported at day 14 for NPWT treatment. Methods of randomization and allocation concealment, as well as absence of reporting on clinically relevant outcomes were noted as study shortcomings. The Molnar study was reported as methodologically poor however this assessment was limited to the available text in the abstract.

HTA Health technology assessment

* Reports contain duplicate studies however one report focuses on chronic wounds(174) and excludes 5 studies.

Table 39a Characteristics of Systematic Reviews of NPWT Devices—Moderate Quality Reviews

Citation | Objective | Search Strategy | Key Inclusion/ Exclusion Criteria | Evidence Base/ Method of Assessing Study Quality | Participant Characteristics | Outcomes Assessed | Results and/or Authors’ Conclusions
Schimmer et al. 2008(175) Management of post-sternotomy mediastinitis: experience and results of different therapy modalities | To provide an overview of current literature referring to the primary treatment of post-sternotomy mediastinitis, and to outline the treatment options used in all 79 German heart centers | A systematic search of the MEDLINE database from years 2000–2006 for text written in English or German. A questionnaire distributed from November 2006 to January 2007 to 79 German heart centers. | Articles including “treatment of deep sternal wound infection” and “post-sternotomy mediastinitis” and including an overview of V.A.C.® therapy or referring to both V.A.C.® therapy and primary closure with suction/irrigation systems. | [underlined: Studies:] 2 retrospective 8 non-randomized comparisons [underlined: Comparators]; - primary closure with suction/irrigation systems; - removal of the sternum and a thoracic closure by means of plastic reconstruction (k = 1); N = 611 [underlined: Quality Assessment:] NR | Patients with post-sternotomy mediastinitis (PM) | 1. mortality; 2. recurrence rate; 3. overall survival; 4. quality of life (QOL); 5. hospital stay; 6. treatment failure; 7. infection | This review included 2 retrospective studies evaluating V.A.C.® therapy and 8 non-randomized comparisons evaluating use of V.A.C.® and primary sternal closure, with a closed mediastinal catheter suction/irrigation system. Benefits to treatment with V.A.C.® included less treatment failure, shorter postoperative stay, lower rates of recurring infection, improved QOL, and increase in overall survival. Study flaws mentioned include the lack of differentiation of patients according to PM types, small study populations, and the lack of randomized trials.
Ubbink et al. 2008^*^(183) A systematic review of topical negative pressure therapy for acute and chronic wounds | To summarize up-to-date, high-level evidence on the effectiveness of NPWT on wound healing, in both acute and chronic settings | A search of the following databases: CINAHL, EMBASE and MEDLINE to June 2007 and the Cochrane controlled trials register to issue 4, 2007. One manufacturer, (Kinetic Concepts, Inc.) was contacted to submit unpublished articles. | RCTs evaluating the use and effectiveness of NPWT in patients aged 18 years and over with wounds with various etiologies. Included trials assessed wound healing as primary endpoint; also assessed change in wound surface area, proportion of wounds healed within the trial period, survival rate of split-thickness skin grafts or wound condition ready for surgery or skin grafting. Secondary endpoints were infection, pain, quality of life, edema, microcirculation, bacterial load, adverse events and duration of hospital stay. | [underlined: Studies:] 13 RCTs [underlined: Comparators:]; - soaked gauze in either 0.9% saline or Ringer’s solution; - hydrocolloid gel plus gauze; - papain-urea topical; - cadexomer iodine or hydrocolloid, hydrogels, alginate and foam; - Compression dressing; - Bolster dressing; N = 554 patients (573 wounds) [underlined: Quality Assessment:] Based on the Dutch Cochrane Collaboration checklist | Patients with the following wound types:; - Chronic (venous, arterial, diabetic or pressure; - Acute including split skin grafts | See inclusion criteria. | In this review, Ubbink and co-investigators evaluated the use of NPWT in the treatment of chronic and acute wounds. The authors conclude that there is “no worthwhile evidence to support the use of NPWT in the treatment of various wounds.”
van den Boogaard et al. 2008(107) The effectiveness of topical negative pressure in the treatment of pressure ulcers: a literature review | To gain insight into the effectiveness of NPWT in the treatment of pressure ulcers | A systematic search of MEDLINE, EMBASE, and CINAHL databases was undertaken. There were no language or publication restrictions. | Randomized controlled clinical studies evaluating the effect of topical negative pressure (TNP) compared to a control intervention in patients with pressure ulcers were included. Key inclusion criteria also included:; a. a group of examined patients consists entirely or partly of patients with pressure ulcers;; b. the outcome measurement is in any case wound healing in terms of volume and or surface reduction or increase in granulation tissue;; c. the control intervention has been described. | [underlined: Studies:] 5 RCTs [underlined: Comparators:]; - Healthpoint System (k = 1); - standard of care (k = 3); - various dressings (k = 1); N = 193 [underlined: Quality Assessment:] Dutch Cochrane quality criteria for RCTs | Patients with pressure ulcers | Outcomes included:; - wound volume; - wound healing; - granulation tissue formation; - wound surface; - cost | 2 RCTs only including patients with pressure sores found no significant differences for wound healing. Remaining 3 studies examining wounds with different etiologies found significant differences in wound healing specifically in the decrease of wound treatment time. Study authors conclude that topical negative pressure wound therapy has not proven to be more effective than various control interventions.
Vikatmaa et al. 2008(178) Negative Pressure Wound Therapy: a Systematic Review on Effectiveness and Safety | To review the use of NPWT for problematic wounds | Literature searches of MEDLINE, MEDLINE in-progress, PubMed and Cochrane Controlled Trials Register from 1996. Cochrane Database of Systematic Reviews, Database of Abstracts of Review of Effectiveness, NHS Economic Evaluation Database, and Health Technology Assessment Database; Cliniclaltrials.gov, National Research Register and meta Register; Aggressive Research Intelligence Facility and manufacturers Web sites were also searched. Searches undertaken in July 2006 and updated in January 2008. | RCT in which NPWT was compared with any other local wound therapy for any wound indication were included. | [underlined: Studies:] 14 RCTs [underlined: Comparators:]; - Healthpoint System; - Gauze soaked with Ringer’s; - standard of care; - hydrocolloids, foams or hydrogels, alginates; - pressure dressing; - Mepitel ® silicone-dressing; [underlined: Quality Assessment:] Method according to Samson et al.(182) | Patients with the following wound types:; - pressure; - post-traumatic; - DFU; - chronic | Primary outcomes included:; - total healing; - time to halve the wound volume; - time to reach minimal incision drainage; - area of skin graft loss; - 100% reepithelialization before 112 days; - wound volume decrease; - definitive closure; - wound healing time | NPWT appears to be a safe alternative treatment and is at least as good as or better than current local treatment for wounds. The effectiveness of NPWT is clearly warranted in the treatment of chronic leg ulcers and post-traumatic ulcers. A majority of the studies were classified as having poor internal validity.
Costa et al. 2005 (modified 2007)(181) Vacuum-assisted wound closure therapy (V.A.C.®) McGill University Health Centre (MUHC) Technology Assessment Unit (TAU) | | Articles published through March 27, 2005 in PubMed, EMBASE, Cochrane Database of Systematic Reviews, and CHSPR, ICES, MCHP, and INAHTA databases published in English/French. Hand searches of reference lists of clinical studies, systematic reviews, and technology assessment reports were also undertaken. | Comparative clinical and economic studies, or systematic reviews | [underlined: Studies:] 4 RCTs 2 non-randomized prospective 1 cross-over with subjects receiving a randomly selected alternate 2 week treatment 1 trial in which different halves of wounds received V.A.C.® and moist dressing treatment 5 retrospective reviews 1 systematic review (N not reported) [underlined: Comparators:]; - Standard of care; - OpSite; [underlined: Total study population reported by:] Patients = 312 Wounds = 96 [underlined: Quality Assessment:] NR | Patients aged 4–81 years with the following wound types:; - decubitus ulcers; - diabetic foot; - skin graft; - pressure sores; - lawnmower injuries; - post-sternotomy osteomyelitis; - sternal; - post-sternotomy mediastinitis | Included:; - wound area; - wound volume/depth; - complete healing; - graft appearance; - time to surgery; - hospital stay; - % graft take; - N requiring free flap; - treatment duration; - treatment failure | Authors conclude there is insufficient evidence to recommend the routine use of V.A.C.® therapy. Study results are inconsistent although the more credible evidence suggested no benefit from V.A.C.® therapy. Additional study weaknesses include small and possible heterogeneity of patient populations, inadequate reporting of baseline wound dimensions, and high attrition rates.
Kanakaris et al. 2007(25) The efficacy of negative pressure wound therapy in the management of lower extremity trauma: Review of clinical evidence | To present the existing clinical evidence on the usefulness of NPWT in the acute setting of lower limb trauma | A search was undertaken of MEDLINE and OVID through 1/08/07. | Studies evaluating NPWT in the acute phase (1^st^ week) of lower limb trauma were included. Studies including less than 6 patients; studies in non-English languages; and manuscripts that evaluated clinical applications in different clinical conditions were excluded. | [underlined: Studies:] Acute lower limb trauma; - 1 RCT; - 1 prospective comparative; - 1 retrospective comparative; - 8 case series; - Burn wounds; - 1 RCT; - 2 non-randomized controlled trials; - 2 case series; [underlined: Comparators]:; - SSD; - Standard of care; N = 430 [underlined: Quality Assessment:] NR | Patients with acute lower limb trauma and burn wounds | Outcomes included:; - Time to closure; - Complications; - Hospitalization stay | Based on evidence from a limited number of controlled trials, authors recommend the use of NPWT in the acute phase of blunt, penetrating and thermal trauma of the extremities.
Vlayen et al. 2007(180) Vacuumgeassisteerde Wondbehandeling: een Rapid Assessment | To provide a clear synthesis of the evidence on the clinical effectiveness, safety and cost-effectiveness of NPWT | HTA database, Cochrane Library [OVID], MEDLINE [OVID], Pre-MEDLINE [OVID], EMBASE [Embase.com], CINAHL [OVID], and British Nursing Index [OVID] were searched. Grey literature was accessed via Google and with contact by suppliers and manufacturers. | HTA, systematic reviews, meta-analysis, and RCTs; use of subatmospheric pressure for the treatment of acute or chronic wounds; major outcomes of interest: wound closure, adverse events, and health-related quality of life were included. Excluded were narrative reviews, letters, commentaries, case series, case studies; articles on primary closed wound drainage, the sandwich-vacuum pack technique, etc. and target conditions other than mentioned above. | [underlined: Studies:]; - 7 HTAs; - 15 RCTs; - 5 SRs; [underlined: Comparators:]; - Modified NPWT system; - Healthpoint System; - Gauze (saline or Ringers); - Bolster dressing; - Conventional grafting; - Standard of care; N = 726 [underlined: Quality Assessment:] INAHTA checklist to assess HTA reports and Dutch Cochrane Centre checklist for SRs and RCTs | Patients with the following wound types:; - traumatic; - DFU; - pressure ulcers; - skin grafts; - complex and traumatic; - other | Outcomes included; - time to complete healing; - time to recurrence; - % graft loss; - change in amount of wound surface; - total nursing time; - complete wound closure; - second amputation; - surgical readiness | Previously identified HTA and SR authors reported that the evidence to-date did not justify widespread use of NPWT. The study authors concluded that the newly available evidence did not allow them to make a clear statement about the clinical efficacy and safety of NPWT. RCT study flaws included low methodological quality and small patient populations. Of the 15 RCTs reviewed, only 2 were found to be of moderate quality while none were considered to be of good quality. With the exception of one study (Armstrong, n = 162), study populations ranged from 10 to 65 patients.
Ontario Health Technology Advisory Committee (OHTAC) 2006(184) Negative Pressure Wound Therapy: Update | To update a 2004 report from the Medical Advisory Secretariat’s (MAS) which concluded that no additional funding be provided for V.A.C.® therapy | MEDLINE, EMBASE, MEDLINE In-Process and Non-Indexed Citations, INAHTA, Cochrane Database of Systematic Reviews, and a vacuum therapy Web Site (http://www.vacuumtherapo.co.uk/index.htm) were searched. | Peer-reviewed, published RCTs with sample size of 20 or more patients involved in a human study analyzing negative pressure wound therapy were included. Non-randomized trials were excluded. | [underlined: Studies:] 6 RCTs [underlined: Comparators:]; - standard of care (k = 3); - Healthpoint System (k = 1); - Saline gauze (k = 1); - Bolster dressing (k = 1); N = 346 [underlined: Quality Assessment:] Grading of Recommendations Assessment, Development and Evaluation (GRADE) criteria | Patients with mean age ranging between 42 and 64 years with the following wound types:; - surgical wounds after amputation (k = 1); - non-healing wounds (k = 2); - decubitus ulcers (k = 2); - pressure sores (k = 1) | Outcomes included:; - wound area; - wound volume; - complete wound closure | This report’s recommendation was based on 1 highly rated RCT due to the “low” or “very low” quality rating of the remaining 5 RCTs. Armstrong & Lavery, a 16 week multicentre study, included 162 patients who had acute, surgical wounds from partial foot amputations and were randomized to NPWT or standard care. In addition some underwent surgical wound closure. OHTAC concludes there was not a statistically significant difference between NPWT and standard care in the rate of complete wound closure in patients who had complete wound closure but did not undergo surgical wound closure. It was not possible to discuss whether or not NPWT decreased the time to complete wound closure due to the lack of reporting on this outcome for patients who did not undergo surgical wound closure.
Pham et al. 2006(176) The safety and efficacy of topical negative pressure in non-healing wounds: a systematic review | To compare the efficacy and safety outcomes of NPWT with those of conventional methods in treating particular wound types | MEDLINE, PreMEDLINE, EMBASE, Current Contents, PubMed and Cochrane Library were searched for articles published until October 2004. The York (UK) Centre for Reviews and Dissemination databases, clinicaltrials.gov, National Research Register, Grey Literature Reports, relevant online journals and Internet were searched in October 2004. Searches were again performed in July 2005 for new RCTs. | Articles were chosen if the abstract included safety and efficacy data in the form of RCTs, other controlled or comparatives studies, or case series with consecutive patients; and if wound type was stated. If relevant safety and efficacy data was present then conference abstracts, manufacturers information, and English abstracts from foreign-language articles was also included. | [underlined: Studies:]; - 2 SRs; - 10 RCTs; - 4 non-randomized comparative; - 7 case series; [underlined: Comparators:]; - Gauze; - Healthpoint System; - Bolster dressings; - Compression dressings; - OpSite dressing; - Conventional dressings; [underlined: Quality Assessment:] NR | Patients with the following wound types:; - DFUs; - Skin grafts; - Pressure ulcers; - Sternal wounds; - Chronic wounds and complex/severe wounds | Outcomes included:; - Wound size; - Rate of epithelialization; - Required repeat split-thickness grafts; - Time to reach surgical readiness; - Median hospital stay; - Treatment duration | Some studies demonstrated a benefit to treatment by NPWT, although a majority of studies were probably too small to detect significant differences. Both foot ulcers and chronic and complex wounds treated with NPWT demonstrated significantly greater reduction in wound volume, depth and treatment duration compared to those managed with saline-moistened gauze and wet-to-moist treatment, respectively. NPWT appears to be more effective than absorbent film-backed dressing and bolster dressings in skin-graft management. Authors conclude that NPWT appears to be a promising alternative for the management of various wounds.
Gray & Peirce 2004(177) Is Negative Pressure Wound Therapy Effective for the Management of Chronic Wounds? | To respond to the following questions:; 1. Does NPWT improve healing of chronic wounds when compared to topical treatments?; 2. Does NPWT improve skin graft survival when compared to other topical treatments?; 3. What adverse side effects have been associated with the use of NPWT? | Searches were undertaken of the MEDLINE and CINAHL databases from January 1966 to January 2004; and OVID databases search service including ACP Journal Club, Cochrane Database of Systematic Review, Cochrane Central Register of Controlled Trials and Database of Abstracts of Reviews of Effects. | Articles reporting original research, English-language abstracts and review articles or chapters from key references in the wound, ostomy, and continence (WOC) nursing literature were included. Research used to judge efficacy was limited to systematic literature reviews, results of experimental (RCTs), and quasi-experimental studies. Results from individual case studies and clinical series (summaries of experience based on multiple case studies) were included to address Question 3 (safety). | [underlined: Studies:] 2 systematic reviews including 2 RCTs 3 non-randomized comparison 1 interim analysis and 3 quasi-experimental [underlined: Comparators:]; - saline (gauze or Ringer’s) (k = 3); - Healthpoint System (k = 1); - conventional (k = 1); - gel and gauze (k = 1); - silver sulfadine or mafenide acetate and gauze (k = 1); - OpSite dressing (k = 1); - bolster dressing (k = 1); N = 279 [underlined: Quality Assessment:] NR | Patients with the following wound types:; - pressure; - wound dehiscence; - venous insufficiency; - radiation; - trauma; - diabetic foot wounds; - sterna; - burn | Outcomes included:; - healing time; - change in wound dimensions; - duration of treatment; - time to suture removal | Key questions addressing the benefit of NPWT compared to other topical treatments and the adverse side effects associated with the treatment were included in this review. The authors concluded that NPWT may be superior to saline-moistened gauze in the treatment of chronic wounds. In addition, superiority of NPWT was determined in the treatment of soft-tissue flaps and skin grafts when compared to topical antimicrobial agents and gauze. Authors were unable to determine whether NPWT is superior to advanced dressings in the treatment of pressure ulcers and diabetic foot ulcers. The study also confirms previous reports that adverse events with NPWT are uncommon.
Samson et al. 2004(182) Wound-Healing Technologies: Low-Level Laser and Vacuum-Assisted Closure Prepared for the Agency for Healthcare Research and Quality | To systematically review evidence on low-level laser and V.A.C.® on wound healing outcomes | Searches were completed of MEDLINE, EMBASE, and the Cochrane Controlled Trials Register. Kinetic Concepts Inc., manufacturer of V.A.C. ® was invited to submit clinical data. | Only RCTs of vacuum-assisted closure compared to other wound healing interventions or with sham intervention. Trials must report on one of the outcomes of interest. | [underlined: Studies:] 6 RCTs [underlined: Comparators:]; - Standard of care dressings (k = 5); - Healthpoint System (k = 1); N = 148 [underlined: Quality Assessment:] U.S. Preventive Services Task Force | Patients with mean ages ranging from 41.7 to 56 with the following wound types:; - Full-thickness wounds; - Pressure ulcers; - Non-healing wounds; - DFUs | Primary outcomes included:; - incidence of complete wound closure; - time to complete closure; - adverse events; Secondary outcomes included:; - need for debridement; - infections; - pain; - quality of life | Only 6 RCTs qualified for inclusion in this review; five studies included fewer than 25 patients. All studies were of poor quality with only one study having a clearly stated randomization method. Study authors concluded that V.A.C.® trials did not find a significant advantage for intervention on primary endpoint, complete healing and did not consistently find significant differences on secondary endpoints.

DFU Diabetic foot ulcer

HTA Health technology assessment

NR Not reported

SR Systematic review

* Reports contain duplicate studies however one report focuses on chronic wounds(174) and excludes 5 studies.

Table 39b Characteristics of Systematic Reviews of NPWT Devices—Low Quality Reviews

Citation | Objective | Search Strategy | Key Inclusion/ Exclusion Criteria | Evidence Base/ Method of Assessing Study Quality | Participant Characteristics | Outcomes Assessed | Results and/or Authors’ Conclusions
Contractor et al. 2008(185) Negative Pressure Wound Therapy With Reticulated Open Cell Foam in Children: An Overview | To discuss the versatility of NPWT/ROCF in exclusively pediatric patients with infected wounds | NR | Articles discussing NPWT with reticulated open cell foam (NPWT/ROCF) exclusively in pediatric patients were included. | [underlined: Studies]:; - 9 retrospective reviews; - 11 case studies; [underlined: Comparators]: N/A [underlined: Quality Assessment]: NR | Children ranging in age from neonates to young adults with the following wound types:; - Open fracture; - Traumatic soft tissue; - Chronic extremity wound; - Pressure ulcer; - Pilonidal disease; - Sternal; - Spine fusion; - Fistula; - Burns | Outcomes included:; - Frequency of change; - Pain; - Complications; - Time for wound closure; - Recurrence; - Infection | This review focused on the unique challenges facing the use of NPWT in pediatric patients with infected wounds. The evaluation of single case studies revealed V.A.C.® as a safe alternative to traditional methods in treating axial, chronic extremity wounds and complex lawnmower injuries. Additional benefits included a reduction in infection rates in tibial shaft fractures and spinal fusions. RCTs are necessary to determine consensus on foam (white or black) selection, optimum amount of negative pressure, frequency of NPWT/ROCF dressing changes, and interposing contact layer selection.
Schintler and Prandl 2008(170) Vacuum-assisted closure – what is evidence based? | NR | Articles were identified by search of PubMed and MEDLINE | Included experimental animal studies, RCTs, observations of clinical applications and case reports | [underlined: Studies]:; - 7 RCTs; - 3 SRs; - 2 retrospective reviews; - 1 cost-effective analysis; - 1 consensus study; [underlined: Comparators]:; - standard of care; - saline gauze; - gel products; N = 445 (RCTs) [underlined: Quality Assessment]: NR | Patients with the following wound types:; - chronic leg ulcers; - acute and chronic; - post-amputation stumps; - chronic non-healing; - DFU | - Wound dimensions; - Time to surgery; - rate of granulation tissue formation; - # of wounds healed; - Need for further surgery | A majority of this review focused on the mechanisms of action of vacuum therapy (VT). The investigators concluded that VT, when used by experienced surgeons, is an excellent option to support wound healing.
Raja and Berg 2007(186) Should vacuum-assisted closure therapy be routinely used for management of deep sternal wound infection after cardiac surgery? | To address the question whether V.A.C.® should be routinely used for management of deep sternal wound infection after cardiac surgery | MEDLINE 1996 to November 2006 using OVID interface, EMBASE 1980 to 2006 Week 52 | NR | [underlined: Studies]:; - 7 retrospective analysis; - 2 reviews; - 4 case series; [underlined: Comparators]:; - Standard of care; - V.A.C.® plus myocutaneous flap or primary wound closure; [underlined: Quality Assessment]: NR | Patients with deep sternal wounds | Outcomes included:; - In-hospital stay; - Rewiring; - Survival | Current evidence is weak to support the routine use of V.A.C.® for management of deep sternal wound infection after cardiac surgery.
Mendonca et al. 2006(187) Negative-pressure wound therapy: a snapshot of the evidence | To provide an overview of clinical studies using NPWT and propose avenues for further research to elucidate the exact mechanism of NPWT | MEDLINE, PubMed and Cochrane databases were searched from 1995–2006. | NR | [underlined: Studies]:; - 1 SR; - 5 RCTs; - 10 case series; - 5 basic science; [underlined: Comparators]:; - Saline gauze; - Standard of care; [underlined: Quality Assessment]: NR | Patients with the following wound types:; - Acute and chronic; - Traumatic wounds; - Sternal, spinal and lower limb; - High-energy; - Pressure ulcers; - DFUs; - Infected wounds | Outcomes included:; - Rate of wound healing; - Wound volume; - Need for further surgery; - Readmission rate; - Complication rate | Key points stated by the authors include benefits and complications to treatment by NPWT, role for future research, cost savings and clinical effectiveness. Due to the mixed results in the few RCTs examined, authors cannot confirm a clear clinical effectiveness of TNP. The benefits to treatment, however, include a decrease in time to healing and limb salvage for DFUs; an aid in the healing of skin grafts; and a valuable adjunct to conventional treatment of sternal wound infection.
Gupta & Cho 2004(188) A Literature Review of Negative Pressure Wound Therapy | To assess existing published data supporting the use of NPWT in multiple clinical situations | A search of the MEDLINE database and a hand search of bibliographies were conducted. Authors also asked clinicians who may be considered experts in wound reconstruction and wound care to submit references. | Retrospective case studies, individual case reports, published letters/comments, animal studies and prospective trials were included. | NR [underlined: Quality Assessment]: rating system developed by study authors | Patients with the following wound types:; - sternal wounds; - skin grafts; - pressure sores; - abdominal wall/laparotomy; - enterocutaneous fistulae; - diabetic wounds; - lower extremity wounds/trauma | NR | Authors conclude that the clinical outcomes demonstrate significance in all of the comparative studies with overall outcome data supporting its effectiveness.
Fisher and Brady 2003(168) Vacuum assisted wound closure therapy The Canadian Coordinating Office for Health Technology Assessment (CCOHTA) | NR | NR | NR | [underlined: Studies]: 4 randomized controlled trials (RCTs) 1 interim analysis [underlined: Comparators]:; - saline gauze (k = 2); - OpSite (k = 1); - conventional treatment (k = 1); - Healthpoint System (k = 1); N = 145 [underlined: Quality Assessment]: NR | Patients with the following wound types:; - post-operative diabetic foot; - requiring skin grafts; - elective surgery patients – postoperative ventral hernia repair; - pressure ulcers (interim analysis) | Included:; - Changes in wound volume/depth; - Duration of treatment; - Length of hospital stay; - Time to suture removal | Outcomes from four small RCTs and 1 interim analysis treated with vacuum assisted closure (V.A.C.®) therapy include a statistically significant positive impact on healing rate, faster healing and a greater reduction in wound surface area. Due to study flaws including short-term follow-up, questionable methods of randomization and allocation concealment, the authors conclude that the studies provide only poor quality data and weak evidence that V.A.C.® therapy may be superior to conventional methods used in healing wounds.
Higgins 2003(169) The effectiveness of vacuum assisted closure (V.A.C.®) in wound healing Clayton, Australia, Centre for Clinical Effectiveness (CCE) | To assess the effectiveness of V.A.C.® in terms of healing time and wound closure compared to passive wound therapy | The Cochrane Library; Ovid Biological Abstracts, MEDLINE, EBM Reviews, CINAHL, and PreMEDLINE; Australasian Medical Index; National Guidance Clearinghouse; Scottish Intercollegiate Guideline Network and Web site “www.vacuumtherapy.co.uk/index.htm” were all searched through August 2003. | Studies comparing vacuum assisted closure with any other form of dressing in patients with acute and chronic wounds were included. Level III and IV Evidence, studies published in non-English language, presenting data published in another report and narrative reviews were excluded. | [underlined: Studies]: 1 Systematic review including 2 RCTs 1 RCT 1 interim analysis [underlined: Comparators]:; - saline gauze (k = 2); - wet-to-dry/wet-to-wet dressings (gauze soaked with Ringers solution) (k =1 ); - Healthpoint System (k = 1); N = 78 [underlined: Quality Assessment]: based on NHMRC guidelines (2000) | Patients with the following wound types:; - pressure sores (paraplegic or tetraplegic patients); - chronic wounds; - diabetic foot ulcers; - ischial, sacral, malleolar, trochanteric and calcaneal | Outcomes included:; - Time for wound size to reduce to 50% of the initial volume; - Time to complete healing; - Rate of change in wound area; - Wound volume; - Proportion of wounds completely healed within trial period | In this update to the Evans and Land (2003) systematic review, investigators confirm previous findings that V.A.C.®, when compared to other wound therapies, may provide an additional treatment benefit to patients. The methodological limitations and small study size of the four included studies, however, limits the validity of any study conclusions.

DFU Diabetic foot ulcer

NR Not reported

SR Systematic review

Table 40 Study Inclusion in Systematic Reviews

Reference | Contractor 2008(185)^***^ | Costa 2005(181) | Fisher 2003(CCOHTA)(168) | Gray 2004(177) | Gregor 2008(173) | Gupta 2004(188)^*^ | Higgins 2003(169) | Kanakaris 2007(25)^**^ | Mendonca 2006(187)^**^ | Noble-Bell and Forbes 2008(70) | OHTAC 2006(184) | Pham 2006(176)^**^ | Raga and Berg 2007(186)^**^ | Samson 2004(182) | Schimmer 2008(175) | Schintler and Prandl 2008(170) | Ubbink 2008(174) | Ubbink 2008(183) | van den Boogaard 2008(107) | Vikatmaa 2008(178) | Vlayen et al. 2007(180) | Wasiak 2007(172)
Argenta 1997 | | | | | | | | | X | | | | | | | X
Armstrong 2005 | | | | | X | | | | | X | X | | | | | X | | X | | X | X
ASERNIP 2003 | | | | | | | | | | | | | | | | | | | | | X
Augustin 2007 | | | | | | | | | | | | | | | | X
Avalia-T 2005 | | | | | | | | | | | | | | | | | | | | | X
Berg 2000 | | | | | | | | | | | | | | | X
Braakenburg 2006 | | | | | | | | | | | | | | | | X | | X | X | X | X
Catarino 2000 | | X | | | | | | | | | | X | | | X
Costa 2005
Cowan 2005 | | | | | | | | | | | | | | | X
Davydov 1994 | | | X | X | | | | | | | | X
Domkowski 2003 | | | | | | | | | | | | | | | X
Doss 2002 | | X | | | X | | | | | | | X
Eginton 2003 | | X | | X | X | | | | | X | | X | | X | | X | X | X | | X | X
Etoz 2004 | | | | | X | | | | | X | | | | | | | | X | | X | X
Evans 2006
Evans 2001 | | X
Fleck 2002 | | | | | | | | | | | | | | | X
Ford 2002 | | X | X | X | X | | X | | | | X | X | | X | | X | X | X | X | X | X
Fuchs 2005 | | | | | | | | | | | | | | | X
Genecov 1998 | | X | X | X | X | | | | | | | X | | | | | | | | | X
Greer 1999 | | | | | | | | | | | | X
Gupta 2004
Gustafsson 2002 | | | | | | | | | | | | | | | X
Heath 2002 | | | | | | | | | | | | X
Higgins 2003 (CCE) | | | | | | | | | | | | | | | | | | | | | X
IQWiG 2006
Jeschke 2004 | | | | | | | | | | | | X | | | | | | X | | | X
Joseph 2000 | | X | X | X | | | X | | X | | X | X | | X | | X | X | X | X | X | X
Kamotz 2004 | | | | | X
Llanos 2006 | | | | | | | | | | | | | | | | | | X | | X | X
Loree 2004 | | | | | | | | | X
Luckraz 2003 | | | | | | | | | | | | | | | X
MAAS 2006 | | | | | | | | | | | | | | | | | | | | | X
McCallon 2000 | | | X | X | X | | X | | | X | | X | | X | | X | X | X | | X | X
McGill 2005 | | | | | | | | | | | | | | | | | | | | | X
Mendonca 2006 | | | | | | | | | | | | | | | | X | | | | | X
Moisidis 2004 | | X | | | X | | | | | | X | X | | | | | | X | | X | X
Molnar 2004 | | | | | | | | | | | | | | | | | | | | | | X
Morris 2007 | | | | | | | | | | | | | | | | X
Moues 2004 | | X | | | X | | | | X | | X | X | | X | | X | X | X | X | X | X
OHTAC 2006
Page 2003 | | X | | | X | | | | X | | | | | | | | | | | | X
Pham 2006
Samson 2004 | | | | | | | | | | | | | | | | X
Scherer 2004 | | X | | X | X | | | | | | | X | | | | | | | | | X
Schrank 2004 | | | | | X | | | | | | | | | | | | | | | | X
Schwien 2005
Segers 2005 | | | | | | | | | | | | | | | X
Shilt 2004 | | X | | | | | | X
Sjogren 2005 | | | | | | | | | | | | | | | X
Sjogren 2005
Song 2003 | | X | | X | | | | | | | | X
Stannard 2006 | | | | | | | | X | | | | | | | | | | | | X | X
Stone 2004 | | | | | X
Vuerstaek 2006 | | | | | | | | | | | | | | | | X | X | X | | X | X
Wanner 2003 | | X | | X | X | | X | | | | X | X | | X | | X | X | X | X | X | X
Weed 2004 | | | | | | | | | X
Wild 2004 | | | | | X
Willy 2006 | | | | | | | | | | | | | | | | | | | | | X
Yang 2006 | | | | | | | | X
Total Studies | *** | 14 | 5 | 9 | 16 | NR | 4 | 3^**^ | 6 | 4 | 6 | 16 | NI | 6 | 10 | 14 | 7 | 13 | 5 | 13 | 25 | 1

NI Not included

NR Not reported

* Did not reference study by name

** Case series or chart reviews not included in listing

*** Based on 9 retrospective reviews and 11 case studies not listed

We assessed the quality of each review using the Assessment of Multiple Systematic Reviews (AMSTAR) measurement tool.(171) The AMSTAR consists of 11 items, which have been tested for face and content validity. The items assess whether or not a systematic review includes important elements, such as a comprehensive literature search, assessment of study quality, appropriate methods to combine study findings, and assessment of publication bias. Responses to each item are checked as “Yes” if the review includes that item, “No” if it does not, “CA” if the item cannot be answered by the information provided in the review, or “NA” if the item is not applicable. The AMSTAR does not provide a method for rating the quality of a review. To rate the quality of the reviews, we applied the following criteria: a rating of “High” if the review received mostly “yes” responses (at least 8), a rating of “Low” if the review received mostly “no” responses (at least 8), and a rating of “Moderate” if the review received mixed responses.

Table 41 Quality of Systematic Reviews

Reference | Was an “a priori” design provided? | Was there duplicate study selection and abstraction? | Was a comprehensive literature search performed? | Was the status of publication (i.e., English only) used as inclusion criterion? | Was a list of studies (included and excluded) provided? | Were the characteristics of the included studies assessed and documented? | Was the scientific quality of the included studies assessed and documented? | Was the scientific quality of the included studies used appropriately in formulating the conclusions? | Were methods used to combine the findings of studies appropriate? | Was the likelihood of publication bias assessed? | Was any conflict of interest stated? | Overall Rating
Contractor et al. 2008(185) | N | N | N | N | N | N | N | N | NA | N | N | Low
Gregor et al. 2008(173) | CA | Y | Y | Y | N | N | Y | Y | Y | Y | Y | High
Noble-Bell and Forbes 2008(70) | CA | Y | Y | Y | Y | N | N | Y | NA | N | N | Moderate
Schimmer et al. 2008(175) | CA | N | N | Y | N | N | N | Y | NA | N | N | Moderate
Schintler and Prandl 2008(170) | CA | N | Y | N | N | N | N | N | NA | N | N | Low
Ubbink et al. 2008(174) | Y | Y | Y | Y | Y | Y | Y | Y | NA | Y | Y | High
Ubbink et al. 2008(183) | CA | Y | Y | Y | N | N | Y | Y | NA | N | N | Moderate
van den Boogaard et al. 2008(107) | Y | Y | Y | Y | N | N | Y | Y | NA | N | N | Moderate
Vikatmaa et al. 2008(178) | CA | Y | Y | Y | N | N | Y | Y | N | N | Y | Moderate
Kanakaris et al. 2007(25) | CA | N | Y | Y | N | N | N | Y | NA | N | Y | Moderate
Raja and Berg 2007(186) | Y | N | Y | N | N | N | N | N | NA | N | N | Low
Vlayen et al. 2007(180) | CA | Y | Y | Y | Y | Y | Y | Y | NA | N | N | Moderate
Wasiak and Cleland 2007(172) | Y | Y | Y | Y | Y | Y | Y | Y | NA | Y | Y | High
Mendonca et al. 2006(187) | CA | N | Y | N | N | N | N | N | NA | N | N | Low
Ontario Health Technology Advisory Committee (OHTAC) 2006(184) | N | N | Y | Y | Y | Y | Y | Y | NA | N | N | Moderate
Pham et al. 2006(176) | Y | Y | Y | Y | N | N | Y | Y | NA | N | N | Moderate
Costa et al. 2005(181) | CA | N | Y | Y | N | N | N | NA | NA | N | N | Moderate
Gray & Peirce 2004(177) | ca | N | Y | Y | N | N | Y | Y | NA | N | N | Moderate
Gupta & Cho 2004(188) | N | N | N | Y | N | N | N | N | NA | N | N | Low
Samson et al. 2004(182) | CA | Y | Y | Y | Y | Y | Y | Y | NA | N | N | Moderate

Source: Shea et al. 2007, AMSTAR: a measurement tool to assess the quality of systematic reviews.(171)

ECRI Institute applied overall assessment ratings using the following criteria: “High” if a study had mostly yes’s (at least 8), “Moderate” if a mix of yes, no’s, and can’t answer, and “Low” if a study had mostly no’s (at least 8)

CA Can’t answer

NA Not applicable

Table 42 Adverse Events Described in Systematic Reviews

Reference | Included Study | Wound Type | Treatment(s) | Complication | Comorbidities
Contractor et al. 2008(185) | Trop 2006 | Burn | NPWT | Massive hematoma in 2 burn patients in the absence of anticoagulation therapy in both a graft and a graft-donor site | NR
Contractor et al. 2008(185) | Baharestani 2007 | Open fracture, abdominal compartment syndrome, sacral, sternal, degloving injury | NPWT | Enterocutaneous fistula developing in a patient’s exposed bowel | NR
Contractor et al. 2008(185) | McCord 2007 | Pressure ulcers, extremity, dehisced surgical, sternal, fistulae, abdominal defects | NPWT | 6 wounds failed to heal | Included infection, an enterocutaneous fistula, and/or immunosuppression
Gregor et al. 2008(173) | Armstrong 2005 | DFU | NPWT | Infections – more common in NWPT | NR
Gregor et al. 2008(173) | Armstrong 2005 | DFU | Standard of care | | NR
Noble-Bell and Forbes 2008(70) | McCallon 2000 | DFU | NPWT | Bleeding and pain at time of dressing change | NR
Noble-Bell and Forbes 2008(70) | Etoz 2004 | DFU | NPWT | Bleeding and pain at time of dressing change | NR
Noble-Bell and Forbes 2008(70) | Eginton 2003 | DFU | NPWT | Withdrawal due to incorrect pressure setting (too low) | NR
Schimmer et al. 2008(175) | Segers 2005 | Post-sternotomy mediastinitis | V.A.C.® | | NR
Schimmer et al. 2008(175) | Segers 2005 | Post-sternotomy mediastinitis | Primary closure with suction/irrigation system | Higher rates of recurring infection, therapeutic failure at discharge | NR
Ubbink et al. 2008(174) | Joseph 2000 | Chronic | TNP vs. gauze | 3 complications in the NPWT group (n = 18) and 8 (n = 18) in the gauze group (RR: 2.67; 95% CI: 0.84 to 8.46). Difference not statistically significant | NR
Ubbink et al. 2008(174) | Vuerstaek 2006 | Chronic ulcers | TNP vs. choice of hydrocolloid or alginate dressing | No significant difference in the complication rate between groups (40% in the NPWT group compared with 23% in the wound gel group; (RD: 0.17; 95%CI: −0.06 to 0.40) No significant difference in mean score for present pain intensity (PPI) in the eighth week of treatment (0.2 (SD 0.7) for NPWT and 0.4 (SD: 0.6) for the control group; (WMD: −0.20; 95% CI: −0.53 to 0.13) | NR
Raja and Berg 2007(186) | Gustafsson 2003 | Sternal | V.A.C.® | Subcutaneous fistulae – 3 | NR
Raja and Berg 2007(186) | Domkowski 2003 | Sternal | V.A.C.® | Hospital mortality – 4 (3.7%) for all patients | NR
Raja and Berg 2007(186) | Domkowski 2003 | Sternal | Standard of care | Hospital mortality – 4 (3.7%) for all patients | NR
Raja and Berg 2007(186) | Luckraz 2003 | Sternal | V.A.C.® | Mortality – 4 | NR
Raja and Berg 2007(186) | Luckraz 2003 | Sternal | V.A.C.® followed by a myocutaneous flap or primary wound closure | Mortality – 7.7% Treatment failure rate – 15% | NR
Raja and Berg 2007(186) | Doss 2002 | Sternal | V.A.C.® | Mortality – 1 | NR
Raja and Berg 2007(186) | Doss 2002 | Sternal | Standard of care | Mortality – 1 | NR
Vlayen et al. 2007(180) | Armstrong 2005 | DFU | NPWT | Infection – 17% Treatment related adverse events – 12% | NR
Vlayen et al. 2007(180) | Armstrong 2005 | DFU | Standard of care | Infection – 6% Treatment related adverse events – 13% | NR
Vlayen et al. 2007(180) | Joseph 2000 | Chronic non-healing | NPWT | Infection – 0% | NR
Vlayen et al. 2007(180) | Joseph 2000 | Chronic non-healing | Gauze | Infection – 33% | NR
Vlayen et al. 2007(180) | Vuerstaek 2006 | Leg ulcers | NPWT | Infection – 0% Cutaneous damage secondary to therapy – 23% | NR
Vlayen et al. 2007(180) | Vuerstaek 2006 | Leg ulcers | Standard of care | Infection – 3% Cutaneous damage secondary to therapy – 7% | NR
Vlayen et al. 2007(180) | Braakenburg 2006 | Chronic and acute | NPWT | Discontinuation of treatment – 2 patients due to pain during dressing changes or during NPWT | NR
Vlayen et al. 2007(180) | Braakenburg 2006 | Chronic and acute | Various dressings | | NR
Mendonca et al. 2006(187) | DeFranzo 2001 | Lower extremity | NPWT | 3 cases of osteomyelitis | NR
OHTAC 2006(184) | Armstrong 2005 | DFU | NPWT | Infection – 13 (17%) 4 severe | NR
OHTAC 2006(184) | Armstrong 2005 | DFU | Standard of care | Infection – 5 (6%) 2 were severe | NR
Costa et al. 2005(181) | Song 2003 | Sternal | NPWT | Osteomyelitis – 1 (6%) Calcaneal fractures – 2 (11%) | NR
Costa et al. 2005(181) | Song 2003 | Sternal | Standard of care | Osteomyelitis – 2 (11%) Fistulae – 2 (11%) Wound infection – 6 (33%) | NR
Costa et al. 2005(181) | Genecov 1998 | Skin grafts | NPWT | Chronically draining wound – 1 (7%) Mediastinitis – 1 (7%) Omental flap losses – 0 Intestinal evisceration – 0 Hernia - 0 | NR
Costa et al. 2005(181) | Genecov 1998 | Skin grafts | OpSite | Chronically draining wound – 1 (6%) Mediastinitis – 1 (6%) Omental flap losses – 2 (12%) Intestinal evisceration – 1 (6%) Hernia – 1 (6%) | NR
Costa et al. 2005(181) | Argenta 1997 | Mixed | V.A.C.® | Pain – traumatic wounds required narcotics due to pain level Bleeding – excessive ingrowth of granulation tissue particularly if dressing kept >48 hours Erosion of adjacent tissue – when positioned over bone or if patient lies on the tube Fistulae – 1 case Wound infection – 2 (5.4%) – due to overgrowth of granulation tissue | NR
Gray and Peirce 2004(177) | Evans 2004 (SR) | NR | NPWT | Calcaneal bone fractures – 2 Osteomyelitis – 1 | NR
Gray and Peirce 2004(177) | Evans 2004 (SR) | NR | Topical treatment | | NR
Gray and Peirce 2004(177) | Fisher et Brady 2003 (SR) | NR | NPWT | Pain – induced from application of pressure or the intermittent pressure associated with sponge changes | NR
Gray and Peirce 2004(177) | Argenta 1997 | NR | NPWT | Tissue erosion – around the egress tube when placed too close to a bony prominence or when excessive pressure is placed over the sponge dressing | NR
Gray and Peirce 2004(177) | Gwan-Nulla and Casal 2001^*^ | NR | NPWT | Toxic shock syndrome – 1 | NR
Gray and Peirce 2004(177) | Chester and Waters 2002^*^ | NR | NPWT | Bacteremia and sepsis – 1 | NR
Gray and Peirce 2004(177) | Chester and Waters 2002^*^ | NR | Standard of care | NR | NR
Samson et al. 2004(182) | Ford 2002 | Decubitus ulcers | V.A.C.® vs. Healthpoint System | - 2 deaths (group assignment NR); - 1 patient required distal lower-extremity amputation | - NR; - diabetes, hypertension, vascular insufficiency and sepsis
Samson et al. 2004(182) | Joseph 2000 | Chronic non-healing | V.A.C.® | 3 of 18 V.A.C.® wounds developed complications including fistulae, wound infection, osteomyelitis, and calcaneal fractures | NR
Samson et al. 2004(182) | Joseph 2000 | Chronic non-healing | Standard care | 8 of 18 wounds developed complications including fistulae, wound infection, osteomyelitis, and calcaneal fractures | NR

SR – Systematic review

* Case study

The Medical Advisory Secretariat performed a post hoc calculation to determine if the difference in the rate of wound infections was statistically significant between groups, and calculated a statistically significant higher rate of wound infection in the NPWT group compared to control (P = 0.04), based on a 2-tailed Fisher’s exact test. MAS did not take into account the severity of the wounds.