# Quality of Literature

## ECRI Institute Study Quality Assessment Instrument

The following instrument was used to evaluate the quality of the included studies. Because it was the most consistently reported outcome, wound area reduction was the outcome for which quality was assessed.

The final quality score was calculated: Yes = 1 point; No = -1 point; NR = 0 point; the raw score was then converted to a 0 to 10 scale by adding the number of questions, dividing by double the number of questions, and then multiplying by ten. Controlled trials with a score of less than 6 as Low quality, greater than 6.0 up to 8.5 as Moderate quality, and greater than 8.5 as High quality.

### Quality Assessment Instrument for Controlled Trials

1. Were patients randomly assigned to the study’s groups?
2. Did the study use appropriate randomization methods?
3. Was there concealment of group allocation?
4. For non-randomized trials, did the study employ any other methods to enhance group comparability?
5. Was the process of assigning patients to groups made independently from physician and patient preference?
6. Did patients in different study groups have similar levels of performance on the outcome of interest at the time they were assigned to groups?
7. Were the study groups comparable for all other important factors at the time they were assigned to groups?
8. Did the study enroll all suitable patients or consecutive suitable patients within a time period?
9. Was the comparison of interest prospectively planned?
10. If patients received ancillary treatment(s), was there a ≤5% difference between groups in the proportion of patients receiving each specific ancillary treatment?
11. Were the two groups treated concurrently?
12. Was compliance with treatment ≥85% in both of the study’s groups?
13. Were patients blinded to the treatment they received?
14. Was the healthcare provider blinded to the groups to which the patients were assigned?
15. Were those who assessed the patient’s outcomes blinded to the group to which the patients were assigned?
16. Was the integrity of blinding of patients, physicians or outcome raters tested and found to be preserved?
17. Was the outcome measure of interest objective and was it objectively measured?
18. Was a standard instrument used to measure the outcome?
19. Was there ≤15% difference in the length of follow-up for the two groups?
20. Did ≥85% of the patients complete the study?
21. Was there a ≤15% difference in completion rates in the study’s groups?
22. Was the funding for this study derived from a source that would not benefit financially from results in a particular direction?

Table 15 Answers to Quality Assessment of Controlled Studies Comparing NPWT to Comparative Treatments^†^

Studies | Year | Q1 | Q2 | Q3 | Q4 | Q5 | Q6 | Q7 | Q8 | Q9 | Q10 | Q11 | Q12
Timmers et al.(106) | 2009 | N | N | N | N | N | NR | Y | Y | N | Y | N | NR
Blume et al.(108) | 2008 | Y | Y | Y | Y | Y | Y | Y | NR | Y | Y | Y | Y
Gabriel et al.(339) | 2008 | N | N | N | N | N | N | Y | N | N | Y | N | NR
Korber et al.(340) | 2008 | N | N | N | N | N | N | N | N | N | Y | N | NR
Ozturk et al.(117) | 2008 | N | N | N | N | NR | NR | NR | Y | Y | Y | Y | Y
Rinker et al.(121) | 2008 | N | N | N | N | N | NR | Y | Y | N | Y | NR | NR
Simek et al.(123) | 2008 | N | N | N | N | N | Y | Y | NR | N | Y | N | NR
Armstrong et al.(109) | 2007 | Y | NR | Y | Y | Y | Y | Y | NR | Y | Y | Y | NR
Denzinger et al.(135) | 2007 | N | N | N | N | N | Y | Y | NR | N | Y | N | NR
Lavery et al.(341) | 2007 | N | N | N | Y | N | N | N | NR | N | Y | N | NR
Moues et al.(136) | 2007 | Y | Y | NR | Y | Y | N | N | NR | Y | N | Y | NR
Siegel et al.(119) | 2007 | N | N | N | N | N | N | N | N | N | Y | N | NR
Braakenburg et al.(114) | 2006 | Y | Y | NR | Y | Y | Y | Y | Y | Y | NR | Y | Y
Huang et al.(127) | 2006 | N | N | N | N | NR | Y | Y | N | N | Y | NR | NR
Stannard et al.(125) | 2006 | Y | Y | NR | Y | Y | N | N | N | N | Y | Y | NR
Vuerstaek et al.(115) | 2006 | Y | Y | Y | Y | Y | Y | Y | NR | Y | Y | Y | NR
Yang et al.(72) | 2006 | N | N | N | N | N | NR | NR | Y | N | Y | N | NR
Bickels et al.(134) | 2005 | N | N | N | N | N | NR | NR | Y | N | Y | N | NR
Fuchs et al.(23) | 2005 | N | N | N | N | N | NR | Y | Y | N | Y | N | NR
Immer et al.(130) | 2005 | N | N | N | N | N | N | N | N | N | Y | NR | NR
Schwien et al.(126) | 2005 | N | N | N | N | N | NR | NR | NR | NR | NR | NR | NR
Segers et al.(122) | 2005 | N | N | N | N | N | N | N | N | Y | N | NR | N
Sjogren et al.(139) | 2005 | N | N | N | N | N | Y | N | Y | N | Y | NR | NR
Vidrine et al.(342) | 2005 | N | N | N | N | N | Y | N | Y | Y | Y | Y | NR
Kamolz et al.(343) | 2004 | N | N | N | N | N | N | Y | Y | Y | Y | Y | NR
Labler et al.(71) | 2004 | N | N | N | N | N | NR | NR | N | N | Y | N | NR
Moisidis et al.(112) | 2004 | Y | NR | NR | Y | Y | Y | Y | N | Y | Y | Y | Y
Page et al.(1) | 2004 | N | N | N | N | N | Y | Y | N | N | NR | NR | NR
Stone et al.(133) | 2004 | N | N | N | N | N | Y | Y | N | N | Y | NR | Y
Shilt et al.(138) | 2004 | N | N | N | N | NR | NR | NR | Y | N | Y | N | NR
Domkowski et al.(129) | 2003 | N | N | N | N | N | NR | NR | NR | N | NR | NR | NR
Song et al.(124) | 2003 | N | N | N | N | N | Y | Y | Y | N | Y | NR | NR
Wanner et al.(118) | 2003 | N | N | N | N | N | NR | N | Y | NR | Y | Y | NR
Doss et al.(128) | 2002 | N | N | N | N | N | NR | Y | N | N | Y | NR | NR
Ford et al.(110) | 2002 | Y | Y | NR | Y | Y | NR | NR | NR | Y | Y | Y | NR
Scherer et al.(132) | 2002 | N | N | N | N | N | N | N | Y | N | Y | NR | NR
Catarino et al.(137) | 2000 | N | N | N | N | N | NR | N | Y | N | Y | NR | N
Joseph et al.(113) | 2000 | Y | Y | N | Y | Y | N | NR | NR | Y | NR | Y | NR
McCallon et al.(120) | 2000 | N | N | N | Y | Y | NR | NR | NR | Y | Y | Y | NR
Genecov et al.(131) | 1998 | N | N | N | N | N | Y | Y | NR | Y | Y | Y | Y
Percent of “Y” Responses | | 22 | 17 | 7 | 27 | 25 | 35 | 45 | 37 | 35 | 82 | 37 | 15

† Based on “change in wound area/volume” as the reference outcome

Table 15a Answers to Quality Assessment of Controlled Studies Comparing NPWT to Comparative Treatments^†^

Studies | Year | Q13 | Q14 | Q15 | Q16 | Q17 | Q18 | Q19 | Q20 | Q21 | Q22 | Overall Score
Timmers et al.(106) | 2009 | N | N | NR | N | Y | Y | NR | Y | Y | Y | 4.54
Blume et al.(108) | 2008 | N | N | N | N | N | Y | Y | N | Y | N | 6.59^*^
Gabriel et al.(339) | 2008 | N | N | N | N | Y | Y | Y | Y | Y | N | 3.41^*^
Korber et al.(340) | 2008 | N | N | N | N | NR | NR | Y | Y | Y | NR | 2.72^**^
Ozturk et al.(117) | 2008 | N | N | N | N | N | N | Y | Y | Y | NR | 4.54^**^
Rinker et al.(121) | 2008 | N | N | N | N | Y | Y | NR | Y | Y | Y | 4.54
Simek et al.(123) | 2008 | N | N | N | N | Y | Y | Y | Y | Y | NR | 4.09^**^
Armstrong et al.(109) | 2007 | N | N | Y | N | Y | Y | Y | Y | Y | N | 7.95^*^
Denzinger et al.(135) | 2007 | N | NR | NR | N | NR | NR | Y | Y | Y | Y | 4.50
Lavery et al.(341) | 2007 | N | NR | NR | N | NR | NR | Y | NR | NR | N | 3.18^*^
Moues et al.(136) | 2007 | N | N | N | N | Y | Y | Y | Y | Y | N | 5.68^*^
Siegel et al.(119) | 2007 | N | NR | NR | N | NR | NR | NR | Y | Y | NR | 2.95^**^
Braakenburg et al.(114) | 2006 | N | N | N | N | Y | Y | Y | N | N | N | 6.4^*^
Huang et al.(127) | 2006 | N | NR | NR | N | NR | NR | NR | NR | NR | NR | 3.86^**^
Stannard et al.(125) | 2006 | N | N | N | N | Y | Y | Y | Y | Y | N | 5.45^*^
Vuerstaek et al.(115) | 2006 | N | N | N | N | Y | Y | Y | N | Y | NR | 7.04^**^
Yang et al.(72) | 2006 | N | N | N | N | NR | NR | NR | Y | Y | NR | 3.41^**^
Bickels et al.(134) | 2005 | N | N | N | N | NR | NR | NR | Y | Y | Y | 3.63
Fuchs et al.(23) | 2005 | N | N | N | N | Y | Y | Y | Y | Y | NR | 4.32^**^
Immer et al.(130) | 2005 | N | N | N | N | Y | Y | N | Y | Y | NR | 2.95^**^
Schwien et al.(126) | 2005 | N | NR | NR | N | NR | NR | NR | NR | NR | N | 3.18^*^
Segers et al.(122) | 2005 | N | N | N | N | Y | Y | Y | N | N | NR | 2.27^**^
Sjogren et al.(139) | 2005 | N | N | N | N | Y | Y | N | Y | Y | Y | 4.09
Vidrine et al.(342) | 2005 | N | N | N | N | Y | Y | Y | Y | Y | NR | 5.0^**^
Kamolz et al.(343) | 2004 | N | N | NR | NR | Y | Y | Y | Y | Y | NR | 5.45^**^
Labler et al.(71) | 2004 | N | N | NR | N | Y | Y | N | Y | Y | NR | 3.41^**^
Moisidis et al.(112) | 2004 | N | N | Y | N | N | N | Y | Y | Y | NR | 6.59^**^
Page et al.(1,112) | 2004 | NR | NR | NR | N | NR | NR | N | Y | Y | NR | 3.86^**^
Stone et al.(133) | 2004 | N | N | N | N | Y | NR | NR | Y | Y | NR | 4.09^**^
Shilt et al.(138) | 2004 | N | N | NR | N | N | Y | Y | Y | Y | Y | 4.32
Domkowski et al.(139) | 2003 | N | N | N | N | Y | Y | NR | NR | NR | NR | 3.18^**^
Song et al.(124) | 2003 | N | N | N | N | Y | Y | Y | Y | Y | Y | 5.00
Wanner et al.(118) | 2003 | N | NR | N | N | Y | Y | Y | Y | Y | NR | 4.77^**^
Doss et al.(128) | 2002 | N | N | N | N | N | NR | NR | NR | NR | NR | 2.72^**^
Ford et al.(110) | 2002 | N | NR | Y | NR | Y | Y | Y | Y | NR | N | 7.27^*^
Scherer et al.(132) | 2002 | N | N | N | N | Y | NR | Y | Y | Y | NR | 3.63^**^
Catarino et al.(137) | 2000 | N | N | N | N | Y | Y | Y | Y | Y | NR | 4.09^**^
Joseph et al.(113) | 2000 | N | N | Y | N | Y | Y | Y | Y | Y | NR | 6.6^**^
McCallon et al.(120) | 2000 | N | N | NR | N | Y | Y | Y | Y | Y | N | 5.68^*^
Genecov et al.(131) | 1998 | N | N | Y | N | Y | Y | Y | N | Y | Y | 5.45
Percent of “Y” Responses | | 0 | 0 | 12 | 0 | 65 | 65 | 65 | 77 | 82 | 20
Median Score | | | | | | | | | | | | 4.32

† Based on “change in wound area/volume” as the reference outcome

* Fully or partially funded by KCI

** Conflict of interest not reported

Table 15b Answers to Quality Assessment of a Controlled Study Comparing NPWT to a Redon Bottle^†^

Studies | Year | Q1 | Q2 | Q3 | Q4 | Q5 | Q6 | Q7 | Q8 | Q9 | Q10 | Q11 | Q12
Wild et al.(116) | 2008 | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y | NR

Table 15c Answers to Quality Assessment of a Controlled Study Comparing NPWT to a Redon Bottle^†^

Studies | Year | Q13 | Q14 | Q15 | Q16 | Q17 | Q18 | Q19 | Q20 | Q21 | Q22 | Overall Score
Wild et al.(116) | 2008 | N | NR | Y | N | Y | Y | Y | Y | Y | Y | 8.64

† Based on “change in wound area/volume” as the reference outcome