# Abbreviations and Acronyms

ABI: Ankle brachial index
AF: Atrial fibrillation
AMWT: Advanced moist wound therapy
AS: Aortic stenosis
BMI: Body mass index
CA: Can’t answer
CABG: Coronary artery bypass surgery
CAD: Coronary artery disease
CAS: Carotid artery stenosis
CC: Cubic centimeter
CHF: Congestive heart failure
CD: Coronary disease
CDI: Closed drainage and irrigation
CDT: Closed drainage technique
CHD: Coronary heart disease
CHF: Congestive heart failure
CI: Confidence interval
CKD: Chronic kidney disease
CLD: Chronic lung disease
CM: Centimeter
CNP: Continuous negative pressure
COPD: Chronic obstructive pulmonary disorder
CRF: Chronic renal failure
D: Day(s)
DED: De-epidermalized dermis
DFU: Diabetic foot ulcer
DM: Diabetes mellitus
DSWI: Deep sternal wound infection
EQ-5D: EuroQol 5 Dimensions Index
ESRD: End stage renal disease
ESRF: End stage renal failure
F: Female
F/U: Follow-up
gm/dl: Grams per deciliter
HF: Heart failure
HP: Healthpoint System
ICG: Indocyanine Green
IDDM: Insulin dependent diabetes mellitus
IHD: Ischaemic heart disease
IQR: Interquartile range
ISS: Injury Severity Score
L: Length
LOS: Length of hospital stay
LVEF: Left ventricular ejection fraction
M: Male
mg/l: Milligram per liter
MI: Myocardial infarction
ml: Milliliter
mmHg: Millimeters of mercury
MRI: Magnetic resonance imaging
MW: Moist to wet
NA: Not applicable
NIDDM: Non insulin dependent diabetes mellitus
NPIT: Negative pressure instillation therapy
NPWT: Negative pressure wound therapy
NR: Not reported
NS: Not significant
OR: Operating room
PA: Peripheral arteriopathy
PAD: Peripheral arterial disease
PAOD: Peripheral artery occlusive disease
PM: Post-sternotomy mediastinitis
PPI: Present pain intensity
PU: Polyurethane
PVA: Polyvinyl alcohol
PVD: Peripheral vascular disease
QOL: Quality of life
RCT: Randomized controlled trial
RD: Renal disease
RF: Renal failure
ROCF: Reticulated open cell foam
RR: Risk ratio
SF-36: Short Form 36
SF-MPQ: Short Form-McGill Pain Questionnaire
SIGN: Scottish Intercollegiate Guideline Network
SOC: Standard of care
SOM: Post-sternotomy osteomyelitis
SR: Systematic review
SSD: Silver sulphadiazine crème
SSI: Surgical site infection
STSG: Split thickness skin graft
SWT: Standard wound therapy
TNP: Topical negative pressure
TPN: Total parenteral nutrition
um: Micrometer
VAC: Vacuum-assisted closure
VAS: Visual analogue scale
W: Width
WDS: Wounds
WM: Wet to moist
WMD: Weighted mean differences