# List of devices names*

ActiV.A.C.® Therapy Unit

Engenex® Advanced NPWT System

Exusdex® wound drainage pump

EZCARE Negative Pressure Wound Therapy

InfoV.A.C.® Therapy Unit

Invia Liberty Wound Therapy

Invia Vario 18 c/i Wound Therapy

Mini V.A.C.®

NPD 1000 Negative Pressure Wound Therapy System

Prodigy™ NPWT System (PMS-800 and PMS-800V)

PRO-I™

PRO-II™

PRO-III™

RENASYS™ EZ Negative Pressure Wound Therapy

SVEDMAN™ and SVED™ Wound Treatment Systems

V.A.C.® ATS™

V.A.C.® Freedom™

V.A.C.® Instill Device

V.A.C.® Therapy Unit

V.A.C.® (Vacuum Assisted Closure™)

V1STA Negative Pressure Wound Therapy

Venturi™ Negative Pressure Wound Therapy

* These devices have U.S. Food and Drug Administration 510(k) clearance for marketing in the United States.