# Peer Reviewers

We wish to acknowledge individuals listed below for their review of this report. This report has been reviewed in draft form by individuals chosen for their expertise and diverse perspectives. The purpose of the review was to provide candid, objective, and critical comments for consideration by the EPC in preparation of the final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.

- Katherine R. Jones, RN, Ph.D.
  Sarah Cole Hirsh Professor Associate Dean for Evidence-based Practice
  Case Western Reserve University
  Bolton School of Nursing
  Cleveland, Ohio
- David Margolis, MD PhD
  Professor of Dermatology and Epidemiology
  University of Pennsylvania
  Philadelphia, Pennsylvania
- Gerit Mulder, DPM, MS, APWCA
  Director, Wound Treatment and Research Center at the Regional Burn Center
  University of California San Diego
  San Diego, California
- Catherine Ratliff
  PhD, APRN-BC
  University of Virginia
  Charlottesville, Virginia