# Refernces

1 Page JC, Newswander B, Schwenke DC, Hansen M, Ferguson J. Retrospective analysis of negative pressure wound therapy in open foot wounds with significant soft tissue defects. Adv Skin Wound Care. Sep. 2004;17(7):354-364. [pmid: 15343085].
2 Lazarus GS, Cooper DM, Knighton DR, Margolis DJ, Pecoraro RE, Rodeheaver G, Robson MC. Definitions and guidelines for assessment of wounds and evaluation of healing. Arch Dermatol. Apr. 1994;130(4):489-493. [pmid: 8166487].
3 Laing P. Diabetic foot ulcers. Am J Surg. Jan. 1994;167(1A):31S-36S. [pmid: 8109682].
4 Stillman RM. Diabetic ulcers. eMedicine [database online]. Omaha (NE). eMedicine.com, Inc. accessed 2005 Sep 7. 1996:25. [updated 2005 Mar 22]. Available: http://www.emedicine.com/med/topic551.htm.
5 Frykberg RG, Armstrong DG, Giurini J, Edwards A, Kravette M, Kravitz S, Ross C, Stavosky J, Stuck R, Vanore J. Diabetic foot disorders: a clinical practice guideline. American College of Foot and Ankle Surgeons. J Foot Ankle Surg. 2000;39(5 Suppl):S1-S60. [pmid: 11280471].
6 Lavery LA, Armstrong DG, Harkless LB. Classification of diabetic foot wounds [internet]. North Miami Beach (FL). Wound Care Institute. accessed 2005 Sep 7. 1991:11. Available: http://www.woundcare.org/newsvol2n2/ulcer2.htm.
7 Stadelmann WK, Digenis AG, Tobin GR. Physiology and healing dynamics of chronic cutaneous wounds. Am J Surg. Aug. 1998;176(2A Suppl):26S-38S. [pmid: 9777970].
8 de Leon J. Negative pressure wound therapy in pressure ulcer management. Ostomy Wound Manage. Feb. 2005;51(2A Suppl):3-8. [pmid: 15699557].
9 Folkedahl BA, Frantz R. Treatment of pressure ulcers. Iowa City (IA). University of Iowa Gerontological Nursing Interventions Research Center, Research Dissemination Core. Aug. 2002:30.
10 Gupta S, Baharestani M, Baranoski S, de Leon J, Engel SJ, Mendez-Eastman S, Niezgoda JA, Pompeo MQ. Guidelines for managing pressure ulcers with negative pressure wound therapy. Adv Skin Wound Care. Nov-Dec. 2004;17(Suppl 2):1-16. [pmid: 15716646].
11 Smith DM. Pressure ulcers in the nursing home. Ann Intern Med. Sep. 15. 1995;123(6):433-442. [pmid: 7639444].
12 Pressure ulcer stages revised by NPUAP [internet]. Washington (DC). National Pressure Ulcer Advisory Panel (NPUAP). accessed 2008 Apr 25. 2007:2. Available: http://www.npuap.org/print.htm.
13 Ankrom MA, Bennett RG, Sprigle S, Langemo D, Black JM, Berlowitz DR, Lyder CH. National Pressure Ulcer Advisory Panel. Pressure-related deep tissue injury under intact skin and the current pressure ulcer staging systems. Adv Skin Wound Care. Jan-Feb. 2005;18(1):35-42. [pmid: 15714036].
14 Sieggreen MY, Kline RA. Recognizing and managing venous leg ulcers. Adv Skin Wound Care. Jul-Aug. 2004;17(6):302-311. quiz 312-3. [pmid: 15289718].
15 Moffatt CJ, Dorman MC. Recurrence of leg ulcers within a community ulcer service. J Wound Care. Feb. 1995;4(2):57-61. [pmid: 7600337].
16 Barr DM. The Unna's boot as a treatment for venous ulcers. Nurse Pract. Jul. 1996;21(7):55-56. 61. 64. 71. 72. passim. [pmid: 8823788].
17 Goodfield M. Optimal management of chronic leg ulcers in the elderly. Drugs Aging. May. 1997;10(5):341-348. [pmid: 9143855].
18 Falanga V, Eaglstein WH. A therapeutic approach to venous ulcers. J Am Acad Dermatol. May. 1986;14(5 Pt 1):777-784. [pmid: 3519695].
19 O’Meara S, Cullum NA, Nelson EA. Compression for venous leg ulcers (Review). Cochrane Database of Systematic Reviews [internet]. Hoboken (NJ). John Wiley & Sons, Ltd. accessed 2009 May 15. 2009;(Issue 1):CD000265. [doi: 10.1002/14651858.CD000265.pub2.].
20 Orgill DP. Advancing the treatment options of chest wounds with negative pressure wound therapy. Ostomy Wound Manage. Feb. 2005;51(2A Suppl):39-43. [pmid: 15699564].
21 Orgill DP, Austen WG Jr, Butler CE, Fine NA, Horvath KA, Mihaljevic T, Song DH, Wolfe WG. Guidelines for the treatment of complex chest wounds with negative pressure wound therapy. Wounds. Dec. 2004;(Suppl B):1-23.
22 Dacey MJ. Mediastinitis. eMedicine [database online]. Omaha (NE). eMedicine.com, Inc. accessed 2005 Sep 8. 1996:17. [updated 2004 Feb 19]. Available: http://www.emedicine.com/med/topic2798.htm.
23 Fuchs U, Zittermann A, Stuettgen B, Groening A, Minami K, Koerfer R. Clinical outcome of patients with deep sternal wound infection managed by vacuum-assisted closure compared to conventional therapy with open packing: a retrospective analysis. Ann Thorac Surg. Feb. 2005;79(2):526-531. [pmid: 15680828].
24 Schwarz K, Dulchavsky S, Lopez FA, Talavera F, Sanders CV, Mylonakis E, Cunha BA. Burn wound infections. [internet]. Omaha (NE). WebMD. Jan. 24. accessed 2008 Apr 11. 2005:12. Available: http://www.emedicine.com/med/TOPIC258.HTM.
25 Kanakaris NK, Thanasas C, Keramaris N, Kontakis G, Granick MS, Giannoudis PV. The efficacy of negative pressure wound therapy in the management of lower extremity trauma: Review of clinical evidence. Injury. 2007;38:S8-S10. S11. S17. [pmid: 18045598].
26 Ingari JV, Powell E. Civilian and detainee orthopaedic surgical care at an Air Force Theater Hospital. Tech Hand Up Extrem Surg. Jan. 2007;11(2):130-134. [pmid: 17549017].
27 Dedmond BT, Kortesis B, Punger K, Simpson J, Argenta J, Kulp B, Morykwas M, Webb LX. The use of negative-pressure wound therapy (NPWT) in the temporary treatment of soft-tissue injuries associated with high-energy open tibial shaft fractures. J Orthop Trauma. Jan. 2007;21(1):11-17. [pmid: 17211263].
28 Stillman RM. Wound care. eMedicine [database online]. Omaha (NE). eMedicine.com, Inc. accessed 2009 May 18. 1996:28. [updated 2008 Aug 19]. Available: http://emedicine.medscape.com/article/194018-print.
29 Brett D. A review of collagen and collagen-based wound dressings. [internet]. St. Petersburg (FL). Smith & Nephew Inc. Dec. 12. 2008:3. Available: http://www.woundsresearch.com/.
30 Martin P. Wound healing--aiming for perfect skin regeneration. Science. Apr. 4. 1997;276(5309):75-81. [pmid: 9082989].
31 Hanna JR, Giacopelli JA. A review of wound healing and wound dressing products. J Foot Ankle Surg. Jan-Feb. 1997;36(1):2-14. discussion 79. [pmid: 9031020].
32 Willy C, editor. The theory and practice of vacuum therapy. Scientific basis, indications for use, case reports, practical advice. Ulm,Germany. Lindqvist book publishing. 2006:405.
33 Morykwas MJ, Argenta LC, Shelton-Brown EI, McGuirt W. Vacuum-assisted closure: a new method for wound control and treatment: animal studies and basic foundation. Ann Plast Surg. Jun. 1997;38(6):553-562. [pmid: 9188970].
34 Saxena V, Hwang CW, Huang S, Eichbaum Q, Ingber D, Orgill DP. Vacuum-assisted closure: microdeformations of wounds and cell proliferation. Plast Reconstr Surg. Oct. 2004;114(5):1086-1096. discussion 1097-. [pmid: 15457017].
35 Scherer SS, Pietramaggiori G, Mathews JC, Prsa MJ, Huang S, Orgill DP. The mechanism of action of the vacuum-assisted closure device. Plast Reconstr Surg. Sep. 2008;122(3):786-797. [pmid: 18766042].
36 Morykwas MJ, Faler BJ, Pearce DJ, Argenta LC. Effects of varying levels of subatmospheric pressure on the rate of granulation tissue formation in experimental wounds in swine. Ann Plast Surg. Nov. 2001;47(5):547-551. [pmid: 11716268].
37 Weed T, Ratliff C, Drake DB. Quantifying bacterial bioburden during negative pressure wound therapy: does the wound VAC enhance bacterial clearance. Ann Plast Surg. Mar. 2004;52(3):276-279. discussion 279-80. [pmid: 15156981].
38 Moues CM, Vos MC, van den Bemd GJ, Stijnen T, Hovius SE. Bacterial load in relation to vacuum-assisted closure wound therapy: a prospective randomized trial. Wound Repair Regen. Jan-Feb. 2004;12(1):11-17. [pmid: 14974959].
39 Ichioka S, Watanabe H, Sekiya N, Shibata M, Nakatsuka T. A technique to visualize wound bed microcirculation and the acute effect of negative pressure. Wound Repair Regen. 2008;16:460-465. [pmid: 18471264].
40 Wackenfors A, Sjogren J, Gustafsson R, Algotsson L, Ingemansson R, Malmsjo M. Effects of vacuum-assisted closure therapy on inguinal wound edge microvascular blood flow. Wound Repair Regen. Nov-Dec. 2004;12(6):600-606. [pmid: 15555050].
41 Paul JC. Vacuum assisted closure therapy: a must in plastic surgery. Plast Surg Nurs. April/June. 2005;25(2):61-65. [pmid: 15983495].
42 Ethicon wound closure manual [Book part online]. Restoring wounded tissue. Ethicon, Inc. accessed 2000 Jan 26. 1998:11. Available: http://www.ethiconinc.com.
43 Ovington LG. Hanging wet-to-dry dressings out to dry. Adv Wound Care. Mar-Apr. 2002;15(2):79-86.
44 Ovington LG. Advances in wound dressings. Clin Dermatol. Jan-Feb. 2007;25(1):33-38. [pmid: 17276199].
45 Ovington LG. The well-dressed wound: an overview of dressing types. Wounds. Jan-Feb. Suppl A. 1998;10:1A-9A.
46 Kannon GA, Garrett AB. Moist wound healing with occlusive dressings a clinical review. Dermatol Surg. Jul. 1995;21(7):583-590. [pmid: 7606367].
47 Hansson C. Interactive wound dressings a practical guide to their use in older patients. Drugs Aging. Oct. 1997;11(4):271-284. [pmid: 9342557].
48 O'Meara S, Al-Kurdi D, Ovington LG. Antibiotics and antiseptics for venous leg ulcers. Cochrane Database of Systematic Reviews [internet]. Hoboken (NJ). John Wiley & Sons, Ltd. accessed 2008 Apr 18. 2008;(Issue 1):CD003557. [doi: 10.1002/14651858.CD003557.pub2.].
49 Singhal H, Kaur K, Zammit C. Wound infection. eMedicine [database online]. Omaha (NE). eMedicine.com, Inc. accessed 2009 May 18. 1996:20. [updated 2008 Aug 21]. Available: http://emedicine.medscape.com/article/188988-print.
50 Fong J, Wood F. Nanocrystalline silver dressings in wound management: a review. Int J Nanomedicine. 2006;1(4):441-449. [pmid: 17722278].
51 White RJ, Cutting KF. Critical colonization--the concept under scrutiny. Ostomy Wound Manage. Nov. 2006;52(11):50-56. [pmid: 17146118].
52 Cutting KF, White RJ. Criteria for identifying wound infection--revisited. Ostomy Wound Manage. Jan. 2005;51(1):28-34. [pmid: 15695833].
53 Edwards R, Harding KG. Bacteria and wound healing. Curr Opin Infect Dis. Apr. 2004;17(2):91-96. [pmid: 15021046].
54 Ovington LG. The truth about silver. Ostomy Wound Manage. Sep. 2004;50(9A Suppl):1S-10S. [pmid: 15499162].
55 Reitsma AM, Rodeheaver GT. Effectiveness of a new antimicrobial gauze dressing as a bacterial barrier. Mansfield (MA). Tyco Healthcare. 2001. Sep. 4.
56 ECRI. Occlusive dressings for the treatment of chronic wounds [Technology assessment report]. Plymouth Meeting (PA). ECRI, Health Technology Assessment Information Service. Feb. 2000:141.
57 Gentzkow GD, Iwasaki SD, Hershon KS, Mengel M, Prendergast JJ, Ricotta JJ, Steed DP, Lipkin S. Use of dermagraft, a cultured human dermis, to treat diabetic foot ulcers. Diabetes Care. Apr. 1996;19(4):350-354. [pmid: 8729158].
58 Sabolinski ML, Alvarez O, Auletta M, Mulder G, Parenteau NL. Cultured skin as a 'smart material' for healing wounds: experience in venous ulcers. Biomaterials. Feb. 1996;17(3):311-320. [pmid: 8745328].
59 Shores JT, Gabriel A, Gupta S. Skin substitutes and alternatives: a review. Adv Skin Wound Care. Sep. 2007;20(9 Pt 1):493-508. quiz 509-10. [pmid: 17762218].
60 van Winterswijk P, Nout E. Tissue engineering and wound healing: an overview of the past, present, and future [internet]. New York (NY). Medscape. Dec. 05. 2007:10. Available: http://www.medscape.com.
61 Center for Biologics Evaluation and Research (CBER). Guidance for industry: chronic cutaneous ulcer and burn wounds — developing products for treatment. Rockville (MD). U.S. Food and Drug Administration, Center for Drug Evaluation and Research. Jun. 2006:22. Also available: http://www.fda.gov/cder/guidance/index.htm#clinical%20medicine.
62 Hackam DG, Redelmeier DA. Translation of research evidence from animals to humans. JAMA. Oct. 11. 2006;296(14):1731-1732. [pmid: 17032985].
63 Hackam DG. Translating animal research into clinical benefit. BMJ. Jan. 27. 2007;334(7586):163-164. [pmid: 17255568].
64 Perel P, Roberts I, Sena E, Wheble P, Briscoe C, Sandercock P, Macleod M, Mignini LE, Jayaram P, Khan KS. Comparison of treatment effects between animal experiments and clinical trials: systematic review. BMJ. Jan. 27. 2007;334(7586):197-200. [pmid: 17175568].
65 Moher D, Pham B, Klassen TP, Schulz KF, Berlin JA, Jadad AR, Liberati A. What contributions do languages other than English make on the results of meta-analyses?. J Clin Epidemiol. Sep. 2000;53(9):964-972. [pmid: 11004423].
66 Juni P, Holenstein F, Sterne J, Bartlett C, Egger M. Direction and impact of language bias in meta-analyses of controlled trials: empirical study. Int J Epidemiol. Feb. 2002;31(1):115-123. [pmid: 11914306].
67 Narine L, Yee DS, Einarson TR, Ilersich AL. Quality of abstracts of original research articles in CMAJ in 1989. CMAJ. Feb. 15. 1991;144(4):449-453. [pmid: 1993292].
68 Pitkin RM, Branagan MA, Burmeister LF. Accuracy of data in abstracts of published research articles. JAMA. Mar. 24-31. 1999;281(12):1110-1111. [pmid: 10188662].
69 Taddio A, Pain T, Fassos FF, Boon H, Ilersich AL, Einarson TR. Quality of nonstructured and structured abstracts of original research articles in the British Medical Journal, the Canadian Medical Association Journal and the Journal of the American Medical Association. CMAJ. May. 15. 1994;150(10):1611-1615. [pmid: 8174031].
70 Noble-Bell G, Forbes A. A systematic review of the effectiveness of negative pressure wound therapy in the management of diabetes foot ulcers. Int Wound J. Jun. 2008;5(2):233-242. [pmid: 18494629].
71 Labler L, Keel M, Trentz O. Vacuum-assisted closure (VAC) for temporary coverage of soft-tissue injury in type III open fracture of lower extremities. Eur J Trauma. 2004;30(5):305-312.
72 Yang CC, Chang DS, Webb LX. Vacuum-assisted closure for fasciotomy wounds following compartment syndrome of the leg. J Surg Orthop Adv. Spring. 2006;15(1):19-23. [pmid: 16603108].
73 Kotsis T, Lioupis C. Use of vacuum assisted closure in vascular graft infection confined to the groin. Acta Chir Belg. Jan-Feb. 2007;107(1):37-44. [pmid: 17405596].
74 Machen MS. Management of traumatic war wounds using vacuum-assisted closure dressings in an austere environment. Army Med Dept J. Jan-Mar. 2007:17-23.
75 Wongworawat MD, Schnall SB, Holtom PD, Moon C, Schiller F. Negative pressure dressings as an alternative technique for the treatment of infected wounds. Clin Orthop Relat Res. Sep. 2003;(414):45-48. [pmid: 12966275].
76 Bendo JA, Quirno M, Pelham F, Barone JA, Awad J. Posterior lumbar wound drainage management with vacuum-assisted closure. World Spine J. Sep. 2007;2(4):187-190.
77 Stonerock CE, Bynoe RP, Yost MJ, Nottingham JM. Use of a vacuum-assisted device to facilitate abdominal closure. Am Surg. Dec. 2003;69(12):1030-1034. discussion 1034-5. [pmid: 14700286].
78 Horn PL, Ruth B, Kean JR. Use of wound V.A.C. therapy in pediatric patients with infected spinal wounds: a retrospective review. Orthop Nurs. Sep-Oct. 2007;26(5):317-322. quiz 323-4. [pmid: 17921893].
79 Mooney JF 3rd, Argenta LC, Marks MW, Morykwas MJ, DeFranzo AJ. Treatment of soft tissue defects in pediatric patients using the V.A.C. system. Clin Orthop Relat Res. Jul. 2000;(376):26-31. [pmid: 10906854].
80 Ploumis A, Mehbod AA, Dressel TD, Dykes DC, Transfeldt EE, Lonstein JE. Therapy of spinal wound infections using vacuum-assisted wound closure: risk factors leading to resistance to treatment. J Spinal Disord Tech. Jul. 2008;21(5):320-323. [pmid: 18600140].
81 Scholl L, Chang E, Reitz B, Chang J. Sternal osteomyelitis: use of vacuum-assisted closure device as an adjunct to definitive closure with sternectomy and muscle flap reconstruction. J Card Surg. Sep-Oct. 2004;19(5):453-461. [pmid: 15383060].
82 Bendewald FP, Cima RR, Metcalf DR, Hassan I. Using negative pressure wound therapy following surgery for complex pilonidal disease: a case series. Ostomy Wound Manage. May. 2007;53(5):40-46. [pmid: 17551174].
83 Ferron G, Garrido I, Martel P, Gesson-Paute A, Classe JM, Letourneur B, Querleu D. Combined laparoscopically harvested omental flap with meshed skin grafts and vacuum-assisted closure for reconstruction of complex chest wall defects. Ann Plast Surg. Feb. 2007;58(2):150-155. [pmid: 17245140].
84 Campbell PE, Smith GS, Smith JM. Retrospective clinical evaluation of gauze-based negative pressure wound therapy. Int Wound J. Jun. 2008;5(2):280-286. [pmid: 18494633].
85 Armstrong DG, Lavery LA, Abu-Rumman P, Espensen EH, Vazquez JR, Nixon BP, Boulton AJ. Outcomes of subatmospheric pressure dressing therapy on wounds of the diabetic foot. Ostomy Wound Manage. Apr. 2002;48(4):64-68. [pmid: 11993062].
86 Garner GB, Ware DN, Cocanour CS, Duke JH, McKinley BA, Kozar RA, Moore FA. Vacuum-assisted wound closure provides early fascial reapproximation in trauma patients with open abdomens. Am J Surg. Dec. 2001;182(6):630-638. [pmid: 11839329].
87 Heller L, Levin SL, Butler CE. Management of abdominal wound dehiscence using vacuum assisted closure in patients with compromised healing. Am J Surg. Feb. 2006;191(2):165-172. [pmid: 16442940].
88 Andrews BT, Smith RB, Goldstein DP, Funk GF. Management of complicated head and neck wounds with vacuum-assisted closure system. Head Neck. Nov. 2006;28(11):974-981. [pmid: 16983694].
89 Rosenthal EL, Blackwell KE, McGrew B, Carroll WR, Peters GE. Use of negative pressure dressings in head and neck reconstruction. Head Neck. Nov. 2005;27(11):970-975. [pmid: 16127668].
90 Stone PA, Hass SM, Flaherty SK, DeLuca JA, Lucente FC, Kusminsky RE. Vacuum-assisted fascial closure for patients with abdominal trauma. J Trauma. Nov. 2004;57(5):1082-1086. [pmid: 15580036].
91 Isago T, Nozaki M, Kikuchi Y, Honda T, Nakazawa H. Negative-pressure dressings in the treatment of pressure ulcers. J Dermatol. Apr. 2003;30(4):299-305. [pmid: 12707466].
92 Avery C, Pereira J, Moody A, Gargiulo M, Whitworth I. Negative pressure wound dressing of the radial forearm donor site. Int J Oral Maxillofac Surg. Jun. 2000;29(3):198-200. [pmid: 10970082].
93 Baharestani MM. Negative pressure wound therapy in the adjunctive management of necrotizing fascitis: examining clinical outcomes. Ostomy Wound Manage. Apr. 2008;54(4):44-50. [pmid: 18480505].
94 Hersh RE, Jack JM, Dahman MI, Morgan RF, Drake DB. The vacuum-assisted closure device as a bridge to sternal wound closure. Ann Plast Surg. Mar. 2001;46(3):250-254. [pmid: 11293515].
95 Perez D, Wildi S, Demartines N, Bramkamp M, Koehler C, Clavien PA. Prospective evaluation of vacuum-assisted closure in abdominal compartment syndrome and severe abdominal sepsis. J Am Coll Surg. Oct. 2007;205(4):586-592. [pmid: 17903734].
96 Clinical in-market evaluation interim report. Hull, United Kingdom. Smith & Nephew Medical, Ltd. Feb. 2. 2009:30.
97 Higgins JP, Thompson SG, Deeks JJ, Altman DG. Measuring inconsistency in meta-analyses. BMJ. Sep. 6. 2003;327(7414):557-560. [pmid: 12958120].
98 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. Jun. 15. 2002;21(11):1539-1558. [pmid: 12111919].
99 Higgins JP, Thompson SG. Controlling the risk of spurious findings from meta-regression. Stat Med. Jun. 15. 2004;23(11):1663-1682. [pmid: 15160401].
100 Agency for Healthcare Research and Quality (AHRQ). Methods reference guide for effectiveness and comparative effectiveness reviews, Version 1.0. [Draft posted Oct. 2007]. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). 128. Also available: http://effectivehealthcare.ahrq.gov/repFiles/2007_10DraftMethodsGuide.pdf.
101 Fu R, Gartlehner G, Grant M, Shamalyan T, Sedrakyan A, Wilt T, Griffith L, Oremus M, Raina P, Ismaila A, Santaguida L, Lau J, Trikalinos T. Conducting quantitative synthesis when comparing medical interventions: AHRQ and the effective healthcare program [unpublished]. 55.
102 Glenny AM, Altman DG, Song F, Sakarovitch C, Deeks JJ, D'Amico R, Bradburn M, Eastwood AJ. International Stroke Trial Collaborative Group. Indirect comparisons of competing interventions. Health Technol Assess. Jul. 2005;9(26):1-134. iii. iv. [pmid: 16014203].
103 Chou R, Fu R, Huffman LH, Korthuis PT. Initial highly-active antiretroviral therapy with a protease inhibitor versus a non-nucleoside reverse transcriptase inhibitor: discrepancies between direct and indirect meta-analyses. Lancet. Oct. 28. 2006;368(9546):1503-1515. [pmid: 17071284].
104 Song F, Altman DG, Glenny AM, Deeks JJ. Validity of indirect comparison for estimating efficacy of competing interventions: empirical evidence from published meta-analyses. BMJ. Mar. 1. 2003;326(7387):472. [pmid: 12609941].
105 Bucher HC, Guyatt GH, Griffith LE, Walter SD. The results of direct and indirect treatment comparisons in meta-analysis of randomized controlled trials. J Clin Epidemiol. Jun. 1997;50(6):683-691. [pmid: 9250266].
106 Timmers MS, Graafland N, Bernards AT, Nelissen RGHH, Van Dissel JT, Jukema GN. Negative pressure wound treatment with polyvinyl alcohol foam and polyhexanide antiseptic solution instillation in posttraumatic osteomyelitis. Wound Repair Regen. Mar-Apr. 2009;17(2):278-286. [pmid: 19320897].
107 Van Den Boogaard M, De Laat E, Spauwen P, Schoonhoven L. The effectiveness of topical negative pressure in the treatment of pressure ulcers: A literature review. Eur J Plastic Surg. Apr. 2008;31(1):1-7.
108 Blume PA, Walters J, Payne W, Ayala J, Lantis J. Comparison of negative pressure wound therapy using vacuum-assisted closure with advanced moist wound therapy in the treatment of diabetic foot ulcers: a multicenter randomized controlled trial. Diabetes Care. Apr. 2008;31(4):631-636. [pmid: 18162494].
109 Armstrong DG, Lavery LA, Boulton AJ. Negative pressure wound therapy via vacuum-assisted closure following partial foot amputation: what is the role of wound chronicity?. Int Wound J. Mar. 2007;4(1):79-86. [pmid: 17425550].
110 Ford CN, Reinhard ER, Yeh D, Syrek D, De Las Morenas A, Bergman SB, Williams S, Hamori CA. Interim analysis of a prospective, randomized trial of vacuum-assisted closure versus the Healthpoint system in the management of pressure ulcers. Ann Plast Surg. Jul. 2002;49(1):55-61. discussion 61. [pmid: 12142596].
111 Leininger BE, Rasmussen TE, Smith DL, Jenkins DH, Coppola C. Experience with wound VAC and delayed primary closure of contaminated soft tissue injuries in Iraq. J Trauma. Nov. 2006;61(5):1207-1211. [pmid: 17099530].
112 Moisidis E, Heath T, Boorer C, Ho K, Deva AK. A prospective, blinded, randomized, controlled clinical trial of topical negative pressure use in skin grafting. Plast Reconstr Surg. Sep. 15. 2004;114(4):917-922. [pmid: 15468399].
113 Joseph E, Hamori CA, Bergman S, Roaf E, Swann NF, Anastasi GW. A prospective, randomized trial of vacuum-assisted closure versus standard therapy of chronic non-healing wounds. Wounds. 2000;12(3):60-67. Also available: http://www.medscape.com/viewarticle/407550_print.
114 Braakenburg A, Obdeijn MC, Feitz R, van Rooij IA, van Griethuysen AJ, Klinkenbijl JH. The clinical efficacy and cost effectiveness of the vacuum-assisted closure technique in the management of acute and chronic wounds: a randomized controlled trial. Plast Reconstr Surg. Aug. 2006;118(2):390-397. discussion 398-400. [pmid: 16874208].
115 Vuerstaek JD, Vainas T, Wuite J, Nelemans P, Neumann MH, Veraart JC. State-of-the-art treatment of chronic leg ulcers: A randomized controlled trial comparing vacuum-assisted closure (V.A.C.) with modern wound dressings. J Vasc Surg. Nov. 2006;44(5):1029-1037. discussion 1038. [pmid: 17000077].
116 Wild T, Stremitzer S, Budzanowski A, Hoelzenbein T, Ludwig C, Ohrenberger G. Definition of efficiency in vacuum therapy--a randomised controlled trial comparing with V.A.C. Therapy. Int Wound J. Dec. 2008;5(5):641-647. [pmid: 19134065].
117 Ozturk E, Ozguc H, Yilmazlar T. The use of vacuum assisted closure therapy in the management of Fournier's gangrene. Am J Surg. 2008. Sep. 11. [pmid: 18789410].
118 Wanner MB, Schwarzl F, Strub B, Zaech GA, Pierer G. Vacuum-assisted wound closure for cheaper and more comfortable healing of pressure sores: a prospective study. Scand J Plast Reconstr Surg Hand Surg. 2003;37(1):28-33. [pmid: 12625392].
119 Siegel HJ, Long JL, Watson KM, Fiveash JB. Vacuum-assisted closure for radiation-associated wound complications. J Surg Oncol. Dec. 1. 2007;96(7):575-582. [pmid: 17999398].
120 McCallon SK, Knight CA, Valiulus JP, Cunningham MW, McCulloch JM, Farinas LP. Vacuum-assisted closure versus saline-moistened gauze in the healing of postoperative diabetic foot wounds. Ostomy Wound Manage. Aug. 2000;46(8):28-32. 34. [pmid: 11189545].
121 Rinker B, Amspacher JC, Wilson PC, Vasconez HC. Subatmospheric pressure dressing as a bridge to free tissue transfer in the treatment of open tibia fractures. Plast Reconstr Surg. May. 2008;121(5):1664-1673. [pmid: 18453991].
122 Segers P, De Jong AP, Kloek JJ, De Mol BAJM. Poststernotomy mediastinitis: Comparison of two treatment modalities. Interact Cardiovasc Thorac Surg. Dec. 1. 2005;4(6):555-560. [pmid: 17670481].
123 Simek M, Hajek R, Fluger I, Zalesak b, Molitor M, Lonsky V, Grulichova J, Langova k. Topical negative pressure versus conventional treatment of deep sternal wound infection in cardiac surgery. EWMA J. Oct. 2008;8(3):17-20.
124 Song DH, Wu LC, Lohman RF, Gottlieb LJ, Franczyk M. Vacuum assisted closure for the treatment of sternal wounds: the bridge between debridement and definitive closure. Plast Reconstr Surg. Jan. 2003;111(1):92-97. [pmid: 12496568].
125 Stannard JP, Robinson JT, Anderson ER, McGwin G Jr, Volgas DA, Alonso JE. Negative pressure wound therapy to treat hematomas and surgical incisions following high-energy trauma. J Trauma. Jun. 2006;60(6):1301-1306. [pmid: 16766975].
126 Schwien T, Gilbert J, Lang C. Pressure ulcer prevalence and the role of negative pressure wound therapy in home health quality outcomes. Ostomy Wound Manag. 2005;51:47-60. [pmid: 16230764].
127 Huang WS, Hsieh SC, Hsieh CS, Schoung JY, Huang T. Use of vacuum-assisted wound closure to manage limb wounds in patients suffering from acute necrotizing fasciitis. Asian J Surg. Jul. 2006;29(3):135-139. [pmid: 16877210].
128 Doss M, Martens S, Wood JP, Wolff JD, Baier C, Moritz A. Vacuum-assisted suction drainage versus conventional treatment in the management of poststernotomy osteomyelitis. Eur J Cardiothorac Surg. Dec. 1. 2002;22(6):934-938. [pmid: 12467816].
129 Domkowski PW, Smith ML, Gonyon DL Jr, Drye C, Wooten MK, Levin LS, Wolfe WG. Evaluation of vacuum-assisted closure in the treatment of poststernotomy mediastinitis. J Thorac Cardiovasc Surg. Aug. 1. 2003;126(2):386-390. [pmid: 12928634].
130 Immer FF, Durrer M, Muhlemann KS, Erni D, Gahl B, Carrel TP. Deep sternal wound infection after cardiac surgery: modality of treatment and outcome. Ann Thorac Surg. Sep. 2005;80(3):957-961. [pmid: 16122463].
131 Genecov DG, Schneider AM, Morykwas MJ, Parker D, White WL, Argenta LC. A controlled subatmospheric pressure dressing increases the rate of skin graft donor site reepithelialization. Ann Plast Surg. Mar. 1998;40(3):219-225. [pmid: 9523602].
132 Scherer LA, Shiver S, Chang M, Meredith JW, Owings JT, Tominaga GT, Schecter WP, Parks SN, Peck J, Mayberry J. The vacuum assisted closure device: a method of securing skin grafts and improving graft survival. Arch Surg. 2002;137(8):930-934. [pmid: 12146992].
133 Stone P, Prigozen J, Hofeldt M, Hass S, DeLuca J, Flaherty S. Bolster versus negative pressure wound therapy for securing split-thickness skin grafts in trauma patients. Wounds. 2004;16(7):219-223.
134 Bickels J, Kollender Y, Wittig JC, Cohen N, Meller I, Malawer MM. Vacuum-assisted wound closure after resection of musculoskeletal tumors. Clin Orthop Relat Res. Dec. 2005;441:346-350. [pmid: 16331025].
135 Denzinger S, Lubke L, Roessler W, Wieland WF, Kessler S, Burger M. Vacuum-assisted closure versus conventional wound care in the treatment of wound failures following inguinal lymphadenectomy for penile cancer: a retrospective study. Eur Urol. May. 2007;51(5):1320-1325. [pmid: 17207916].
136 Moues CM, van den Bemd GJ, Heule F, Hovius SE. Comparing conventional gauze therapy to vacuum-assisted closure wound therapy: a prospective randomised trial. J Plast Reconstr Aesthet Surg. 2007;60(6):672-681. [pmid: 17485058].
137 Catarino PA, Chamberlin MH, Wright NC, Black E, Campbell K, Robson D, Pillai RG. High-pressure suction drainage via a polyurethane foam in the management of poststernotomy mediastinitis. Ann Thorac Surg. 2000;70:1891-1895. [pmid: 11156090].
138 Shilt JS, Yoder JS, Manuck TA, Jacks L, Rushing J, Smith BP. Role of vacuum-assisted closure in the treatment of pediatric lawnmower injuries. J Pediatr Orthop. 2004;24(5):482-487. [pmid: 15308896].
139 Sjogren J, Gustafsson R, Nilsson J, Malmsjo M, Ingemansson R. Clinical outcome after poststernotomy mediastinitis: Vacuum-assisted closure versus conventional treatment. Ann Thorac Surg. 2005;79(6):2049-2055. [pmid: 15919308].
140 Ha J, Phillips M. A retrospective review of the outcomes of vacuum-assisted closure therapy in a vascular surgery unit. Wounds. Aug. 2008;20(8):221-229.
141 Bollero D, Carnino R, Risso D, Gangemi EN, Stella M. Acute complex traumas of the lower limbs: A modern reconstructive approach with negative pressure therapy. Wound Repair Regen. Jul. 2007;15(4):589-594. [pmid: 17650104].
142 McCord SS, Naik-Mathuria BJ, Murphy KM, McLane KM, Gay AN, Bob Basu C, Downey CR, Hollier LH, Olutoye OO. Negative pressure therapy is effective to manage a variety of wounds in infants and children. Wound Repair Regen. May-Jun. 2007;15(3):296-301. [pmid: 17537115].
143 Mendonca DA, Drew PJ, Harding KG, Price PE. A pilot study on the effect of topical negative pressure on quality of life. J Wound Care. Feb. 2007;16(2):49-53. [pmid: 17319616].
144 Butter A, Emran M, Al-Jazaeri A, Ouimet A. Vacuum-assisted closure for wound management in the pediatric population. J Pediatr Surg. May. 2006;41(5):940-942. [pmid: 16677888].
145 Demaria RG, Giovannini U, Teot L, Frapier JM, Albat B. A new technique for the treatment of delayed sternotomy healing: the vacuum therapy. Heart Surg Forum. 2003;6(5):434-437. [pmid: 14721827].
146 Gustafsson RI, Sjogren J, Ingemansson R. Deep Sternal Wound Infection: A Sternal-Sparing Technique with Vacuum-Assisted Closure Therapy. Ann Thorac Surg. 2003;76(6):2048-2053. [pmid: 14667639].
147 Schimp VL, Worley C, Brunello S, Levenback CC, Wolf JK, Sun CC, Bodurka DC, Ramirez PT. Vacuum-assisted closure in the treatment of gynecologic oncology wound failures. Gynecol Oncol. Feb. 2004;92(2):586-591. [pmid: 14766251].
148 Argenta LC, Morykwas MJ. Vacuum-assisted closure: a new method for wound control and treatment: clinical experience. Ann Plast Surg. Jun. 1997;38(6):563-576. discussion 577. [pmid: 9188971].
149 Svensson S, Monsen C, Kolbel T, Acosta S. Predictors for Outcome after Vacuum Assisted Closure Therapy of Perivascular Surgical Site Infections in the Groin. Eur J Vasc Endovasc Surg. Jul. 2008;36(1):84-89. [pmid: 18294875].
150 Jones GA, Butler J, Lieberman I, Schlenk R. Negative-pressure wound therapy in the treatment of complex postoperative spinal wound infections: complications and lessons learned using vacuum-assisted closure. J Neurosurg Spine. May. 2007;6(5):407-411. [pmid: 17542505].
151 Sartipy U, Lockowandt U, Gabel J, Jideus L, Dellgren G. Cardiac Rupture During Vacuum-Assisted Closure Therapy. Ann Thorac Surg. Sep. 2006;82(3):1110-1111. [pmid: 16928555].
152 Adamkova M, Tymonova J, Zamecnikova I, Kadlcik M, Klosova H. First experience with the use of vacuum assisted closure in the treatment of skin defects at the Burn Center. Acta Chir Plast. 2005;47(1):24-27. [pmid: 15954460].
153 Bapat V, El-Muttardi N, Young C, Venn G, Roxburgh J. Experience with vacuum-assisted closure of sternal wound infections following cardiac surgery and evaluation of chronic complications associated with its use. J Card Surg. May. 2008;23(3):227-233. [pmid: 18435637].
154 Gdalevitch P, Afilalo J, Lee C. Predictors of vacuum-assisted closure failure of sternotomy wounds. J Plast Reconstr Aesthet Surg. 2008. Nov. 21. Epub ahead of print. [pmid: 19028156].
155 Horch RE, Dragu A, Lang W, Banwell P, Leffler M, Grimm A, Bach AD, Uder M, Kneser U. Coverage of exposed bones and joints in critically ill patients: lower extremity salvage with topical negative pressure therapy. J Cutan Med Surg. Sep-Oct. 2008;12(5):223-229. [pmid: 18845091].
156 DeFranzo AJ, Pitzer K, Molnar JA, Marks MW, Chang MC, Miller PR, Letton RW, Argenta LC. Vacuum-assisted closure for defects of the abdominal wall. Plast Reconstr Surg. Mar. 2008;121(3):832-839. [pmid: 18317132].
157 DeFranzo AJ, Argenta LC, Marks MW, Molnar JA, David LR, Webb LX, Ward WG, Teasdall RG. The use of vacuum-assisted closure therapy for the treatment of lower-extremity wounds with exposed bone. Plast Reconstr Surg. Oct. 2001;108(5):1184-1191. [pmid: 11604617].
158 Wu SH, Zecha PJ, Feitz R, Hovius SE. Vacuum therapy as an intermediate phase in wound closure: A clinical experience. Eur J Plastic Surg. May. 2000;23(4):174-177.
159 Lang E, Bauer G, Becker U, Losel S. Vacuum sealing technique for severe soft tissue trauma of the ankle and foot. Foot Ankle Surg. 1999;5(1):9-14.
160 Chen Y, Almeida AA, Mitnovetski S, Goldstein J, Lowe C, Smith JA. Managing deep sternal wound infections with vacuum-assisted closure. ANZ J Surg. May. 2008;78(5):333-336. [pmid: 18380722].
161 Wondberg D, Larusson HJ, Metzger U, Platz A, Zingg U. Treatment of the open abdomen with the commercially available vacuum-assisted closure system in patients with abdominal sepsis : low primary closure rate. World J Surg. Dec. 2008;32(12):2724-2729. [pmid: 18836762].
162 Baharestani MM. Use of negative pressure wound therapy in the treatment of neonatal and pediatric wounds: a retrospective examination of clinical outcomes. Ostomy Wound Manage. Jun. 2007;53(6):75-85. [pmid: 17586874].
163 Rao M, Burke D, Finan PJ, Sagar PM. The use of vacuum-assisted closure of abdominal wounds: a word of caution. Colorectal Dis. Mar. 2007;9(3):266-268. [pmid: 17298627].
164 Morgan K, Brantigan CO, Field CJ, Paden M. Reverse sural artery flap for the reconstruction of chronic lower extremity wounds in high-risk patients. J Foot Ankle Surg. Nov. 2006;45(6):417-423. [pmid: 17145467].
165 Caniano DA, Ruth B, Teich S. Wound management with vacuum-assisted closure: experience in 51 pediatric patients. J Pediatr Surg. Jan. 2005;40(1):128-132. discussion 132. [pmid: 15868572].
166 Suliburk JW, Ware DN, Balogh Z, McKinley BA, Cocanour CS, Kozar RA, Moore FA. Vacuum-Assisted Wound Closure Achieves Early Fascial Closure of Open Abdomens after Severe Trauma. J Trauma Inj Infect Crit Care. 2003;55(6):1155-1160. [pmid: 14676665].
167 De Lange MY, Schasfoort RA, Obdeijn MC, Van Der Werff JFA, Nicolai JPA. Vacuum-assisted closure: Indications and clinical experience. Eur J Plastic Surg. May. 2000;23(4):178-182.
168 Fisher A, Brady B. Vacuum assisted wound closure therapy. Issues Emerg Health Technol. Mar. 2003;(44):1-6. [pmid: 12653112].
169 Higgins S. The effectiveness of vacuum assisted closure (VAC) in wound healing. Clayton, Victoria, Australia. Centre for Clinical Effectiveness (CCE). Dec. 2003:16. Also available: http://www.med.monash.edu.au/healthservices/cce.
170 Schintler MV, Prandl E-C. Vacuum-assisted closure - What is evidence based?. Eur Surg. 2008;40(1):11-18.
171 Shea BJ, Grimshaw JM, Wells GA, Boers M, Andersson N, Hamel C, Porter AC, Tugwell P, Moher D, Bouter LM. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989].
172 Wasiak J, Cleland H. Topical negative pressure (TNP) for partial thickness burns (Review). Cochrane Database of Systematic Reviews [internet]. Hoboken (NJ). John Wiley & Sons, Ltd. 2007;(Issue 3):CD006215. [pmid: 17636835].
173 Gregor S, Maegele M, Sauerland S, Krahn JF, Peinemann F, Lange S. Negative pressure wound therapy: a vacuum of evidence?. Arch Surg. Feb. 2008;143(2):189-196. [pmid: 18283145].
174 Ubbink DT, Westerbos SJ, Evans D, Land L, Vermeulen H. Topical negative pressure for treating chronic wounds (Review). Cochrane Database of Systematic Reviews [internet]. Hoboken (NJ). John Wiley & Sons, Ltd. 2008;(Issue 3):CD001898. [pmid: 18646080].
175 Schimmer C, Sommer SP, Bensch M, Elert O, Leyh R. Management of poststernotomy mediastinitis: experience and results of different therapy modalities. Thorac Cardiovasc Surg. Jun. 2008;56(4):200-204. [pmid: 18481237].
176 Pham CT, Middleton PF, Maddern GJ. The safety and efficacy of topical negative pressure in non-healing wounds: a systematic review. J Wound Care. Jun. 2006;15(6):240-250. [pmid: 16802559].
177 Gray M, Peirce B. Is negative pressure wound therapy effective for the management of chronic wounds. J Wound Ostomy Continence Nurs. May/June. 2004;31(3):101-105. [pmid: 15867737].
178 Vikatmaa P, Juutilainen V, Kuukasjarvi P, Malmivaara A. Negative Pressure Wound Therapy: a Systematic Review on Effectiveness and Safety. Eur J Vasc Endovasc Surg. Oct. 2008;36(4):438-448. [pmid: 18675559].
179 Sjogren J, Nilsson J, Gustafsson R, Malmsjo M, Ingemansson R. The impact of vacuum-assisted closure on long-term survival after post-sternotomy mediastinitis. Ann Thorac Surg. Oct. 2005;80(4):1270-1275. [pmid: 16181853].
180 Vlayen J, Camerlin C, Ramaekers D. Vacuumgeassisteerde Wondbehandeling: een Rapid Assessment. Health Technology Assessment (HTA). Brussel. Federaal Kenniscentrum voor de Gezondheidszorg (KCE). 2007. (KCE reports 61A (D2007/10.273/30); ).
181 Costa V, Brophy J, McGregor M. Vacuum-assisted wound closure therapy (V.A.C). Montreal. Technology Assessment Unit of the McGill University Health Center (MUHC). 2005:24. Also available: http://www.mcgill.ca/files/tau/VAC_REPORT_FINAL.pdf.
182 Samson DJ, Lefevre F, Aronson N. Wound-healing technologies: low-level laser and vacuum-assisted closure. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). 2004:75. (Evidence report/technology assessment, no. 111).
183 Ubbink DT, Westerbos SJ, Nelson EA, Vermeulen H. A systematic review of topical negative pressure therapy for acute and chronic wounds. Br J Surg. Jun. 2008;95(6):685-692. [pmid: 18446777].
184 Ontario Ministry of Health and Long-Term Care. Negative pressure wound therapy: update. health technology policy assessment. Toronto (ON). Medical Advisory Secretariat, Ontario Ministry of Health and Long-Term Care (MAS). Jul. 2006:38.
185 Contractor D, Amling J, Brandoli C, Tosi LL. Negative pressure wound therapy with reticulated open cell foam in children: an overview. J Orthop Trauma. Nov-Dec. 2008;22(10 Suppl):S167-S176. [pmid: 19034165].
186 Raja SG, Berg GA. Should vacuum-assisted closure therapy be routinely used for management of deep sternal wound infection after cardiac surgery?. Interact Cardiovasc Thorac Surg. Aug. 2007;6(4):523-527. [pmid: 17669926].
187 Mendonca DA, Papini R, Price PE. Negative-pressure wound therapy: a snapshot of the evidence. Int Wound J. Dec. 2006;3(4):261-271. [pmid: 17199762].
188 Gupta S, Cho T. A literature review of negative pressure wound therapy. Ostomy Wound Manage. Nov. 2004;50(11A Suppl):2S-4S. [pmid: 15632458].
189 Peinemann F, McGauran N, Sauerland S, Lange S. Negative pressure wound therapy: Potential publication bias caused by lack of access to unpublished study results data. BMC Med Res Methodol. 2008;8:4. [pmid: 18267008].
190 Schulz KF, Chalmers I, Hayes RJ, Altman DG. Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. Feb. 1. 1995;273(5):408-412. [pmid: 7823387].
191 Agosti JK. A study of combined interventions: negative pressure wound therapy and a 100% sodium carboxymethylcellulose fiber dressing with ionic silver for the management of a surgical flap [1429]. WOCN Society 39th annual conference. June 9-13, 2007. Salt Lake City, UT. Mt. Laurel (NJ). Wound, Ostomy and Continence Nurses Society (WOCN). 2007.
192 Apelqvist J, Armstrong DG, Lavery LA, Boulton AJ. Resource utilization and economic costs of care based on a randomized trial of vacuum-assisted closure therapy in the treatment of diabetic foot wounds. Am J Surg. Jun. 2008;195(6):782-788. [pmid: 18355797].
193 Armstrong DG, Nguyen HC. Improvement in healing with aggressive edema reduction after debridement of foot infection in persons with diabetes. Arch Surg. Dec. 2000;135(12):1405-1409. [pmid: 11115342].
194 Armstrong DG, Kunze K, Martin BR, Kimbriel HR, Nixon BP, Boulton AJ. Plantar pressure changes using a novel negative pressure wound therapy technique. J Am Podiatr Med Assoc. Sep-Oct. 2004;94(5):456-460. [pmid: 15377721].
195 Armstrong DG, Lavery LA. Diabetic Foot Study Consortium. Negative pressure wound therapy after partial diabetic foot amputation: a multicentre, randomised controlled trial. Lancet. Nov. 12. 2005;366(9498):1704-1710. [pmid: 16291063].
196 Armstrong DG, Lavery LA. Negative pressure wound therapy via vacuum assisted closure following partial foot amputation: what is the role of wound chronicity?. American Diabetes Association 66th scientific sessions. June 9-13, 2006. Washington, D.C. San Antonio (TX). KCI. 2006.
197 Augustin M. Benefit evaluation of out-and inpatient VAC-therapy from the patient's perspective [abstract 104]. EWMA conference: innovation, education, implementation. Prague, Czech Republic. European Wound Management Association (EWMA). 2006.
198 Aust MC, Spies M, Guggenheim M, Gohritz A, Kall S, Rosenthal H, Pichlmaier M, Oehlert G, Vogt PM. Lower limb revascularisation preceding surgical wound coverage - an interdisciplinary algorithm for chronic wound closure. J Plast Reconstr Aesthet Surg. Aug. 2008;61(8):925-933. [pmid: 18407817].
199 Baharestani MM, Houliston-Otto DB, Barnes S. Early versus late initiation of negative pressure wound therapy: examining the impact on home care length of stay. Ostomy Wound Manage. Nov. 2008;54(11):48-53. [pmid: 19037137].
200 Barker DE, Kaufman HJ, Smith LA, Ciraulo DL, Richart CL, Burns RP. Vacuum pack technique of temporary abdominal closure: a 7-year experience with 112 patients. J Trauma. Feb. 2000;48(2):201-206. discussion 206-7. [pmid: 10697075].
201 Barnes SA, Miller E. V.A.C. therapy is associated with greater wound healing in LTAC pressure ulcer patients. APWCA2007 National Clinical Conference, Wound Care and the Related Sciences. Apr 22, 2007. Philadelphia, PA. Richboro (PA). American Professional Wound Care Association (APWCA). 2007.
202 Barringer CB, Gorse SJ, Burge TS. The VAC dressing--a cautionary tale. Br J Plast Surg. Jul. 2004;57(5):482. [pmid: 15191843].
203 Bee TK, Croce MA, Magnotti LJ, Zarzaur BL, Maish GO 3rd, Minard G, Schroeppel TJ, Fabian TC. Temporary abdominal closure techniques: a prospective randomized trial comparing polyglactin 910 mesh and vacuum-assisted closure. J Trauma. Aug. 2008;65(2):337-342. discussion 342-4. [pmid: 18695468].
204 Bernstein B, Williams A, Driver VR. Improving split thickness skin graft take with V.A.C. Therapy in high risk patients. A team approach: diabetic limb salvage, Georgetown University Hospital. Sep 18-20, 2008. Washington, D.C. Lafayette (LA). International Conference Management. 2008.
205 Bischoff M, Maier D, Sarkar M, Halter G, Beck A. Vacuum-sealing fixation of mesh grafts. Eur J Plast Surg. 2003;26(4):186-190. EMBASE (OVID): 2003327284.
206 Blackett A, Bohnenkamp SK. A fistula, a styrofoam cup, and negative pressure wound closure therapy [149]. 38th Annual WOCN Society Conference. June 24-28, 2006. Minneapolis, MN. Mt. Laurel (NJ). Wound, Ostomy and Continence Nurses Society (WOCN). 2006.
207 Bovill E, Banwell PE, Teot L, Eriksson E, Song C, Mahoney J, Gustafsson R, Horch R, Deva A, Whitworth I. International Advisory Panel on Topical Negative Pressure. Topical negative pressure wound therapy: a review of its role and guidelines for its use in the management of acute wounds. Int Wound J. Oct. 2008;5(4):511-529. [pmid: 18808432].
208 Brin YS, Mumcuoglu KY, Massarwe S, Wigelman M, Gross E, Nyska M. Co-treatment of maggot debridement therapy and vacuum assisted closure for foot ulcers -- a case report [p007]. EWMA conference: innovation, education, implementation. Prague, Czech Republic. European Wound Management Association (EWMA). 2006.
209 Bruenner W, Koelblinger C, Schwarzl F. Vacuum assisted closure system in the management of open abdomen and intestinal fistula - a case report [p038]. EWMA conference: innovation, education, implementation. Prague, Czech Republic. European Wound Management Association (EWMA). 2006.
210 Bui TD, Huerta S, Gordon IL. Negative pressure wound therapy with off-the-shelf components. Am J Surg. Aug. 2006;192(2):235-237. [pmid: 16860636].
211 Burbage J. Salvage the split thickness skin graft by using the combination of V.A.C. therapy and select silver wound dressing [2209]. WOCN Society 40th Annual Conference. June 21-25, 2008. Orlando, FL. Mt. Laurel (NJ). Wound, Ostomy and Continence Nurses Society (WOCN). 2008.
212 Burdette-Taylor SR. Use of the versatile one (V1) for closed suction drainage to stimulate closure in chronic wounds in home care. San Diego (CA). Blue Sky Medical. 2003:1.
213 Buttenschoen K, Fleischmann W, Haupt U, Kinzl L, Buttenschoen DC. The influence of vacuum-assisted closure on inflammatory tissue reactions in the postoperative course of ankle fractures. Foot Ankle Surg. 2001;7(3):165-173.
214 Campbell PE. Teaching old wounds old tricks???. Healing chronic wounds with classic treatments using the Chariker-Jeter closed suction wound drainage system. San Diego (CA). Blue Sky Medical. 2004:1.
215 Centers for Medicare & Medicaid Services (CMS). Negative pressure wound therapy pump. Code: E2402. HCPCS and CPT Codebook [internet]. Baltimore (MD). Centers for Medicare & Medicaid Services (CMS). 2009:5.
216 Centers for Medicare & Medicaid Services (CMS). Negative pressure wound therapy drsg set. Code: A6550. HCPCS and CPT Codebook [internet]. Baltimore (MD). Centers for Medicare & Medicaid Services (CMS). 2009:6.
217 Negative pressure wound therapy pump: DMEPOS fee schedule [internet]. Baltimore (MD). Centers for Medicare & Medicaid Services (CMS). 2009:1.
218 Chavarria-Aguilar M, Cockerham WT, Barker DE, Ciraulo DL, Richart CM, Maxwell RA. Management of destructive bowel injury in the open abdomen. J Trauma. Mar. 2004;56(3):560-564. [pmid: 15128127].
219 Cipolla J, Stawicki SP, Hoff WS, McQuay N, Hoey BA, Wainwright G, Grossman MD. A proposed algorithm for managing the open abdomen. Am Surg. Mar. 2005;71(3):202-207. [pmid: 15869132].
220 Corvino P, Stokes TH. Closure of dehisced myelomeningocele wound using extracellular wound matrix and negative pressure wound therapy in a neonate [2214]. WOCN Society 40th Annual Conference. June 21-25, 2008. Orlando, FL. Mt. Laurel (NJ). Wound, Ostomy and Continence Nurses Society (WOCN). 2008.
221 Davis JM. Combining wound debridement modalities with negative pressure wound therapy [123]. 38th Annual WOCN Society Conference. June 24-28, 2006. Minneapolis, MN. Mt. Laurel (NJ). Wound, Ostomy and Continence Nurses Society (WOCN). 2006.
222 Dedmond BT, Kortesis B, Punger K, Simpson J, Argenta J, Kulp B, Morykwas M, Webb LX. Subatmospheric pressure dressings in the temporary treatment of soft tissue injuries associated with type III open tibial shaft fractures in children. J Pediatr Orthop. Nov. 2006;26(6):728-732. [pmid: 17065934].
223 de Leon J, Miller E, Keith M. A cost-effectiveness evaluation of vacuum-assisted closure treatment for hospitalized diabetic foot ulcer wound patients [256]. 38th Annual WOCN Society Conference. June 24-28, 2006. Minneapolis, MN. Mt. Laurel (NJ). Wound, Ostomy and Continence Nurses Society (WOCN). 2006.
224 Doxford M. A practical guide for using VAC therapy on post-operative diabetic foot wounds. Diabetic Foot. Autumn. 2007;10(3):156. 158. 160 passim.
225 Edwards J. A novel use for VAC in a tracheostomy site [abstract 105]. EWMA conference: innovation, education, implementation. Prague, Czech Republic. European Wound Management Association (EWMA). 2006.
226 Eginton MT, Brown KR, Seabrook GR, Towne JB, Cambria RA. A prospective randomized evaluation of negative-pressure wound dressings for diabetic foot wounds. Ann Vasc Surg. Nov. 2003;17(6):645-649. [pmid: 14534844].
227 Eifert S, Kronschnabl S, Kaczmarek I, Reichart B, Vicol C. Omental flap for recurrent deep sternal wound infection and mediastinitis after cardiac surgery. Thorac Cardiovasc Surg. Sep. 2007;55(6):371-374. EMBASE (OVID):2007459831. [pmid: 17721846].
228 Using topical negative pressure with a lipidocolloid dressing. Ostomy Wound Manage. Jun. 2008;54(6):12-14. [pmid: 18702191].
229 Teot L, Lambert L, Ourabah Z, Bey E, Steenman C, Wierzbiecka E, Malikov S, Charles JP, Vives F, Bohbot S. Use of topical negative pressure with a lipidocolloid dressing: results of a clinical evaluation. J Wound Care. Sep. 2006;15(8):355-358. [pmid: 17001944].
230 Farren M, Dionson M, Mandel M, Dozier A. Case study: home health care management strategies for a client with complex clinical and social issues using NPWT for wound healing [1266]. WOCN Society 39th annual conference. June 9-13, 2007. Salt Lake City, UT. Mt. Laurel (NJ). Wound, Ostomy and Continence Nurses Society (WOCN). 2007.
231 Fife CE, Walker D, Thomson B, Otto G. The safety of negative pressure wound therapy using vacuum-assisted closure in diabetic foot ulcers treated in the outpatient setting. Int Wound J. Jun. Suppl 2. 2008;5:17-22. [pmid: 18577134].
232 Foo A, Kin-Sze Chong A, Shenthilkumar N. The 'hand-in-gloves' technique: vacuum-assisted closure dressing for multiple finger wounds. J Plast Reconstr Aesthet Surg. 2008. Sep. 5. Epub ahead of print. [pmid: 18774764].
233 Francu M. The surgical solution of pressure sores and TNP therapy [299]. 18th EWMA Conference: wound management · wound healing – responsibility and actions. May 14-16, 2008. Lisbon, Portugal. European Wound Management Association (EWMA). 2008.
234 Frykberg RG, Zgonis T, Armstrong DG, Driver VR, Giurini JM, Kravitz SR, Landsman AS, Lavery LA, Moore C, Schuberth JM, Wukick DK, Andersen C, Vanore JV. American College of Foot and Ankle Surgeons. Diabetic foot disorders: a clinical practice guideline. J Foot Ankle Surg. Sep-Oct. 2006;45(5):S2-S66.
235 Girolami S, Sadowski-Liest D. Bio-Dome technology: the newest approach to negative pressure wound therapy. 20th annual symposium on advanced wound care. April 28 - May 1, 2007. Tampa, FL. Norristown (PA). Boehringer Wound Systems, LLC. 2007.
236 Gupta S, Cho T. A literature review of negative pressure wound therapy. Ostomy Wound Manage. Apr. 2004;50(4A Suppl):6-8. [pmid: 15317236].
237 Harris PA. Use of a SIS wound matrix with negative pressure wound therapy (NPWT) in pediatric transplant patients [1275]. WOCN Society 39th annual conference. June 9-13, 2007. Salt Lake City, UT. Mt. Laurel (NJ). Wound, Ostomy and Continence Nurses Society (WOCN). 2007.
238 Harris PA. Use of NPWT and silver foam to treat a complex peristomal breakdown in the post operative intestinal transplant patient [2220]. WOCN Society 40th Annual Conference. June 21-25, 2008. Orlando, FL. Mt. Laurel (NJ). Wound, Ostomy and Continence Nurses Society (WOCN). 2008.
239 Heinsler CM, Krenzer ME, Salathiel M. Use of vacuum assisted therapy for management of enterocutaneous fistulae in open abdominal wound as component of total patient care plan [205]. 38th Annual WOCN Society Conference. June 24-28, 2006. Minneapolis, MN. Mt. Laurel (NJ). Wound, Ostomy and Continence Nurses Society (WOCN). 2006.
240 Hill L, McCormick J, Tamburino J, Haggerty J, Cohen P, Jensen C, McMullin MJ, Zemitis L, Rodgers S, Connolly M, Petrillo K, Brooks S. The effectiveness of engenex: a new NPWT device. 20th annual symposium on advanced wound care. April 28 - May 1, 2007. Tampa, FL. Norristown (PA). Boehringer Wound Systems, LLC. 2007.
241 Howell-Taylor M, Hall MG Jr, Brownlee WJ III, Taylor M. Combined use of negative pressure wound therapy and acoustic pressure wound therapy to prepare infected, open postsurgery wounds for secondary surgical closure. Washington (DC). Specialty Hospital of Washington Capitol Hill. 2008:1.
242 Hunter JE, Teot L, Horch R, Banwell PE. Evidence-based medicine: Vacuum-assisted closure in wound care management. Int Wound J. Sep. 2007;4(3):256-269. [pmid: 17924882].
243 Institute for Clinical Systems Improvement (ICSI). Pressure ulcer treatment. Health care protocol. Bloomington (MN). Institute for Clinical Systems Improvement (ICSI). Jan. 2008:28.
244 Institute for Quality and Efficiency in Health Care. Negative pressure wound therapy. Final report N04-03. Cologne (Germany). Institute for Quality and Efficiency in Health Care. Mar. 13. 2006:135. Also available: http://www.iqwig.de/.
245 Institute for Quality and Efficiency in Health Care. Negative pressure wound therapy: executive summary. Rapid report N06-02. Cologne (Germany). Institute for Quality and Efficiency in Health Care. Jan. 29. 2007:5.
246 Jeschke MG, Rose C, Angele P, Fuchtmeier B, Nerlich MN, Bolder U. Development of new reconstructive techniques: use of Integra in combination with fibrin glue and negative-pressure therapy for reconstruction of acute and chronic wounds. Plast Reconstr Surg. Feb. 2004;113(2):525-530. [pmid: 14758212].
247 Jones SM, Banwell PE, Shakespeare PG. Interface dressings influence the delivery of topical negative-pressure therapy. Plast Reconstr Surg. Sep. 15. 2005;116(4):1023-1028. [pmid: 16163089].
248 Karoo RO, Shariff Z, Stanley PR. DuoDERM strip border - A new technique for Vacuum-assisted closure in complex facial wounds. Br J Oral Maxillofac Surg. Mar. 1. 2009;47(2):163-164. [pmid: 18778879].
249 Kendall H. Integration of negative pressure wound therapy into nursing practice [2342]. WOCN Society 40th Annual Conference. June 21-25, 2008. Orlando, FL. Mt. Laurel (NJ). Wound, Ostomy and Continence Nurses Society (WOCN). 2008.
250 Keyser LD. The pressure is on – successful wound closure in a challenging patient with a cranial wound using a versatile negative pressure wound therapy system [2228]. WOCN Society 40th Annual Conference. June 21-25, 2008. Orlando, FL. Mt. Laurel (NJ). Wound, Ostomy and Continence Nurses Society (WOCN). 2008.
251 Kim EK, Hong JP. Efficacy of negative pressure therapy to enhance take of 1-stage allodermis and a split-thickness graft. Ann Plast Surg. May. 2007;58(5):536-540. [pmid: 17452839].
252 Kollrack Y, Möllenhoff G. TNP-therapy as a valuable adjunct in complicated wound healing after trauma of the lower limb - case studies [234]. 18th EWMA Conference: wound management - wound healing - responsibility and actions. May 14-16, 2008. Lisbon, Portugal. European Wound Management Association (EWMA). 2008.
253 Krasner DL. Managing wound pain in patients with vacuum-assisted closure devices. Ostomy Wound Manage. May. 2002;48(5):38-43. [pmid: 12046489].
254 Kring J, Carlson B, Konz EC. Use of a contact layer with silver under a negative pressure dressing. Third congress of the World Union of Wound Healing Societies. June 4-8, 2008. Toronto, Ontario, Canada. Libertyville (IL). Hollister Wound Care LLC. 2008.
255 Kwasnik EM, Arruffat S, Harkins SM. Mechanical adjuncts to wound healing. Curr Surg. Sep-Oct. 2005;62(5):465-469. [pmid: 16125600].
256 Lambert KV, Hayes P, McCarthy M. Vacuum assisted closure: a review of development and current applications. Eur J Vasc Endovasc Surg. Mar. 2005;29(3):219-226. [pmid: 15694791].
257 Lavery LA, Barnes SA, Keith MS, Seaman JW Jr, Armstrong DG. Prediction of healing for postoperative diabetic foot wounds based on early wound area progression. Diabetes Care. Jan. 2008;31(1):26-29. [pmid: 17934156].
258 Li S, Zhang H, Jiao QF, Liu Z, Mao BY. A comparative study on therapeutic method of traumatic epidural hematoma. Chin J Traumatol. Jun. 2007;10(3):166-170. [pmid: 17535641].
259 Llanos S, Danilla S, Barraza C, Armijo E, Pineros JL, Quintas M, Searle S, Calderon W. Effectiveness of negative pressure closure in the integration of split thickness skin grafts: a randomized, double-masked, controlled trial. Ann Surg. Nov. 2006;244(5):700-705. [pmid: 17060762].
260 Lopez Almodovar LF, Canas AC, Lima Canadas PP, Hernandez MC. Vacuum-assisted therapy with a handcrafted system for the treatment of wound infection after median sternotomy. Interact Cardiovasc Thorac Surg. Oct. 1. 2005;4(5):412-414. [pmid: 17670445].
261 Lübke L, Denzinger S, Burger M, Kessler S, Wieland WF, Otto W. Topical negative pressure therapy in ureteroileal anastomotic leakage after surgical therapy of bladder cancer [93]. 18th EWMA Conference: wound management - wound healing - responsibility and actions. May 14-16, 2008. Lisbon, Portugal. European Wound Management Association (EWMA). 2008.
262 Luckraz H, Murphy F, Bryant S, Charman SC, Ritchie AJ. Vacuum-assisted closure as a treatment modality for infections after cardiac surgery. J Thorac Cardiovasc Surg. 2003;125(2):301-305. [pmid: 12579098].
263 Manahan MA, Shermak MA. Massive panniculectomy after massive weight loss. Plast Reconstr Surg. Jun. 2006;117(7):2191-2197. [pmid: 16772916].
264 Martinsek PE, Chucta S, Schlanger R. Case study: the use of topical oxygen and negative pressure wound therapy to potentiate wound healing [1283]. WOCN Society 39th annual conference. June 9-13, 2007. Salt Lake City, UT. Mt. Laurel (NJ). Wound, Ostomy and Continence Nurses Society (WOCN). 2007.
265 Matzi V, Lindenmann J, Porubsky C, Mujkic D, Maier A, Smolle-Juettner FM. V.A.C. treatment: a new approach to the management of septic complications in thoracic surgery [abstract 102]. EWMA conference: innovation, education, implementation. Prague, Czech Republic. European Wound Management Association (EWMA). 2006.
266 McCord SS, Naik-Mathuria B, Murphy K, Hollier L, Olutoye O. Negative pressure wound therapy is effective to manage a variety of wounds in infants and children [1448]. WOCN Society 39th annual conference. June 9-13, 2007. Salt Lake City, UT. Mt. Laurel (NJ). Wound, Ostomy and Continence Nurses Society (WOCN). 2007.
267 McGinnis P, Lisco C. The use of negative wound pressure therapy and polyhexamethalene biguanide impregnated gauze to promote wound healing status-post surgical debridment of Fournier's gangrene [1284]. WOCN Society 39th annual conference. June 9-13, 2007. Salt Lake City, UT. Mt. Laurel (NJ). Wound, Ostomy and Continence Nurses Society (WOCN). 2007.
268 McLane K, Bookout KR, McCord S. Case study: using a negative pressure wound therapy device (NPWT) in pediatric patients [152]. 38th Annual WOCN Society Conference. June 24-28, 2006. Minneapolis, MN. Mt. Laurel (NJ). Wound, Ostomy and Continence Nurses Society (WOCN). 2006.
269 Medeiros AC, Aires-Neto T, Marchini JS, Brandao-Neto J, Valenca DM, Egito EST. Treatment of postoperative enterocutaneous fistulas by high-pressure vacuum with a normal oral diet. Dig Surg. 2004;21(5-6):401-405. [pmid: 15564785].
270 Mees ST, Palmes D, Mennigen R, Senninger N, Haier J, Bruewer M. Endo-vacuum assisted closure treatment for rectal anastomotic insufficiency. Dis Colon Rectum. Apr. 2008;51(4):404-410. [pmid: 18197452].
271 Mendez-Eastman S. Using negative-pressure wound therapy for positive results. Nursing. May. 2005;35(5):48-50. [pmid: 15879970].
272 Miller MS, Brown R. Use of Blue Sky Medical versatile one negative pressure wound therapy for pressure based chronic wounds. San Diego (CA). Blue Sky Medical. 2003:1.
273 Miller MS, Brown R. Use of Blue Sky Medical versatile one negative pressure wound therapy for treating post surgical dehiscence of abdominal wounds. San Diego (CA). Blue Sky Medical. 2003:1.
274 Miller MS, Brown R. Use of Blue Sky Medical versatile one negative pressure wound therapy and kremlin kit for treating diabetic foot ulcers. San Diego (CA). Blue Sky Medical. 2003:1.
275 Miller MS, Brown R. Use of Blue Sky Medical versatile one negative pressure wound therapy for treating open lower extremity wounds due to venomous spider bites. San Diego (CA). Blue Sky Medical. 2004:1.
276 Miller MS, McDaniel C. Use of Blue Sky Medical versatile one negative pressure wound therapy system and miller dermivex drain to treat large post-amputation stump wounds. San Diego (CA). Blue Sky Medical. 2004:1.
277 Miller MS, McDaniel C. Treating a pilonidal cystectomy abscess wound with the Blue Sky Medical versatile 1 negative pressure wound therapy. Carlsbad (CA). Blue Sky Medical. 2005:1.
278 Miller MS, McDaniel C. Treating post surgical dehiscence of thoracic wounds with the Blue Sky Medical versatile 1 negative pressure wound therapy and the miller dermivex drain. La Costa (CA). Blue Sky Medical. 2005:1.
279 Miller MS, McDaniel C. Use of the versatile one negative pressure wound therapy and miller dermivex drain for treating open extremity wounds due to venomous insect bites. La Costa (CA). Blue Sky Medical. 2005:1.
280 Miller MS, McDaniel C. Treating difficult diabetic foot wounds with the Blue Sky Medical versatile 1 negative pressure wound therapy system -- a case series of three. San Diego (CA). Blue Sky Medical. 2006:1.
281 Miller PR, Thompson JT, Faler BJ, Meredith JW, Chang MC. Late fascial closure in lieu of ventral hernia: the next step in open abdomen management. J Trauma. Nov. 2002;53(5):843-849. [pmid: 12435933].
282 Miller PR, Meredith JW, Johnson JC, Chang MC. Prospective evaluation of vacuum-assisted fascial closure after open abdomen: planned ventral hernia rate is substantially reduced. Ann Surg. May. 2004;239(5):608-614. discussion 614-6. [pmid: 15082964].
283 Miller MS, Whinney R, McDaniel C, Brown R. Use of Blue Sky Medical versatile one negative pressure wound therapy and miller dermivex drain for treating deep tunneling wounds. San Diego (CA). Blue Sky Medical. 2005:1.
284 Mody GN, Nirmal IA, Duraisamy S, Perakath B. A blinded, prospective, randomized controlled trial of topical negative pressure wound closure in India. Ostomy Wound Manage. Dec. 2008;54(12):36-46. [pmid: 19104122].
285 Moues CM, van den Bemd GJ, Meerding WJ, Hovius SE. An economic evaluation of the use of TNP on full-thickness wounds. J Wound Care. May. 2005;14(5):224-227. [pmid: 15909439].
286 Nelson EA. Vacuum assisted closure for chronic wounds: a review of the evidence. EWMA J. Oct. 2007;7(3):5-11.
287 NHS Quality Improvement Scotland. Vacuum assisted closure (VAC) for wound healing. Glasgow. NHS Quality Improvement Scotland. Nov. 2003:1. (Evidence note; no. 5).
288 Niehuser ME. Negative pressure therapy dressing application in a patient with Fournier's gangrene [2241]. WOCN Society 40th Annual Conference. June 21-25, 2008. Mt. Laurel (NJ). Wound, Ostomy and Continence Nurses Society (WOCN). 2008.
289 The effectiveness of V.A.C. therapy with or without hyperbaric oxygen therapy in the treatment of diabetic foot ulcers in an outpatient setting. A team approach: diabetic limb salvage, Georgetown University Hospital. Sep 18-20, 2008. Washington, DC. Lafayette (LA). International Conference Management. 2008.
290 Evaluation of health-care utilization and costs for hospitalizations and surgical procedures in patients with diabetic foot ulcers treated with V.A.C. therapy versus advanced moist wound therapy. A team approach: diabetic limb salvage, Georgetown University Hospital. Sep 18-20, 2008. Washington, DC. Lafayette (LA). International Conference Management. 2008.
291 Noridian. Negative pressure wound therapy. Baltimore (MD). Centers for Medicare & Medicaid Services (CMS). Nov. 18. 2008:7.
292 O’Keefe SK, Gutta R. Management of complex avulsive scalp injuries with vacuum-assisted skin grafting [poster 082]. AAOMS 90TH annual meeting. Sep 16-20, 2008. Seattle, WA. Rosemont (IL). American Association of Oral and Maxillofacial Surgeons (AAOMS). 2008.
293 Olejnik J, Vokurka J, Vician M. Acute necrotizing pancreatitis: Intra-abdominal vacuum sealing after necrosectomy. Hepatogastroenterology. Mar. 2008;55(82-83):315-318. [pmid: 18613356].
294 Oomen JWPM, Spauwen PHM, Bleichrodt RP, Goor H. Guideline proposal to reconstructive surgery for complex perineal sinus or rectal fistula. Int J Colorectal Dis. Feb. 2007;22(2):225-230. [pmid: 16552521].
295 Parker MJ, Livingstone V, Clifton R, McKee A. Closed suction surgical wound drainage after orthopaedic surgery. Cochrane Database of Systematic Reviews [internet]. Hoboken (NJ). John Wiley & Sons, Ltd. 2007;(Issue 3):CD001825. [doi: 10.1002/14651858.CD001825.pub2]. [pmid: 11687125].
296 Parrett BM, Matros E, Pribaz JJ, Orgill DP. Lower extremity trauma: Trends in the management of soft-tissue reconstruction of open tibia-fibula fractures. Plast Reconstr Surg. Apr. 1. 2006;117(4):1315-1322. [pmid: 16582806].
297 Pattison PS, Gordon JK, Muto PM, Mallen JK, Hoerner J. Case report: using dual therapies of a negative pressure wound therapy (NPWT) and modified silicone gel liner to treat a limb postamputation and dehiscence [120]. 38th Annual WOCN Society Conference. June 24-28, 2006. Minneapolis, MN. Mt. Laurel (NJ). Wound, Ostomy and Continence Nurses Society (WOCN). 2006.
298 Peinemann F, McGauran N, Sauerland S, Lange S. Disagreement in primary study selection between systematic reviews on negative pressure wound therapy. BMC Med Res Methodol. 2008;8:41. [pmid: 18582373].
299 Powell CA, Bruch S. Case study: using negative wound therapy to isolate an enterocutaneous fistula from an abdominal wound [1214]. WOCN Society 39th annual conference. June 9-13, 2007. Salt Lake City, UT. Mt. Laurel (NJ). Wound, Ostomy and Continence Nurses Society (WOCN). 2007.
300 Price P, Mendonca D, Drew P, Harding K. Quality of life outcomes in negative wound pressure therapy [abstract 101]. EWMA conference: innovation, education, implementation. Prague, Czech Republic. European Wound Management Association (EWMA). 2006.
301 Pu LL. An alternative approach for soft-tissue coverage of a complex wound in the foot and ankle with vacuum-assisted closure over artificial dermis and subsequent skin graft. J Plast Reconstr Aesthet Surg. 2008. Nov. 20. Epub ahead of print. [pmid: 19027380].
302 Rajzer L, Wojas-Pelc A, Kozka M, Snarska A, Wozniak W, Ozga E, Ignacak E. The management of difficult to heal wounds of lower extremities and using V.A.C. therapy [p016]. EWMA conference: innovation, education, implementation. Prague, Czech Republic. European Wound Management Association (EWMA). 2006.
303 Reddy M, Gill SS, Kalkar SR, Wu W, Anderson PJ, Rochon PA. Treatment of pressure ulcers: A systematic review. JAMA. Dec. 10. 2008;300(22):2647-2662. [pmid: 19066385].
304 Registered Nurses Association of Ontario (RNAO). Assessment and management of foot ulcers for people with diabetes. Toronto (ON). Registered Nurses Association of Ontario (RNAO). Mar. 2005:112.
305 Registered Nurses' Association of Ontario (RNAO). Assessment & management of stage I to IV pressure ulcers. Toronto (ON). Registered Nurses' Association of Ontario (RNAO). Mar. 2007:112.
306 Sachithanandan A, Nanjaiah P, Nightingale P, Wilson IC, Graham TR, Rooney SJ, Keogh BE, Pagano D. Deep sternal wound infection requiring revision surgery: impact on mid-term survival following cardiac surgery. Eur J Cardiothorac Surg. Apr. 2008;33(4):673-678. [pmid: 18243720].
307 Schimmer C, Sommer SP, Bensch M, Leyh R. Primary treatment of deep sternal wound infection after cardiac surgery: a survey of German heart surgery centers. Interact Cardiovasc Thorac Surg. Dec. 2007;6(6):708-711. [pmid: 17884847].
308 Schlatterer D, Hirshorn K. Negative pressure wound therapy with reticulated open cell foam-adjunctive treatment in the management of traumatic wounds of the leg: a review of the literature. J Orthop Trauma. Nov-Dec. 2008;22(10 Suppl):S152-S160. [pmid: 19034163].
309 Schuster R, Singh J, Safadi BY, Wren SM. The use of acellular dermal matrix for contaminated abdominal wall defects: wound status predicts success. Am J Surg. 2006;192(5 Spec Iss):594-597. [pmid: 17071190].
310 Segers P, de Jong AP, Kloek JJ, van der Horst CM, Spanjaard L, de Mol BA. Topical negative pressure therapy in wounds after cardiothoracic surgery: successful experience supported by literature. Thorac Cardiovasc Surg. Aug. 2006;54(5):289-294. [pmid: 16902874].
311 Segers P, de Jong AP, Kloek JJ, Spanjaard L, de Mol BA. Risk control of surgical site infection after cardiothoracic surgery. J Hosp Infect. Apr. 2006;62(4):437-445. [pmid: 16455163].
312 Sibbald RG, Mahoney J. V.A.C. Therapy Canadian Consensus Group. A consensus report on the use of vacuum-assisted closure in chronic, difficult-to-heal wounds. Ostomy Wound Manage. Nov. 2003;49(11):52-66. [pmid: 14652413].
313 Shalom A, Eran H, Westreich M, Friedman T. Our experience with a "Homemade" vacuum-assisted closure system. Isr Med Assoc J. Aug-Sep. 2008;10(9):613-616. [pmid: 18847164].
314 Simek M. Vaccum-assisted closure as a treatment modality for deep sternal infection in cardiac surgery [abstract 100]. EWMA conference: innovation, education, implementation. Prague, Czech Republic. European Wound Management Association (EWMA). 2006.
315 Smith N. The benefits of VAC therapy in the management of pressure ulcers. Br J Nurs. 2004 Dec 9-2005 Jan 12;13(22):1359-1365. [pmid: 15687905].
316 Sposato G, Molea G, Di Caprio G, Scioli M, La Rusca I, Ziccardi P. Ambulant vacuum-assisted closure of skin-graft dressing in the lower limbs using a portable mini-VAC device. Br J Plast Surg. Apr. 2001;54(3):235-237. [pmid: 11254417].
317 Stojkovic C, Smeulders MJ, Van der Horst CM. Wound drainage after plastic and reconstructive surgery of the breast. Cochrane Database of Systematic Reviews [internet]. Hoboken (NJ). John Wiley & Sons, Ltd. 2008;(Issue 3):CD007258. [doi: 10.1002/14651858.CD007258].
318 Strecker T, Rosch J, Horch RE, Weyand M, Kneser U. Sternal wound infections following cardiac surgery: Risk factor analysis and interdisciplinary treatment. Heart Surg Forum. 2007;10(5):258-263.
319 Stremitzer S, Budzanowski A, Hoelzenbein T, Ludwig C, Wild T. Definition of vacuum therapy - Redon vs VAC therapy [p110]. EWMA conference: innovation, education, implementation. Prague, Czech Republic. European Wound Management Association (EWMA). 2006.
320 Suess JJ, Kim PJ, Steinberg JS. Negative pressure wound therapy: evidence-based treatment for complex diabetic foot wounds. Curr Diab Rep. Dec. 2006;6(6):446-450. [pmid: 17118227].
321 Tamir J, Haik J, Winkler E, Zeillig G, Orenstein A. Vacuum assisted skin grafting of chronic ulcers [p130]. EWMA conference: innovation, education, implementation. Prague, Czech Republic. European Wound Management Association (EWMA). 2006.
322 Tamir E, Daniels TR, Finestone A, Nof M. Off-loading of hindfoot and midfoot neuropathic ulcers using a fiberglass cast with a metal stirrup. Foot Ankle Int. Oct. 2007;28(10):1048-1052. [pmid: 17923053].
323 Tanna N, Clary MS, Conrad DE, Lenert J, Sadeghi N. Vacuum-assisted closure for wound dehiscence in head and neck reconstruction. Plast Reconstr Surg. Jan. 2009;123(1):19e-21e. [pmid: 19116512].
324 Téot L, Lambert L, Ourabah Z, Bohbot S. Use of negative pressure wound therapy with a new wound contact layer: results of a clinical evaluation. 20th Annual Symposium on Advanced Wound Care. April 28 - May 1, 2007. Tampa, FL. Libertyville (IL). Hollister Wound Care. 2007.
325 Teot L, Ourabah Z, Bohbot S. Use of topical negative pressure with a new wound contact layer: results of a clinical evaluation [1435]. WOCN Society 39th annual conference. June 9-13, 2007. Salt Lake City, UT. Mt. Laurel (NJ). Wound, Ostomy and Continence Nurses Society (WOCN). 2007.
326 Timmers MS, Le Cessie S, Banwell P, Jukema GN. The effects of varying degrees of pressure delivered by negative-pressure wound therapy on skin perfusion. Ann Plast Surg. Dec. 2005;55(6):665-671. [pmid: 16327472].
327 Timms CG, Murphree RW. Complex wound closure using negative pressure therapy to facilitate granulation and provide a surface for pouching a compromised colostomy site [1215]. WOCN Society 39th Annual Conference. June 9-13, 2007. Salt Lake City, UT. Mt. Laurel (NJ). Wound, Ostomy and Continence Nurses Society (WOCN). 2007.
328 TriCenturion. Negative pressure wound therapy pumps. LMRP database ID number L11500 [internet]. Baltimore (MD). Centers for Medicare & Medicaid Services (CMS). Apr. 1. 2004:11.
329 TriCenturion. Negative pressure wound therapy (NPWT) widespread probe. HCPCS E2402. Columbia (SC). TriCenturion. Jul. 2006:2.
330 TriCenturion. LCD for negative pressure wound therapy pumps (L11500) [internet]. Baltimore (MD). Centers for Medicare & Medicaid Services (CMS). Jun. 1. 2007:12. Available: http://www.medicarenhic.com/dme/medical_review/mr_lcds/mr_lcd_current/L11500_2007-07-01_PA_2006-01.pdf.
331 TriCenturion. Negative pressure wound therapy (NPWT) widespread probe results. Jurisdiction A - final report. Columbia (SC). TriCenturion. Feb. 2007:2.
332 TriCenturion. Widespread quarterly review results for negative pressure wound therapy (NPWT). HCPCS E2402 - Jurisdiction A. Columbia (SC). Tricenturion. Feb. 2008:2.
333 Wainstein DE, Fernandez E, Gonzalez D, Chara O, Berkowski D. Treatment of high-output enterocutaneous fistulas with a vacuum-compaction device. A ten-year experience.[erratum appears in World J Surg. 2008 Mar;32(3):429]. World J Surg. Mar. 2008;32(3):430-435. [pmid: 17899253].
334 Webb M. Use of porcine mesh and NPWT to manage a complex surgical wound with metastatic disease [2263]. WOCN Society 40th Annual Conference. June 21-25, 2008. Orlando, FL. Mt. Laurel (NJ). Wound, Ostomy and Continence Nurses Society (WOCN). 2008.
335 Webb M. Use of PVA and NPWT to remove infection in wound with exposed bone and hardware used for fracture consolidation at one long term care facility after an automobile accident [2264]. WOCN Society 40th Annual Conference. June 21-25, 2008. Orlando, FL. Mt. Laurel (NJ). Wound, Ostomy and Continence Nurses Society (WOCN). 2008.
336 Wild T, Stremitzer S, Budzanowski A, Rinder H, Tamandl D, Zeisel C, Holzenbein T, Sautner T. ["Abdominal dressing" - a new method of treatment for open abdomen following secondary peritonitis]. Zentralbl Chir. May. Suppl 1. 2004;129:S20-S23. (ger). [pmid: 15168277].
337 Witkowski W. Treating complex pressure ulcers with topical negative pressure [158]. 18th EWMA Conference: wound management · wound healing – responsibility and actions. May 14-16, 2008. Lisbon, Portugal. European Wound Management Association (EWMA). 2008.
338 World Union of Wound Healing Societies (WUWHS). Principles of best practice: vacuum-assisted closure: recommendations for use. A consensus document. London. MEP Ltd. 2008:12. Also available: http://wuwhs.org/datas/2_1/11/VAC_English_WEB.pdf.
339 Gabriel A, Shores J, Heinrich C, Baqai W, Kalina S, Sogioka N, Gupta S. Negative pressure wound therapy with instillation: A pilot study describing a new method for treating infected wounds. Int Wound J. Jun. 2008;5(3):399-413. [pmid: 18593390].
340 Korber A, Franckson T, Grabbe S, Dissemond J. Vacuum assisted closure device improves the take of mesh grafts in chronic leg ulcer patients. Dermatology. 2008;216(3):250-256. [pmid: 18204263].
341 Lavery LA, Boulton AJ, Niezgoda JA, Sheehan P. A comparison of diabetic foot ulcer outcomes using negative pressure wound therapy versus historical standard of care. Int Wound J. Jun. 2007;4(2):103-113. [pmid: 17651226].
342 Vidrine DM, Kaler S, Rosenthal EL. A comparison of negative-pressure dressings versus Bolster and splinting of the radial forearm donor site. Otolaryngol Head Neck Surg. Sep. 2005;133(3):403-406. [pmid: 16143190].
343 Kamolz LP, Andel H, Haslik W, Winter W, Meissl G, Frey M. Use of subatmospheric pressure therapy to prevent burn wound progression in human: first experiences. Burns. May. 2004;30(3):253-258. [pmid: 15082354].
344 Bannasch H, Iblher N, Penna V, Torio N, Felmerer G, Stark GB, Momeni A. A critical evaluation of the concomitant use of the implantable Doppler probe and the Vacuum Assisted Closure system in free tissue transfer. Microsurgery. 2008;28(6):412-416. [pmid: 18623161].
345 Brandi C, Grimaldi L, Nisi G, Silvestri A, Brafa A, Calabro M, D'Aniello C. Treatment with vacuum-assisted closure and cryo-preserved homologous de-epidermalised dermis of complex traumas to the lower limbs with loss of substance, and bones and tendons exposure. J Plast Reconstr Aesthet Surg. Dec. 2008;61(12):1507-1511. [pmid: 17993300].
346 Dhir K, Reino AJ, Lipana J. Vacuum-assisted closure therapy in the management of head and neck wounds. Laryngoscope. Dec. 31. 2008;119(1):54-61. [pmid: 19117292].
347 Rhode JM, Burke WM, Cederna PS, Haefner HK. Outcomes of surgical management of stage III vulvar hidradenitis suppurativa. J Reprod Med. Jun. 2008;53(6):420-428. [pmid: 18664060].
348 Rozen WM, Shahbaz S, Morsi A. An improved alternative to vacuum-assisted closure (VAC) as a negative pressure dressing in lower limb split skin grafting: a clinical trial. J Plast Reconstr Aesthet Surg. 2008;61(3):334-337. [pmid: 18267313].
349 Steiert AE, Gohritz A, Schreiber TC, Krettek C, Vogt PM. Delayed flap coverage of open extremity fractures after previous vacuum-assisted closure (VAC) therapy - worse or worth. J Plast Reconstr Aesthet Surg. 2008. Mar. 24. Epub ahead of print. [pmid: 18373969].
350 Bhattacharyya T, Mehta P, Smith M, Pomahac B. Routine use of wound vacuum-assisted closure does not allow coverage delay for open tibia fractures. Plast Reconstr Surg. Apr. 2008;121(4):1263-1266. [pmid: 18349645].
351 Helgeson MD, Potter BK, Evans KN, Shawen SB. Bioartificial dermal substitute: A preliminary report on its use for the management of complex combat-related soft tissue wounds. J Orthop Trauma. Jul. 2007;21(6):394-399. [pmid: 17620998].
352 Labler L, Trentz O. The use of vacuum assisted closure (VAC(trade mark)) in soft tissue injuries after high energy pelvic trauma. Langenbecks Arch Surg. Sep. 2007;392(5):601-609. [pmid: 16983575].
353 Peck MA, Clouse WD, Cox MW, Bowser AN, Eliason JL, Jenkins DH, Smith DL, Rasmussen TE. The complete management of extremity vascular injury in a local population: A wartime report from the 332nd Expeditionary Medical Group/Air Force Theater Hospital, Balad Air Base, Iraq. J Vasc Surg. Jun. 2007;45(6):1197-1205. [pmid: 17543685].
354 Segers P, Kloek JJ, Strackee DS, de Mol BA. Open window thoracostomy: a new therapeutic option using topical negative pressure wound therapy. Wounds. Oct. 2007;19(10):264-269.
355 Senchenkov A, Petty PM, Knoetgen J 3rd, Moran SL, Johnson CH, Clay RP. Outcomes of skin graft reconstructions with the use of Vacuum Assisted Closure (VAC(R)) dressing for irradiated extremity sarcoma defects. World J Surg Oncol. 2007;5:138. [pmid: 18047659].
356 Cothren CC, Moore EE, Johnson JL, Moore JB, Burch JM. One hundred percent fascial approximation with sequential abdominal closure of the open abdomen. Am J Surg. Aug. 2006;192(2):238-242. [pmid: 16860637].
357 Labler L, Zwingmann J, Mayer D, Stocker R, Trentz O, Keel M. V.A.C. Abdominal Dressing System: A temporary closure for open abdomen. Eur J Trauma. Oct. 2005;31(5):488-494.
358 Stoeckel WT, David L, Levine EA, Argenta AE, Perrier ND. Vacuum-assisted closure for the treatment of complex breast wounds. Breast. Nov. 2006;15(5):610-613. [pmid: 16443363].
359 Savolainen H, Widmer MK, Heller G, Makaloski V, Carrel T, Schmidli J. The problematic inguinal wound in vascular surgery - What is the optimal treatment?. Int J Angiol. Dec. 2004;13(4):193-196.
360 Herscovici D Jr, Sanders RW, Scaduto JM, Infante A, DiPasquale T. Vacuum-assisted wound closure (VAC therapy) for the management of patients with high-energy soft tissue injuries. J Orthop Trauma. 2003;17(10):683-688. [pmid: 14600567].
361 Ennker IC, Pietrowski D, Vohringer L, Kojcici B, Albert A, Vogt PM, Ennker J. Surgical debridement, vacuum therapy and pectoralis plasty in poststernotomy mediastinitis. J Plast Reconstr Aesthet Surg. 2008. Nov. 6. Epub ahead of print. [pmid: 18996074].
362 Fleck T, Kickinger B, Moidl R, Waldenberger F, Wolner E, Grabenwoger M, Wisser W. Management of open chest and delayed sternal closure with the vacuum assisted closure system: Preliminary experience. Interact Cardiovasc Thorac Surg. Oct. 2008;7(5):801-804. [pmid: 18541606].
363 Hamed O, Muck PE, Smith JM, Krallman K, Griffith NM. Use of vacuum-assisted closure (VAC) therapy in treating lymphatic complications after vascular procedures: new approach for lymphoceles. J Vasc Surg. Dec. 2008;48(6):1520-1523. 1523.e1. 1523.e4. [pmid: 19118737].
364 Labanaris AP, Polykandriotis E, Horch RE. The effect of vacuum-assisted closure on lymph vessels in chronic wounds. J Plast Reconstr Aesthet Surg. 2008. Jun. 2. [pmid: 18524708].
365 Lopez G, Clifton-Koeppel R, Emil S. Vacuum-assisted closure for complicated neonatal abdominal wounds. J Pediatr Surg. Dec. 2008;43(12):2202-2207. [pmid: 19040935].
366 Mokhtari A, Sjogren J, Nilsson J, Gustafsson R, Malmsjo M, Ingemansson R. The cost of vacuum-assisted closure therapy in treatment of deep sternal wound infection. Scand Cardiovasc J. 2008;42(1):85-89. [pmid: 18273735].
367 Shrestha BM, Nathan VC, Delbridge MS, Parker K, Throssell D, McKane WS, Karim MS, Raftery AT. Vacuum-assisted closure (VAC) therapy in the management of wound infection following renal transplantation. Kathmandu Univ Med J (KUMJ). 2007;5(17):4-7. [pmid: 18603977].
368 van Rhee MA, de Klerk LW, Verhaar JA. Vacuum-assisted wound closure of deep infections after instrumented spinal fusion in six children with neuromuscular scoliosis. Spine J. Sep-Oct. 2007;7(5):596-600. [pmid: 17905322].
369 Gorlitzer M, Grabenwoeger M, Meinhart J, Swoboda H, Oczenski W, Fiegl N, Waldenberger F. Descending Necrotizing Mediastinitis Treated With Rapid Sternotomy Followed by Vacuum-Assisted Therapy. Ann Thorac Surg. Feb. 2007;83(2):393-396. [pmid: 17257957].
370 Labler L, Keel M, Trentz O, Heinzelmann M. Wound conditioning by vacuum assisted closure (V.A.C.) in postoperative infections after dorsal spine surgery. Eur Spine J. Sep. 2006;15(9):1388-1396. [pmid: 16835734].
371 Pelham FR, Kubiak EN, Sathappan SS, Di Cesare PE. Topical negative pressure in the treatment of infected wounds with exposed orthopaedic implants. J Wound Care. Mar. 2006;15(3):111-116. [pmid: 16550664].
372 Agarwal JP, Ogilvie M, Wu LC, Lohman RF, Gottlieb LJ, Franczyk M, Song DH. Vacuum-assisted closure for sternal wounds: A first-line therapeutic management approach. Plast Reconstr Surg. Sep. 15. 2005;116(4):1035-1040. [pmid: 16163091].
373 Cowan KN, Teague L, Sue SC, Mahoney JL. Vacuum-assisted wound closure of deep sternal infections in high-risk patients after cardiac surgery. Ann Thorac Surg. Dec. 2005;80(6):2205-2212. [pmid: 16305872].
374 Lee SS, Lin SD, Chen HM, Lin TM, Yang CC, Lai CS, Chen YF, Chiu CC. Management of intractable sternal wound infections with topical negative pressure dressing. J Card Surg. May-Jun. 2005;20(3):218-222. [pmid: 15854081].
375 Mendonca DA, Cosker T, Makwana NK. Vacuum-assisted closure to aid wound healing in foot and ankle surgery. Foot Ankle Int. Sep. 2005;26(9):761-766. [pmid: 16174508].
376 Mehbod AA, Ogilvie JW, Pinto MR, Schwender JD, Transfeldt EE, Wood KB, Le Huec JC, Dressel T. Postoperative deep wound infections in adults after spinal fusion: Management with vacuum-assisted wound closure. J Spinal Disord Tech. 2005;18(1):14-17. [pmid: 15687846].
377 O'Connor J, Kells A, Henry S, Scalea T. Vacuum-assisted closure for the treatment of complex chest wounds. Ann Thorac Surg. Apr. 2005;79(4):1196-1200. [pmid: 15797049].
378 Routledge T, Saeb-Parsy K, Murphy F, Ritchie AJ. The use of vacuum-assisted closure in the treatment of post-transplant wound infections: A case series. J Heart Lung Transplant. 2005;24(9):1444.e15-1444.e16. [pmid: 16143271].
379 Clare MP, Fitzgibbons TC, McMullen ST, Stice RC, Hayes DF, Henkel L. Experience with the Vacuum Assisted Closure negative pressure technique in the treatment of non-healing diabetic and dysvascular wounds. Foot Ankle Int. Oct. 1. 2002;23(10):896-901. [pmid: 12398140].
380 Fleck TM, Fleck M, Moidl R, Czerny M, Koller R, Giovanoli P, Hiesmayer MJ, Zimpfer D, Wolner E, Grabenwoger M. The vacuum-assisted closure system for the treatment of deep sternal wound infections after cardiac surgery. Ann Thorac Surg. Nov. 1. 2002;74(5):1596-1600. [pmid: 12440614].
381 Gustafsson R, Johnsson P, Algotsson L, Blomquist S, Ingemansson R. Vacuum-assisted closure therapy guided by C-reactive protein level in patients with deep sternal wound infection. J Thorac Cardiovasc Surg. May. 2002;123(5):895-900. [pmid: 12019374].
382 Deva AK, Buckland GH, Fisher E, Liew SC, Merten S, McGlynn M, Gianoutsos MP, Baldwin MA, Lendvay PG. Topical negative pressure in wound management. Med J Aust. Aug. 7. 2000;173(3):128-131. [pmid: 10979377].
383 Gabriel A, Heinrich C, Shores J, Cho D, Baqai W, Moores D, Miles D, Gupta S. Outcomes of vacuum-assisted closure for the treatment of wounds in a paediatric population: case series of 58 patients. J Plast Reconstr Aesthet Surg. 2008. Oct. 2. Epub ahead of print. [pmid: 18835547].
384 Wada A, Ferreira MC, Tuma P Jr, Arrunategui G. Experience with local negative pressure (vacuum method) in the treatment of complex wounds. Sao Paulo Med J. 2006;124(3):150-153. [pmid: 17119692].
385 Antony S, Terrazas S. A retrospective study: Clinical experience using vacuum-assisted closure in the treatment of wounds. J Natl Med Assoc. 2004;96(8):1073-1077. [pmid: 15303413].
386 Bihariesingh VJ, Stolarczyk EM, Karim RB, van Kooten EO. Plastic solutions for orthopaedic problems. Arch Orthop Trauma Surg. 2004;124(2):73-76. [pmid: 14730453].
387 Loree S, Dompmartin A, Penven K, Harel D, Leroy D. Is Vacuum Assisted Closure a valid technique for debriding chronic leg ulcers?. J Wound Care. Jun. 2004;13(6):249-252. [pmid: 15214145].
388 Molnar JA, DeFranzo AJ, Hadaegh A, Morykwas MJ, Shen P, Argenta LC. Acceleration of integra incorporation in complex tissue defects with subatmospheric pressure. Plast Reconstr Surg. Apr. 15. 2004;113(5):1339-1346. [pmid: 15060345].
389 Mullner T, Mrkonjic L, Kwasny O, Vecsei V. The use of negative pressure to promote the healing of tissue defects: a clinical trial using the vacuum sealing technique. Br J Plast Surg. Apr. 1997;50(3):194-199. [pmid: 9176007].
390 Abai B, Zickler RW, Pappas PJ, Lal BK, Padberg FT Jr. Lymphorrhea responds to negative pressure wound therapy. J Vasc Surg. Mar. 2007;45(3):610-613. [pmid: 17321350].
391 Agrawal S, Hayhurst C, Joseph T, Prinsloo D, Morgan RH, Pherwani AD. Successful salvage of infected and exposed non-absorbable mesh following decompressing laparostomy after emergency repair of ruptured abdominal aortic aneurysm using vacuum-assisted closure system. Eur J Vasc Endovasc Surg. Jan. 2008;15(1):1-2.
392 Aguinaga S, Welber A, Stephens S. Positive steps towards negative pressure wound therapy. Medsurg Nurs. Jun. 2007;16(3):181-182. 189. [pmid: 17849925].
393 Alvarez AA, Maxwell GL, Rodriguez GC. Vacuum-assisted closure for cutaneous gastrointestinal fistula management. Gynecol Oncol. Mar. 2001;80(3):413-416. [pmid: 11263943].
394 Andrabi SI, Ahmad J, Rathore MA, Yousaf M. Vacuum assisted closure of laparostomy wounds"a novel technique". J Ayub Med Coll Abbottabad. Jul-Sep. 2007;19(3):89-92. [pmid: 18444599].
395 Andrabi SI, Ahmad J. Negative pressure therapy for laparotomy wounds--a word of caution. J Wound Ostomy Continence Nurs. Jul-Aug. 2007;34(4):425-427. [pmid: 17667090].
396 Andrews BT, Smith RB, Chang KE, Scharpf J, Goldstein DP, Funk GF. Management of the radial forearm free flap donor site with the vacuum-assisted closure (VAC) system. Laryngoscope. Oct. 2006;116(10):1918-1922. [pmid: 17003705].
397 Andrews BT, Smith RB, Hoffman HT, Funk GF. Orocutaneous and pharyngocutaneous fistula closure using a vacuum-assisted closure system. Ann Otol Rhinol Laryngol. Apr. 2008;117(4):298-302. [pmid: 18478840].
398 Andros G, Armstrong DG, Attinger C, Boutlon AJ, Frykberg RG, Joseph WS, Lavery LA, Morbach S, Niezgoda JA, Toursarkissian B. Consensus statement on negative pressure wound therapy (VAC Therapy) for the management of diabetic foot wounds. Wounds. Jun. 2006;52(6 Suppl):1-32.
399 Arca MJ, Somers KK, Derks TE, Goldin AB, Aiken JJ, Sato TT, Shilyansky J, Winthrop A, Oldham KT. Use of vacuum-assisted closure system in the management of complex wounds in the neonate. Pediatr Surg Int. Jul. 2005;21(7):532-535. Epub 2005 Jun 17. [pmid: 15965692].
400 Archdeacon MT, Messerschmitt P. Modern papineau technique with vacuum-assisted closure. J Orthop Trauma. Feb. 2006;20(2):134-137. [pmid: 16462567].
401 Argenta LC, Morykwas MJ, Marks MW, DeFranzo AJ, Molnar JA, David LR. Vacuum-assisted closure: state of clinic art. Plast Reconstr Surg. Jun. 2006;117(7 Suppl):127S-142S. [pmid: 16799380].
402 Argenta PA, Rahaman J, Gretz HF 3rd, Nezhat F, Cohen CJ. Vacuum-assisted closure in the treatment of complex gynecologic wound failures. Obstet Gynecol. Mar. 2002;99(3):497-501. [pmid: 11864680].
403 Armstrong DG, Attinger CE, Boulton AJ, Frykberg RG, Kirsner RS, Lavery LA, Mills JL. Guidelines regarding negative wound therapy (NPWT) in the diabetic foot. Ostomy Wound Manage. Apr. 2004;50(4B Suppl):3S-27S. [pmid: 15311482].
404 Armstrong DG, Boulton AJ, Banwell P. Negative pressure wound therapy in treatment of diabetic foot wounds: a marriage of modalities. Ostomy Wound Manage. Apr. 2004;50(4A Suppl):9-12. [pmid: 15317237].
405 Armstrong DG, Lavery LA. Decreasing foot pressures while implementing topical negative pressure (vacuum-assisted closure) therapy. Int J Low Extrem Wounds. Mar. 2004;3(1):12-15. [pmid: 15866783].
406 Attar KH, Imran D, Iyer S. Vacuum-assisted closure (VAC) therapy in the management of digital pulp defects. Acta Chir Plast. 2007;49(3):75-76. [pmid: 18051587].
407 Aydin U, Ozgenel Y. A simple solution for preventing air leakage in VAC therapy for sacral pressure sores. J Plast Reconstr Aesthet Surg. Oct. 2008;61(10):1267-1269. [pmid: 18586592].
408 Ayello EA, Baranoski S, Morey J. VAC heals complex wounds. Nurs Spectrum (Phila Tri-State). Dec. 2003;15(24):16-17.
409 Azad SM, Allison K, Khwaja N, Moiemen N. Frostbite of the gluteal region. Burns. Nov. 2003;29(7):739-744. [pmid: 14556736].
410 Baharestani M, de Leon J, Mendez-Eastman S, Powell G, Weir D, Niezgoda J, Payne W, Nanney LB, Pelham F, Gupta S. Consensus statement: a practical guide for managing pressure ulcers with negative pressure wound therapy utilizing vacuum-assisted closure. Understanding the treatment algorithm. Adv Skin Wound Care. Jan. 2008;21(Suppl 1):1-20.
411 Baharestani MM, Driver VR, de Leon JM, Gabriel A, Kaplan M, Lantis J, Lavery L, Pelham F, Powell G, Webb LX. Optimizing clinical and cost effectiveness with early intervention of v.a.C.(R) therapy. Ostomy Wound Manage. Nov. 2008;54(11):1-15.
412 Baharestani MM. Negative pressure wound therapy: an examination of cost-effectiveness. Ostomy Wound Manage. Nov. 2004;50(11A Suppl):29S-33S. [pmid: 15632465].
413 Ballard K, McGregor F. Use of vacuum-assisted closure therapy following foot amputation. Br J Nurs. Aug. 2001;10(15 Suppl):S6-S12. [pmid: 11923716].
414 Banwell PE, Ahmed S, Teot L. Topical negative pressure versus closed surgical wound drainage: a difference in philosophy. J Wound Care. Oct. 2005;14(9):445-447. [pmid: 16240627].
415 Banwell PE, Musgrave M. Topical negative pressure therapy: mechanisms and indications. Int Wound J. Jun. 2004;1(2):95-106. [pmid: 16722882].
416 Banwell PE, Teot L. Topical negative pressure (TNP): the evolution of a novel wound therapy. J Wound Care. Jan. 2003;12(1):22-28. [pmid: 12572233].
417 Banwell PE. Topical negative pressure therapy in wound care. J Wound Care. Feb. 1999;8(2):79-84. [pmid: 10232203].
418 Banwell PE. Topical negative pressure wound therapy: advances in burn wound management. Ostomy Wound Manage. Nov. 2004;50(11A Suppl):9S-14S. [pmid: 15632460].
419 Baxandall T. Tissue viability. Healing cavity wounds with negative pressure. Nurs Stand. Oct. 30. 1996;11(6):49-51. [pmid: 8998055].
420 Baynham SA, Kohlman P, Katner HP. Treating stage IV pressure ulcers with negative pressure therapy: a case report. Ostomy Wound Manage. Apr. 1999;45(4):28-32. 34. 35. [pmid: 10347508].
421 Benbow M, Beldon P, Butcher M, Newton H, Hampton S, Baxter H. Topical negative pressure: a systematic review of the available evidence. J Community Nurs. Jun. 2007;21(6):18. 20. 22 passim.
422 Benbow M. Update on VAC therapy. Journal of Community Nursing-Online. 2006. Apr. [accessed 2006 Nov 15]. Available: http://www.jcn.com.uk/.
423 Bennett W. Novel use of VAC therapy in a patient with lymphocele after varicose surgery. Wounds UK. Dec. 2007;3(4):129-132.
424 Bernstein BH, Tam H. Combination of subatmospheric pressure dressing and gravity feed antibiotic instillation in the treatment of post-surgical diabetic foot wound: a case series. Wounds. Feb. 2005;17(2):37-48.
425 Bertelsen CA, Wille-Jorgensen P. Use of topical negative pressure to manage a complex wound with a vesicocutaneous fistula. J Wound Care. Apr. 2006;15(4):172-173. [pmid: 16620047].
426 Birchall L, Street L, Clift H. Developing a trust-wide centralised approach to the use of TNP. J Wound Care. Sep. 2002;11(8):311-314. [pmid: 12360765].
427 Blackburn JH 2d, Boemi L, Hall WW, Jeffords K, Hauck RM, Banducci DR, Graham WP 3d. Negative-pressure dressings as a bolster for skin grafts. Ann Plast Surg. May. 1998;40(5):453-457. [pmid: 9600426].
428 Bolton L. Evidence corner: negative pressure wound therapy. Wounds. Apr. 2005;17(4):A29-A32.
429 Bonnet F, Pavy B, Beaudoin S, Dubousset J, Mitrofanoff M. Treatment of a large defect of the chest wall in a child using a negative pressure wound dressing. Scand J Plast Reconstr Surg Hand Surg. 2007;41(3):143-145. [pmid: 17486521].
430 Bookout K, McCord S, McLane K. Case studies of an infant, a toddler, and an adolescent treated with a negative pressure wound treatment system. J Wound Ostomy Continence Nurs. Jul-Aug. 2004;31(4):184-192. [pmid: 15851860].
431 Brace JA. Negative pressure wound therapy for abdominal wounds. J Wound Ostomy Continence Nurs. Jul-Aug. 2007;34(4):428-430. [pmid: 17667091].
432 Brogna L. Home care management of an ostomy within a dehisced abdominal wound. J Wound Ostomy Continence Nurs. May-Jun. 2005;32(3):200-202. discussion 202-4. [pmid: 15931151].
433 Bronchard R, de Vaumas C, Lasocki S, Jabbour K, Geffroy A, Kermarrec N, Montravers P. Vacuum-assisted closure in the treatment of perineal necrotizing skin and soft tissue infections. Intensive Care Med. Jul. 2008;34(7):1345-1347. [pmid: 18389219].
434 Bronson N, Menon R, Butler J, Gordon I. Parathyroidectomy, excision and skin grafting with topical negative pressure for calciphylactic ulcers. J Wound Care. Jul. 2007;16(7):295-297. [pmid: 17708379].
435 Brown KM, Harper FV, Aston WJ, O'Keefe PA, Cameron CR. Vacuum-assisted closure in the treatment of a 9-year-old child with severe and multiple dog bite injuries of the thorax. Ann Thorac Surg. Oct. 2001;72(4):1409-1410. [pmid: 11603487].
436 Burton L. Nonhealing foot ulcer. Ostomy Wound Manage. Sep. 1999;45(9):20-21. [pmid: 10655872].
437 Canavese F, Gupta S, Krajbich JI, Emara KM. Vacuum-assisted closure for deep infection after spinal instrumentation for scoliosis. J Bone Joint Surg Br. Mar. 2008;90(3):377-381. [pmid: 18310764].
438 Canter HI, Isci E, Erk Y. Vacuum-assisted wound closure for the management of a foot ulcer due to Buerger's disease. J Plast Reconstr Aesthet Surg. 2007. Nov. 1. Epub ahead of print. [pmid: 17980686].
439 Carson SN, Overall K, Lee-Jahshan S, Travis E. Vacuum-assisted closure used for healing chronic wounds and skin grafts in the lower extremities. Ostomy Wound Manage. Mar. 2004;50(3):52-58. [pmid: 15206090].
440 Chandawarkar RY, Piorkowski J, Amjad I, Deckers PJ. Combination therapy of a large, recurrent keloid. Dermatol Surg. Feb. 2007;33(2):229-235. [pmid: 17300611].
441 Chaouat M, Bonnet F, Seroussi D, Smarrito S, Mimoun M. Topical negative pressure for the treatment of complex cavity wounds associated with osteitis. J Wound Care. Jul. 2006;15(7):292-294. [pmid: 16869195].
442 Chariker ME, Jeter KF, Tintle TE, Bottsford JE. Effective management of incisional and cutaneous fistulae with close suction wound drainage. Contemp Surg. Jun. 1989;34:59-63.
443 Chave H, Ahmed S, Fu B, Webber J, Banwell P, Tiernan E. Salvage of infected dermal collagen implants with topical negative pressure therapy. J Wound Care. Apr. 2006;15(4):156-158. [pmid: 16620044].
444 Chen SZ, Li J, Li XY, Xu LS. Effects of Vacuum-assisted Closure on Wound Microcirculation: An Experimental Study. Asian J Surg. Jul. 2005;28(3):211-217. [pmid: 16024319].
445 Chesher E. Use of vacuum-assisted closure in the community. Prim Intent. Feb. 1998;6(1):12-15.
446 Chester DL, Waters R. Adverse alteration of wound flora with topical negative-pressure therapy: a case report. Br J Plast Surg. Sep. 2002;55(6):510-511. [pmid: 12479427].
447 Childress B, Stechmiller JK, Schultz GS. Arginine metabolites in wound fluids from pressure ulcers: a pilot study. Biol Res Nurs. Oct. 2008;10(2):87-92. [pmid: 18829591].
448 Chung CJ, David LR, Morykwas M, Argenta L. Case review: management of life-threatening sepsis and wound healing in a Klippel-Trenaunay patient using serial surgical debridements and vaccum-assisted closure. Eur J Plastic Surg. Jul. 2003;26(4):214-216.
449 Coggrave M, West H, Leonard B. Topical negative pressure for pressure ulcer management. Br J Nurs. Mar. 2002;11(6 Suppl):S29-S36. [pmid: 11979189].
450 Colwell AS, Donaldson MC, Belkin M, Orgill DP. Management of Early Groin Vascular Bypass Graft Infections with Sartorius and Rectus Femoris Flaps. Ann Plast Surg. 2004;52(1):49-53. [pmid: 14676699].
451 Copson D. Topical negative pressure and necrotising fasciitis. Nurs Stand. Oct. 22-28. 2003;18(6):71-74. 76. 78 passim. [pmid: 14618897].
452 Cravero L, Taveggia A, Boriani F, Bruschi S, Boriani F. Osteomyelitis: A possible diagnostic mistake after vacuum-assisted therapy. J Plast Reconstr Aesthet Surg. 2006;59(11):1250-1251. [pmid: 17046642].
453 Cresti S, Ouaissi M, Sielezneff I, Chaix JB, Pirro N, Berthet B, Consentino B, Sastre B. Advantage of vacuum assisted closure on healing of wound associated with omentoplasty after abdominoperineal excision: a case report. World J Surg Oncol. Dec. 23. 2008;6(1):136. [pmid: 19102785].
454 Cro C, George KJ, Donnelly J, Irwin ST, Gardiner KR. Vacuum assisted closure system in the management of enterocutaneous fistulae. Postgrad Med J. Jun. 2002;78(920):364-365. [pmid: 12151694].
455 Crumbley DR, Perciballi JA. Negative pressure wound therapy in a contaminated soft-tissue wound. J Wound Ostomy Continence Nurs. Sep-Oct. 2007;34(5):507-512. [pmid: 17876212].
456 Culliford AT 4th, Spector JA, Levine JP. A novel technique for vacuum assisted closure device application in noncontiguous wounds. J Plast Reconstr Aesthet Surg. 2007;60(1):99-100. [pmid: 17126274].
457 Dakin J, Thompson S. Use of topical negative pressure therapy with an abdominal dressing in management of a laparostomy. J Wound Care. Oct. 2006;15(9):386-388. [pmid: 17044352].
458 Datiashvili RO, Knox KR. Negative pressure dressing: an alternative to free tissue transfers?. Wounds. Aug. 2005;17(8):206-212.
459 Davis L, Barker A. Coordination and management of TNP from acute to primary care: overcoming the issues. J Wound Care. Apr. 2006;15(4):169-171. [pmid: 16620046].
460 Davydov YA, Malafeeva EV, Smirnov AP, Flegontov VB. [Vacuum therapy in the treatment of suppurative lactation mastitis]. Vestn Khir Im I I Grek. Sep. 1986;137(11):66-70. (Rus). [pmid: 3824787].
461 Davydov YA, Larichev AB, Abramov AY, Menkov KG. [Concepts for clinical biological management of the wound process in the treatment of purulent wounds using vacuum therapy] translated from Russian. Vestnik Khirurgii. Feb. 1991:132-135. (Rus).
462 Davydov YA, Larichev AB, Menlov KG. [Bacteriologic and cytologic evaluation of vacuum therapy of suppurative wounds]. Vestn Khir Im I I Grek. Oct. 1988;141(10):48-52. (Rus). [pmid: 3242232].
463 de Geus HR, van der Klooster JM. Vacuum-assisted closure in the treatment of large skin defects due to necrotizing fasciitis. Intensive Care Med. Apr. 2005;31(4):601. [pmid: 15666139].
464 de la Torre JI, Martin SA, Oberheu AM, Vasconez LO. Healing a wound with an exposed Herrington rod: a case study. Ostomy Wound Manage. May. 2002;48(5):18-19. [pmid: 12046485].
465 de Weerd L, Kjaeve J, Aghajani E, Elvenes OP. The sandwich design: a new method to close a high-output enterocutaneous fistula and an associated abdominal wall defect. Ann Plast Surg. May. 2007;58(5):580-583. [pmid: 17452848].
466 Dee A. The successful management of a dehisced surgical wound with TNP following femoropopliteal bypass. J Wound Care. Jan. 2007;16(1):42-44. [pmid: 17334148].
467 DeFranzo AJ, Marks MW, Argenta LC, Genecov DG. Vacuum-assisted closure for the treatment of degloving injuries. Plast Reconstr Surg. Dec. 1999;104(7):2145-2148. [pmid: 11149782].
468 Demaria R, Giovannini UM, Teot L, Chaptal PA. Using VAC to treat a vascular bypass site infection. J Wound Care. Feb. 2001;10(2):12-13. [pmid: 12964221].
469 Derrick KL, Norbury K, Kieswetter K, Skaf J, McNulty AK. Comparative analysis of global gene expression profiles between diabetic rat wounds treated with vacuum-assisted closure therapy, moist wound healing or gauze under suction. Int Wound J. Dec. 2008;5(5):615-624. [pmid: 19134062].
470 Deva AK, Siu C, Nettle WJ. Vacuum-assisted closure of a sacral pressure sore. J Wound Care. Jul. 1997;6(7):311-312. [pmid: 9325823].
471 Dickie SR, Dorafshar AH, Song DH. Definitive closure of the infected median sternotomy wound: a treatment algorithm utilizing vacuum-assisted closure followed by rigid plate fixation. Ann Plast Surg. Jun. 2006;56(6):680-685. [pmid: 16721085].
472 Dieu T, Leung M, Leong J, Morrison W, Cleland H, Archer B, Oppy A. Too much vacuum-assisted closure. ANZ J Surg. Dec. 2003;73(12):1057-1060. [pmid: 14632906].
473 Dobke MK, Nguyen D, Trott SA. A novel approach to acute infection of the glenohumeral joint following rotator cuff repair? A case series. Wounds. Jun. 2005;17(6):137-140.
474 Donovan DJ, Person DA. Giant eccrine adenocarcinoma of the scalp with intracranial invasion: resection and reconstruction using a vacuum-assisted closure device: technical case report. Neurosurgery. Apr. 2006;58(4 Suppl 2). ONS-E371; discussion ONS-. [pmid: 16575296].
475 Dosluoglu HH, Schimpf DK, Schultz R, Cherr GS. Preservation of infected and exposed vascular grafts using vacuum assisted closure without muscle flap coverage. J Vasc Surg. Nov. 2005;42(5):989-992. [pmid: 16275458].
476 Dunbar A, Bowers DM, Holderness H Jr. Silicone net dressing as an adjunct with negative pressure wound therapy. Ostomy Wound Manage. Apr. 2005;51(4):18. 20. [pmid: 16089053].
477 Durai R, Hoque H, Davies TW. 'Indirect VAC': a novel technique of applying vacuum-assisted closure dressing. J Perioper Pract. Oct. 2008;18(10):437-439. [pmid: 18983066].
478 Duxbury MS, Finlay IG, Butcher M, Lambert AW. Use of a vacuum assisted closure device in pilonidal disease. J Wound Care. Oct. 2003;12(9):355. [pmid: 14601229].
479 Easterlin B, Bromberg W, Linscott J. A novel technique of vacuum assisted wound closure that functions as a delayed primary closure. Wounds. 19(12):331-333.
480 Eberlein T, Fendler H. Case studies of Prospera NPWT. Available: http://www.prospera-npwt.com/clincal_references.htm.
481 Edwards AR. Vacuum device closes gap in wound care. Biomechanics. Dec. 2001;8(12):27-34.
482 Emohare O, Kowal-Vern A, Wiley D, Latenser BA. Vacuum-assisted closure use in calciphylaxis. J Burn Care Rehabil. Mar-Apr. 2004;25(2):161-164. [pmid: 15091142].
483 Ennis WJ. (President, Association for the Advancement of Wound Care). Personal communication. Feb. 5. 2009:2.
484 Erba P, Rieger UM, Pierer G, Kalbermatten DF. Vacuum-assisted closure (VAC) for venous congestion of the nipple-areola complex. J Plast Reconstr Aesthet Surg. Jul. 2008;61(7):852-854. [pmid: 18440887].
485 Erdmann D, Drye C, Heller L, Wong MS, Levin SL. Abdominal wall defect and enterocutaneous fistula treatment with the Vacuum-Assisted Closure (V.A.C.) system. Plast Reconstr Surg. Dec. 2001;108(7):2066-2068. [pmid: 11743402].
486 Espensen EH, Nixon BP, Lavery LA, Armstrong DG. Use of subatmospheric (VAC) therapy to improve bioengineered tissue grafting in diabetic foot wounds. J Am Podiatr Med Assoc. Jul-Aug. 2002;92(7):395-397. [pmid: 12122126].
487 Evans D, Land L. Topical negative pressure for treating chronic wounds: A systemic review. Br J Plast Surg. 2001;54(3):238-242. [pmid: 11254418].
488 Ferdinando E, Guerin L, Jervis AO, Obidigbo H. Negative-pressure wound therapy and external fixation for infection and hematoma after hallux abducto valgus surgery. J Am Podiatr Med Assoc. Sep-Oct. 2007;97(5):410-414. [pmid: 17901348].
489 Ferreira MC, Wada A, Tuma Jr P. The vacuum assisted closure of complex wounds: report of 3 cases. Rev Hosp Clin Fac Med Sao Paulo. Jul-Aug. 2003;58(4):227-230. [pmid: 14534677].
490 Fette A. Treatment of pressure ulcers with topical negative pressure versus traditional wound management methods: a research sampler. Plast Surg Nurs. Oct-Dec. 2005;25(4):176-180. [pmid: 16361965].
491 Fife CE, Otto G, Walker D, Turner T, Smith L. Healing dehisced surgical wounds with negative pressure wound therapy. Ostomy Wound Manage. Apr. 2004;50(4A Suppl):28-31. [pmid: 15317243].
492 Fischer JE. A cautionary note: the use of vacuum-assisted closure systems in the treatment of gastrointestinal cutaneous fistula may be associated with higher mortality from subsequent fistula development. Am J Surg. Jul. 2008;196(1):1-2. [pmid: 18355795].
493 Fitzmaurice M, Lawson D, Friedman H. A novel approach for the application of the vacuum assisted closure device to the difficult anatomy. J Plast Reconstr Aesthet Surg. 2006;59(11):1249-1250. [pmid: 17046640].
494 Flack S, Apelqvist J, Keith M, Trueman P, Williams D. An economic evaluation of VAC therapy compared with wound dressings in the treatment of diabetic foot ulcers. J Wound Care. Feb. 2008;17(2):71-78. [pmid: 18389832].
495 Fleck T, Gustafsson R, Harding K, Ingemansson R, Lirtzman MD, Meites HL, Moidl R, Price P, Ritchie A, Salazar J, Sjogren J, Song DH, Sumpio BE, Toursarkissian B, Waldenberger F, Wetzel-Roth W. The management of deep sternal wound infections using vacuum assisted closure (V.A.C.) therapy. Int Wound J. Dec. 2006;3(4):273-280. [pmid: 17199763].
496 Fleck T, Moidl R, Giovanoli P, Aszmann O, Bartunek A, Blacky A, Grabenwoger M, Wolner E. A conclusion from the first 125 patients treated with the vacuum assisted closure system for postoperative sternal wound infection. Interact Cardiovasc Thorac Surg. Apr. 2006;5(2):145-148. [pmid: 17670536].
497 Fleck T, Simon P, Burda G, Wolner E, Wollenek G. Vacuum assisted closure therapy for the treatment of sternal wound infections in neonates and small infants. Interact Cardiovasc Thorac Surg. Jun. 2006;5(3):285-288. [pmid: 17670570].
498 Fleck TM, Koller R, Giovanoli P, Moidl R, Czerny M, Fleck M, Wolner E, Grabenwoger M. Primary or delayed closure for the treatment of poststernotomy wound infections. Ann Plast Surg. Mar. 2004;52(3):310-314. [pmid: 15156988].
499 Fleischmann W, Strecker W, Bombelli M, Kinzl L. [Vacuum sealing as treatment of soft tissue damage in open fractures. Unfallchirurg. Sep. 1993;96(9):488-492. [pmid: 8235687].
500 Ford SJ, Rathinam S, King JE, Vaughan R. Tuberculous osteomyelitis of the sternum: successful management with debridement and vacuum assisted closure. Eur J Cardiothorac Surg. Oct. 2005;28(4):645-647. [pmid: 16179195].
501 Ford-Dunn S. Use of vacuum assisted closure therapy in the palliation of a malignant wound. Palliat Med. Jun. 2006;20(4):477-478. [pmid: 16875120].
502 Fox A, Tadros A, Perks AG. An unusual complication of Vacuum Assisted Closure in the treatment of a pressure ulcer. J Wound Care. Sep. 2004;13(8):344-345. [pmid: 15469221].
503 Fox MP, Fazal MA, Ware HE. Vacuum assisted wound closure. A new method for control of wound problems in total knee arthroplasty. J Bone Joint Surg Br. Jan. Suppl 1. 2000;82-B:19.
504 Fredeking AE, Silverman RA. Successful treatment of trigeminal trophic syndrome in a 6-year-old boy with negative pressure wound therapy. Arch Dermatol. Aug. 2008;144(8):984-986. [pmid: 18711069].
505 Friedman T, Westreich M, Shalom A. Vacuum-assisted closure treatment complicated by anasarca. Ann Plast Surg. Oct. 2005;55(4):420-421. [pmid: 16186711].
506 Froiland KG. Nursing interventions in oncology complex wound care: use of negative pressure therapy for wound healing in an ovarian cancer patient [internet]. accessed 2001 Oct 23. Available: http://www.thecancergroup.org/kathrynfroiland.htm.
507 Frykberg F. When is NPWT appropriate for amputation wounds?. APMA News. May. 2005;26(5 Suppl):20-23.
508 Frykberg RG, Williams DV. Negative-pressure wound therapy and diabetic foot amputations: a retrospective study of payer claims data. J Am Podiatr Med Assoc. Sep-Oct. 2007;97(5):351-359. [pmid: 17901338].
509 Gabriel A, Gollin G. Management of complicated gastroschisis with porcine small intestinal submucosa and negative pressure wound therapy. J Pediatr Surg. Nov. 2006;41(11):1836-1840. [pmid: 17101354].
510 Gabriel A, Heinrich C, Shores JT, Baqui WK, Rogers FR, Gupta S. Reducing bacterial bioburden in infected wounds with vacuum assisted closure and a new silver dressing - a pilot study. Wounds. Sep. 2006;18(9):245-255.
511 Geller S. A closer look at NPWT in the wound care clinic setting. APMA News. May. 2005;26(5 Suppl):43-45.
512 Geller S. How to use NPWT successfully in the home care setting. APMA News. May. 2005;26(5 Suppl):33-34.
513 Geller SM, Longton JA. Ulceration of pyoderma gangrenosum treated with negative pressure wound therapy. J Am Podiatr Med Assoc. Mar-Apr. 2005;95(2):171-174. [pmid: 15778477].
514 Gerry R, Kwei S, Bayer L, Breuing KH. Silver-impregnated vacuum-assisted closure in the treatment of recalcitrant venous stasis ulcers. Ann Plast Surg. Jul. 2007;59(1):58-62. [pmid: 17589262].
515 Ghersi MM, Ricotti C, Nousari CH, Newman MI. Negative pressure dressing in the management of pyoderma gangrenosum ulcer. Arch Dermatol. Oct. 2007;143(10):1249-1251. [pmid: 17938337].
516 Gomoll AH, Lin A, Harris MB. Incisional vacuum-assisted closure therapy. J Orthop Trauma. Nov-Dec. 2006;20(10):705-709. [pmid: 17106382].
517 Goverman J, Yelon JA, Platz JJ, Singson RC, Turcinovic M. The "Fistula VAC," a technique for management of enterocutaneous fistulae arising within the open abdomen: report of 5 cases. J Trauma. Feb. 2006;60(2):428-431. discussion 431. [pmid: 16508512].
518 Greene AK, Puder M, Roy R, Arsenault D, Kwei S, Moses MA, Orgill DP. Microdeformational wound therapy: effects on angiogenesis and matrix metalloproteinases in chronic wounds of 3 debilitated patients. Ann Plast Surg. Apr. 2006;56(4):418-422. [pmid: 16557076].
519 Greer s, Sims CD, Borud L, Thorne C, Kasabian A. The use of a subatmospheric pressure dressing to salvage a septic ankle with concomitant osteomyelitis and avert a free flap. Foot Ankle Int. Sep. 1997;18(3):151-156. [pmid: 9116895].
520 Greer SE, Adelman M, Kasabian A, Galiano RD, Scott R, Longaker MT. The use of subatmospheric pressure dressing therapy to close lymphocutaneous fistulas of the groin. Br J Plast Surg. Sep. 2000;53(6):484-487. [pmid: 10927677].
521 Greer SE, Duthie E, Cartolano B, Koehler KM, Maydick-Youngberg D, Longaker MT. Techniques for applying subatmospheric pressure dressing to wounds in difficult regions of anatomy. J Wound Ostomy Continence Nurs. Sep. 1999;26(5):250-253. [pmid: 10795208].
522 Greer SE, Longaker MT, Margiotta M, Mathews AJ, Kasabian A. The use of subatmospheric pressure dressing for the coverage of radial forearm free flap donor-site exposed tendon complications. Ann Plast Surg. Nov. 1999;43(5):551-554. [pmid: 10560875].
523 Grimm A, Dimmler A, Stange S, Labanaris A, Sauer R, Grabenbauer G, Horch RE. Expression of HIF-1 alpha in irradiated tissue is altered by topical negative-pressure therapy. Strahlenther Onkol. Mar. 2007;183(3):144-149. [pmid: 17340073].
524 Gudbjartsson T, Sigurdsson HK, Sigurdsson E, Kjartansson J. Vacuum-assisted closure for successful treatment of a major contaminated gunshot chest-wound: A case report. Eur J Trauma Emerg Surg. 2008. July. 25. Epub.
525 Gunn LA, Follmar KE, Wong MS, Lettieri SC, Levin LS, Erdmann D. Management of enterocutaneous fistulas using negative-pressure dressings. Ann Plast Surg. Dec. 2006;57(6):621-625. [pmid: 17122546].
526 Gupta S, Gabriel A, Shores J. The perioperative use of negative pressure wound therapy in skin grafting. Ostomy Wound Manage. Apr. 2004;50(4A Suppl):32-34. [pmid: 15317244].
527 Guzzo J, Bluman EM. Technique tip: easing subatmospheric wound dressing application and increasing sponge conformity. Foot Ankle Int. May. 2007;28(5):638-639. [pmid: 17559777].
528 Gwan-Nulla DN, Casal RS. Toxic shock syndrome associated with the use of the vacuum-assisted closure device. Ann Plast Surg. Nov. 2001;47(5):552-554. [pmid: 11716269].
529 Hallock GG, Cipolle MD, Bradow BP. Enterocutaneous fistula associated with an unrecognized retained vacuum-assisted closure sponge. Plast Reconstr Surg. Aug. 2008;122(2):84e-85e. [pmid: 18626332].
530 Hanasono MM, Skoracki RJ. Securing skin grafts to microvascular free flaps using the vacuum-assisted closure (VAC) device. Ann Plast Surg. May. 2007;58(5):573-576. [pmid: 17452846].
531 Hardcastle MR. The application of negative pressure in wound healing. Prim Intent. Feb. 1998:5-10.
532 Hardwicke J, Paterson P. A role for vacuum-assisted closure in lower limb trauma: a proposed algorithm. Int J Low Extrem Wounds. Jun. 2006;5(2):101-104. [pmid: 16698913].
533 Harlan JW. Treatment of open sternal wounds with the vacuum-assisted closure system: a safe, reliable method. Plast Reconstr Surg. Feb. 2002;109(2):710-712. [pmid: 11818858].
534 Hartnett JM. Use of vacuum-assisted wound closure in three chronic wounds. J Wound Ostomy Continence Nurs. Nov. 1998;25(6):281-290. [pmid: 9919143].
535 Hersh RE, Kaza AK, Long SM, Fiser SM, Drake DB, Tribble CG. A technique for the treatment of sternal infections using the Vacuum Assisted Closure device. Heart Surg Forum. 2001;4(3):211-215. [pmid: 11673139].
536 Heugel JR, Parks KS, Christie SS, Pulito JF, Zegzula DH, Kemalyan NA. Treatment of the exposed achilles tendon using negative pressure wound therapy: a case report. J Burn Care Rehabil. May-Jun. 2002;23(3):167-171. [pmid: 12032366].
537 Heuser M, Laabs SO, Plothe KD. Extraperitoneal bladder leakage after provision of topical negative therapy: a case report. J Wound Care. Oct. 2005;14(9):406. [pmid: 16240618].
538 Hopf HW, Ueno C, Aslam R, Burnand K, Fife C, Grant L, Holloway A, Iafrati MD, Mani R, Misare B, Rosen N, Shapshak D, Benjamin Slade J Jr, West J, Barbul A. Guidelines for the treatment of arterial insufficiency ulcers. Wound Repair Regen. Nov-Dec. 2006;14(6):693-710. [pmid: 17199834].
539 Huljev D, Kucisec-Tepes N. Necrotizing fascilitis of the abdominal wall as a post-surgical complication: a case report. Wounds. Jul. 2005;17(7):169-177.
540 Humburg J, Holzgreve W, Hoesli I. Negative pressure wound therapy in post-cesarian superficial wound disruption: a report of 3 cases. Wounds. Jun. 2006;18(6):166-169.
541 Hunter S, Langemo D, Hanson D, Anderson J, Thompson P. The use of negative pressure wound therapy. Adv Skin Wound Care. Feb. 2007;20(2):90-95.
542 Hutchinson L, Thompson J. Vacuum-assisted closure: a method of facilitating wound healing. World Counc Enteros Ther J. Jul-Sep. 1999;19(3):17-21.
543 Isago T, Nozaki M, Kikuchi Y, Honda T, Nakazawa H. Effects of different negative pressures on reduction of wounds in negative pressure dressings. J Dermatol. Aug. 2003;30(8):596-601. [pmid: 12928528].
544 Isago T, Nozaki M, Kikuchi Y, Honda T, Nakazawa H. Skin graft fixation with negative-pressure dressings. J Dermatol. Sep. 2003;30(9):673-678. [pmid: 14578557].
545 Iusupov IuN, Epifanov MV. [Active drainage of a wound. Vestn Khir Im I I Grek. Apr. 1987;138(4):42-46. [pmid: 3629844].
546 Jacobs S, Simhaee DA, Marsano A, Fomovsky GM, Niedt G, Wu JK. Efficacy and mechanisms of vacuum-assisted closure (VAC) therapy in promoting wound healing: a rodent model. J Plast Reconstr Aesthet Surg. 2008. Jul. 8. Epub ahead of print. [pmid: 18617451].
547 Jehle KS, Rohatgi A. Use of porcine dermal collagen graft and topical negative pressure on infected open abdominal wounds. J Wound Care. Jan. 2007;16(1):36-37. [pmid: 17334145].
548 Jones SM, Banwell PE, Shakespeare PG. Advances in wound healing: topical negative pressure therapy. Postgrad Med J. Jun. 2005;81(956):353-357. [pmid: 15937199].
549 Josty IC, Ramaswamy R, Laing JH. Vaccum assisted closure: an alternative strategy in the management of degloving injuries of the foot. Br J Plast Surg. Jun. 2001;54(4):363-365. [pmid: 11355997].
550 Kadohama T, Akasaka N, Nagamine A, Nakanishi K, Kiyokawa K, Goh K, Sasajima T. Vacuum-assisted closure for pediatric post-sternotomy mediastinitis: are low negative pressures sufficient. Ann Thorac Surg. Mar. 2008;85(3):1094-1096. [pmid: 18291211].
551 Kang GC, Yam A. Vacuum-assisted closure of a large palmar defect after debriding a midpalmar tuberculous abscess. Int Wound J. Mar. 2008;5(1):45-48. [pmid: 18336379].
552 Kaplan M, Banwell P, Orgill DP, Ivatury RR, Demetriades D, Moore FA, Miller P, Nicholas J, Henry S. Guidelines for the management of the open abdomen. Wounds. Oct. Suppl 1. 2005;17:S1-S24.
553 Kaplan M. Abdominal compartment syndrome. Ostomy Wound Manage. Apr. 2004;50(4A Suppl):20-21. [pmid: 15317240].
554 Kaplan M. Managing the open abdomen. Ostomy Wound Manage. Jan. 1. 2004;50(1A Suppl):C2-8. quiz. [pmid: 14711999].
555 Kaplan M. Negative pressure wound therapy in the management of abdominal compartment syndrome. Ostomy Wound Manage. Nov. 2004;50(11A Suppl):20S-25S. [pmid: 15632463].
556 Kaplan M. Negative pressure wound therapy in the management of abdominal compartment syndrome. Ostomy Wound Manage. Feb. 2005;51(2A Suppl):29-35. [pmid: 15699562].
557 Kaufman MW, Pahl DW. Vacuum-assisted closure therapy: wound care and nursing implications. Dermatol Nurs. Aug. 2003;15(4):317-320. 323. 325. quiz 326. [pmid: 14515610].
558 Kendrick AS, Chase CW. Salvage of an infected breast tissue expander with an implant sizer and negative pressure wound management. Plast Reconstr Surg. Mar. 2008;121(3):138e-139e. [pmid: 18317104].
559 Kennedy A, Van Zant RS. Diverse applications of negative pressure wound therapy: a multiple case report. Physiother Theory Pract. Apr. 2006;22(2):83-90. [pmid: 16703817].
560 Kilbride KE, Cooney DR, Custer MD. Vacuum-assisted closure: A new method for treating patients with giant omphalocele. J Pediatr Surg. Jan. 2006;41(1):212-215. [pmid: 16410135].
561 Kilpadi D, Stechmiller J, Childress B, Cowan L, Comerio M, Kieswetter K, Schultz G. Composition of wound fluid from pressure ulcers treated with negative pressure wound therapy using VAC therapy in home health or extend care patients: a pilot study. Wounds. 2006;18(5):119-126.
562 Kilpadi DV, Feeley TD, Kiel JW. V.A.C. Therapy normalizes vascular response of injured tissue in full-thickness wounds in rabbits. Ann Plast Surg. May. 2007;58(5):555-560. [pmid: 17452843].
563 Kirby JP, Fantus RJ, Ward S, Sanchez O, Walker E, Mellett MM, Maltz SB, Lerner TT. Novel uses of a negative-pressure wound care system. J Trauma. Jul. 2002;53(1):117-121. [pmid: 12131402].
564 Klayman MH, Trowbridge CC, Stammers AH, Wolfgang GL, Zijerdi DA, Bitterly TJ. Autologous platelet concentrate and vacuum-assisted closure device use in a nonhealing total knee replacement. J Extra Corpor Technol. Mar. 2006;38(1):44-7. [pmid: 16637523].
565 Kloth LC. 5 questions-and answers-about negative pressure wound therapy. Adv Skin Wound Care. Sep-Oct. 2002;15(5):226-229. [pmid: 12368712].
566 Koehler C, Niederbichler AD, Jung FJ, Scholz T, Labler L, Perez D, Jandali A, Comber M, Kuenzi W, Wedler V. Wound therapy using the vacuum-assisted closure device: clinical experience with novel indications. J Trauma. Sep. 2008;65(3):722-731. discussion 731. [pmid: 18784590].
567 Kopp J, Kneser U, Bach AD, Horch RE. Buried chip skin grafting in neuropathic diabetic foot ulcers following vacuum-assisted wound bed preparation: enhancing a classic surgical tool with novel technologies. Int J Low Extrem Wounds. Sep. 2004;3(3):168-171. [pmid: 15866810].
568 Kopp J, Strnad V, Bach AD, Sauer R, Horch RE. Vacuum application increases therapeutic safety and allows intensified local radiation treatment of malignant soft-tissue tumors. Strahlenther Onkol. Feb. 2005;181(2):124-130. [pmid: 15702301].
569 Kordasiewicz LM, Schultz RO. A paraplegic with stage IV pressure ulcers: risk factors and wound care. J Wound Ostomy Continence Nurs. Mar. 2003;30(2):84-89. [pmid: 12658236].
570 Kostiuchenok BM, Kolker II, Karlov VA, Ignatenko SN, Samykina TD. [Vacuum treatment in the surgical management of suppurative wounds]. Vestn Khir Im I I Grek. 1986;137(9):18-21. (Rus). [pmid: 3787969].
571 Kovacs LH, Kloeppel M, Papadopulos NA, Reeker W, Biemer E. Necrotizing fasciitis. Ann Plast Surg. Dec. 2001;47(6):680-682. [pmid: 11756845].
572 Kumar S, O'Donnell ME, Khan K, Dunne G, Carey PD, Lee J. Successful treatment of perineal necrotising fasciitis and associated pubic bone osteomyelitis with the vacuum assisted closure system. World J Surg Oncol. 2008;6:67. [pmid: 18577204].
573 Lam WL, Garrido A, Stanley PR. Use of topical negative pressure in the treatment of chronic osteomyelitis. A case report. J Bone Joint Surg Am. Mar. 2005;87(3):622-624. [pmid: 15741632].
574 Langley-Hawthorne C. Economics of negative pressure wound therapy. Ostomy Wound Manage. Apr. 2004;50(4A Suppl):35-37. [pmid: 15317245].
575 Laverty D, DeFranzo A. Negative pressure wound therapy in the management of orthopedic wounds. Ostomy Wound Manage. Nov. 2004;50(11A Suppl):18S-19S. [pmid: 15632462].
576 Lavery L. Disease management programs: can they make a difference?. APMA News. May. 2005;26(5-Suppl):27-29.
577 Lavery L. Treating heel pressure unlcers with NPWT. APMA News. May. 2005;26(5-Suppl):13-15.
578 Lee AT, Fanton GS, McAdams TR. Acute compartment syndrome of the thigh in a football athlete: a case report and the role of the vacuum-assisted wound closure dressing. J Orthop Trauma. Nov-Dec. 2005;19(10):748-750. [pmid: 16314725].
579 Leijnen M, Steenvoorde P, van Doorn L, Zeillemaker AM, da Costa SA, Oskam J. Does VAC increase the risk of venous thromboembolism. J Wound Care. May. 2007;16(5):211-212. [pmid: 17552405].
580 Lemaire V, Brilmaker J, Kerzmann A, Jacquemin D. Treatment of a groin lymphatic fistula with negative pressure wound therapy. Eur J Vasc Endovasc Surg. Oct. 2008;36(4):449-451. [pmid: 18524650].
581 Lemmon JA, Ahmad J, Ghavami A, Bidic SM. Vacuum-assisted closure over an external fixation device. Plast Reconstr Surg. Apr. 2008;121(4):234e-235e. [pmid: 18349619].
582 Lentz S. Use of the vacuum-assisted closure system in management of the gynecologic surgical wound: a case report. J Pelvic Med Surg. Jan. 2002;8(1):53-56.
583 Levin LS. Principles of definitive soft tissue coverage with flaps. J Orthop Trauma. Nov-Dec. 2008;22(10 Suppl):S161-S166. [pmid: 19034164].
584 Liao EC, Breuing KH. Breast mound salvage using vacuum-assisted closure device as bridge to reconstruction with inferolateral AlloDerm hammock. Ann Plast Surg. Aug. 2007;59(2):218-224. [pmid: 17667419].
585 Lindstedt S, Malmsjo M, Gesslein B, Ingemansson R. Evaluation of continuous and intermittent myocardial topical negative pressure. J Cardiovasc Med (Hagerstown). Aug. 2008;9(8):813-819. [pmid: 18607247].
586 Lindstedt S, Malmsjo M, Gesslein B, Ingemansson R. Topical negative pressure effects on coronary blood flow in a sternal wound model. Int Wound J. Oct. 2008;5(4):503-509. [pmid: 19006573].
587 Lindstedt S, Malmsjo M, Ingemansson R. Blood flow changes in normal and ischemic myocardium during topically applied negative pressure. Ann Thorac Surg. Aug. 2007;84(2):568-573. [pmid: 17643636].
588 Lindstedt S, Malmsjo M, Ingemansson R. No hypoperfusion is produced in the epicardium during application of myocardial topical negative pressure in a porcine model. J Cardiothorac Surg. 2007;2:53. [pmid: 18062803].
589 Lindstedt S, Malmsjo M, Sjogren J, Gustafsson R, Ingemansson R. Impact of different topical negative pressure levels on myocardial microvascular blood flow. Cardiovasc Revasc Med. Jan-Mar. 2008;9(1):29-35. [pmid: 18206635].
590 Lindstedt S, Paulsson P, Mokhtari A, Gesslein B, Hlebowicz J, Malmsjo M, Ingemansson R. A compare between myocardial topical negative pressure levels of-25 mmHg and-50 mmHg in a porcine model. BMC Cardiovasc Disord. 2008;8:14. [pmid: 18570679].
591 Literature review on Negative pressure wound therapy submission to AHRQ by the Association for the Advancement of Wound Care (AAWC) [unpublished]. 140.
592 Loos B, Kopp J, Hohenberger W, Horch RE. Post-malignancy irradiation ulcers with exposed alloplastic materials can be salvaged with topical negative pressure therapy (TNP). Eur J Surg Oncol. Sep. 2007;33(7):920-925. [pmid: 17289332].
593 Lopez Almodovar LF, Bustos G, Lima P, Canas A, Paredes I, Buendia JA. Transverse plate fixation of sternum: a new sternal-sparing technique. Ann Thorac Surg. Sep. 2008;86(3):1016-1017. [pmid: 18721609].
594 Lynch JB, Laing AJ, Regan PJ. Vacuum-assisted closure therapy: a new treatment option for recurrent pilonidal sinus disease. Report of three cases. Dis Colon Rectum. Jun. 2004;47(6):929-932. [pmid: 15129309].
595 Maguina P, Kalimuthu R. Posterior rectal hernia after vacuum-assisted closure treatment of sacral pressure ulcer. Plast Reconstr Surg. Jul. 2008;122(1):46e-47e. [pmid: 18594380].
596 Malli S. Keep a close eye on vacuum-assisted wound closure. Nursing. Jul. 2005;35(7):25. [pmid: 15988191].
597 Malmsjo M, Ingemansson R, Sjogren J. Mechanisms governing the effects of vacuum-assisted closure in cardiac surgery. Plast Reconstr Surg. Oct. 2007;120(5):1266-1275. [pmid: 17898599].
598 Mandal A, Addison P, Stewart K, Neligan P. Vacuum-assisted closure therapy on pyoderma gangrenosum. J Plast Surg. Apr. 2006;28(8):529-531.
599 Mandal A. Role of topical negative pressure in pressure ulcer management. J Wound Care. Jan. 2007;16(1):33-35. [pmid: 17334144].
600 Marathe US, Sniezek JC. Use of the vacuum-assisted closure device in enhancing closure of a massive skull defect. Laryngoscope. Jun. 2004;114(6):961-964. [pmid: 15179195].
601 Marsh DJ, Abu-Sitta G, Patel H. The role of vacuum-assisted wound closure in blast injury. Plast Reconstr Surg. May. 2007;119(6):1978-1979. [pmid: 17440412].
602 Matzi V, Lindenmann J, Porubsky C, Neuboeck N, Maier A, Smolle-Juettner FM. Intrathoracic insertion of the VAC device in a case of pleural empyema 20 years after pneumonectomy. Ann Thorac Surg. Nov. 2007;84(5):1762-1764. [pmid: 17954112].
603 McEwan W, Brown TL, Mills SM, Muller MJ. Suction dressings to secure a dermal substitute. Burns. May. 2004;30(3):259-261. [pmid: 15082355].
604 McGuinness JG, Winter DC, O'Connell PR. Vacuum-assisted closure of a complex pilonidal sinus. Dis Colon Rectum. Feb. 1. 2003;46(2):274-276. [pmid: 12576904].
605 Effects of negative pressure wound therapy on cellular energetics in fibroblasts grown in a provisional wound (fibrin) matrix [In Press]. Wound Repair Regen.
606 McNulty AK, Schmidt M, Feeley T, Kieswetter K. Effects of negative pressure wound therapy on fibroblast viability, chemotactic signaling, and proliferation in a provisional wound (fibrin) matrix. Wound Repair Regen. Nov-Dec. 2007;15(6):838-846. [pmid: 18028132].
607 Meara JG, Guo L, Smith JD, Pribaz JJ, Breuing KH, Orgill DP. Vacuum-assisted closure in the treatment of degloving injuries. Ann Plast Surg. Jun. 1999;42(6):589-594. [pmid: 10382793].
608 Mendez-Eastman S. Give stubborn wounds a helping hand. Nursing Made Incredibly Easy. Sep. 2007;5(5):18-20.
609 Mendez-Eastman S. Guidelines for using negative pressure wound therapy. Adv Skin Wound Care. Nov-Dec. 2001;14(6):314-322. quiz 324-5. [pmid: 11794443].
610 Mendez-Eastman S. Negative pressure wound therapy. Plast Surg Nurs. Spring. 1998;18(1):27-29. 33. 37. [pmid: 9592540].
611 Mendez-Eastman S. New treatment for an old problem: negative-pressure wound therapy. Nursing. May. 2002;32(5):58-63. quiz 64. [pmid: 12035656].
612 Mendez-Eastman S. Use of hyperbaric oxygen and negative pressure therapy in the multidisciplinary care of a patient with nonhealing wounds. J Wound Ostomy Continence Nurs. MAR. 1999;26(2):67-76. [pmid: 10373862].
613 Bier's hyperemic treatment in surgery, medicine and the specialties a manual of it's practical application. 2nd ed. Philadelphia. W.B. Saunders Company.
614 Meyer W, Schmieden V. Biers hyperemic treatment. Philadelphia. W.B. Saunders Company. 78-153.
615 Miller Q, Bird E, Bird K, Meschter C, Moulton MJ. Effect of subatmospheric pressure on the acute healing wound. Curr Surg. Mar-Apr. 2004;61(2):205-208. [pmid: 15051265].
616 Molnar JA, DeFranzo AJ, Marks MW. Single-stage approach to skin grafting the exposed skull. Plast Reconstr Surg. Jan. 2000;105(1):174-177. [pmid: 10626988].
617 Molnar JA, Simpson JL, Voignier DM, Morykwas MJ, Argenta LC. Management of an acute thermal injury with subatmospheric pressure. J Burns Wounds. 2005;4:e5. [pmid: 16921410].
618 Molnar JA. Applications of negative pressure wound therapy to thermal injury. Ostomy Wound Manage. Apr. 2004;50(4A Suppl):17-19. [pmid: 15317239].
619 Montecamozzo G, Leopaldi E, Baratti C, Previde P, Ferla F, Pizzi M, Sposato J, Pariani D, Sartani A, Trabucchi E. Incarcerated massive incisional hernia: extensive necrosis of the colon in a very obese patient. Surgical treatment and vacuum-assisted closure therapy: a case report. Hernia. Dec. 2008;12(6):641-643. [pmid: 18427907].
620 Moore K. VAC therapy: interactions in the healing process. Wounds UK. May. 2005;1(1):86-90.
621 Moran SG, Windham ST, Cross JM, Melton SM, Rue LW 3rd. Vacuum-assisted complex wound closure with elastic vessel loop augmentation: a novel technique. J Wound Care. Jun. 2003;12(6):212-213. [pmid: 12838597].
622 Moreno-Coutino G, Estrada-Chavez G, Dominguez-Cherit J. Hip ulcer secondary to foreign body reaction and vacuum-assisted closure therapy: report of a case. Int Wound J. Mar. 2005;2(1):81-83. [pmid: 16722857].
623 Morris GS, Brueilly KE, Hanzelka H. Negative pressure wound therapy achieved by vacuum-assisted closure: Evaluating the assumptions. Ostomy Wound Manage. Jan. 2007;53(1):52-57. [pmid: 17264356].
624 Morton N. Use of topical negative pressure therapy in postoperative dehisced or infected wounds. J Wound Care. Sep. 2004;13(8):346-348. [pmid: 15469222].
625 Morykwas MJ, Argenta LC. Nonsurgical modalities to enhance healing and care of soft tissue wounds. J South Orthop Assoc. Winter. 1997;6(4):279-288. [pmid: 9434249].
626 Morykwas MJ, David LR, Schneider AM, Whang C, Jennings DA, Canty C, Parker D, White WL, Argenta LC. Use of subatmospheric pressure to prevent progression of partial-thickness burns in a swine model. J Burn Care Rehabil. Jan-Feb. 1999;20(1 Pt 1):15-21. [pmid: 9934631].
627 Morykwas MJ, Howell H, Bleyer AJ, Molnar JA, Argenta LC. The effect of externally applied subatmospheric pressure on serum myoglobin levels after a prolonged crush/ischemia injury. J Trauma. Sep. 2002;53(3):537-540. [pmid: 12352493].
628 Morykwas MJ, Kennedy A, Argenta JP, Argenta LC. Use of subatmospheric pressure to prevent doxorubicin extravasation ulcers in a swine model. J Surg Oncol. SEP. 1999;72(1):14-17. [pmid: 10477870].
629 Morykwas MJ, Simpson J, Punger K, Argenta A, Kremers L, Argenta J. Vacuum-assisted closure: state of basic research and physiologic foundation. Plast Reconstr Surg. Jun. 2006;117(7 Suppl):121S-126S. [pmid: 16799379].
630 Motta GJ, Corbett LQ. Impact of an antimicrobial gauze upon bacterial colonies in wounds that require packing. Ostomy Wound Manage. Aug. 2004;50(8):48-62. [pmid: 15356368].
631 Moues CM, van Toorenenbergen AW, Heule F, Hop WC, Hovius SE. The role of topical negative pressure in wound repair: expression of biochemical markers in wound fluid during wound healing. Wound Repair Regen. Jul-Aug. 2008;16(4):488-494. [pmid: 18638266].
632 Nagell CF, Holte K. Treatment of anastomotic leakage after rectal resection with transrectal vacuum-assisted drainage (VAC). A method for rapid control of pelvic sepsis and healing. Int J Colorectal Dis. Oct. 2006;21(7):657-660. [pmid: 16447032].
633 Neubauer G, Ujlaky R. The cost-effectiveness of topical negative pressure versus other wound-healing therapies. J Wound Care. Nov. 2003;12(10):392-393. [pmid: 14648965].
634 Newton H, Benbow M, Hampton S, Beldon P, Butcher M, Baxter H. TNP therapy in the community: findings of a national survey. Wounds UK. Dec. 2006;2(4):31-35.
635 Ng R, Sebastin SJ, Tihonovs A, Peng YP. Hand in glove--VAC dressing with active mobilisation. J Plast Reconstr Aesthet Surg. 2006;59(9):1011-1013. [pmid: 16920602].
636 Nienhuijs SW, Manupassa R, Strobbe LJ, Rosman C. Can topical negative pressure be used to control complex enterocutaneous fistulae. J Wound Care. Oct. 2003;12(9):343-345. [pmid: 14601226].
637 Niezgoda JA, Mendez-Eastman S. The effective management of pressure ulcers. Adv Skin Wound Care. Jan-Feb. Suppl 1. 2006;19:3-15. [pmid: 16565615].
638 Niezgoda JA. Combining negative pressure wound therapy with other wound management modalities. Ostomy Wound Manage. Feb. 2005;51(2A Suppl):36-38. [pmid: 15699563].
639 Niezgoda JA. Incorporating negative pressure therapy into the management strategy for pressure ulcers. Ostomy Wound Manage. Nov. 2004;50(11A Suppl):26-29. [pmid: 15632459].
640 Niezgoda JA. The economic value of negative pressure wound therapy. Ostomy Wound Manage. Feb. 2005;51(2A Suppl):44-47. [pmid: 15699565].
641 No Authors. Position Document: Topical negative pressure in wound management. European Wound Management. May. 2007:1-17.
642 No Authors. Topical negative pressure for chronic wounds?. Drugs and Therapeutics Bulletin. Aug. 2007;45(8):57-61.
643 No Authors. V.A.C. Therapy: Proceedings of the 2nd World Union of Wound Healing Societies Meeting (8-13 July 2004, Paris France). Wounds. Dec. 2004;16(12-Suppl A):1-19.
644 Norbury K, Kieswetter K. Vacuum-assisted closure therapy attenuates the inflammatory response in a porcine acute wound healing model. Wounds. Apr. 2007;19(4):97-106.
645 Norton SE, De Souza B, Marsh D, Moir G. Vacuum-assisted closure (VAC Therapy) and the risk of fluid loss in acute trauma. Ann Plast Surg. Feb. 2006;56(2):194-195. [pmid: 16432331].
646 NPWT Info and history of NPWT. St. Petersburg (FL). Smith & Nephew, Inc. Feb. 2009:13.
647 Nugent N, Lannon D, O'Donnell M. Vacuum-assisted closure - a management option for the burns patient with exposed bone. Burns. May. 2005;31(3):390-393. [pmid: 15774302].
648 Obdeijn MC, de Lange MY, Lichtendahl DH, de Boer WJ. Vacuum-assisted closure in the treatment of poststernotomy mediastinitis. Ann Thorac Surg. Dec. 1999;68(6):2358-2360. [pmid: 10617044].
649 Oczenski W, Waldenberger F, Nehrer G, Kneifel W, Swoboda H, Schwarz S, Fitzgerald RD. Vacuum-assisted closure for the treatment of cervical and mediastinal necrotizing fasciitis. J Cardiothorac Vasc Anesth. Jun. 2004;18(3):336-338. [pmid: 15232816].
650 Orgill DP. Utilizing negative pressure wound therapy on open chest/sternotomy wounds. Ostomy Wound Manage. Nov. 2004;50(11A Suppl):15S-17S. [pmid: 15632461].
651 O'Rourke ME. Vacuum-assisted closure therapy. Clin J Oncol Nurs. Dec. 2006;10(6):825-826. [pmid: 17193949].
652 Ovington LG. 1,2,3 s-t-r-e-t-c-h; vacuum-enhances wound closure. Adv Wound Care. Jan. 1999;(Suppl):125-127.
653 Ozer K, Smith W. A simple technique for applying vacuum-assisted closure therapy over the circular type external fixation device. Ann Plast Surg. Jun. 2006;56(6):693-694. [pmid: 16721088].
654 Page JC. Utilizing NPWT for large soft tissue defects. APMA News. May. 2005;26(5 Suppl):30-32.
655 Pape HC, Webb LX. History of open wound and fracture treatment. J Orthop Trauma. Nov-Dec. 2008;22(10 Suppl):S133-S134. [pmid: 19034158].
656 Patane F, Zingarelli E, Sansone F, Cappuccio G, Rinaldi M. Vacuum-assisted sternal closure after a 'depression induced ischemic test' in severe mediastinitis. J Cardiovasc Med (Hagerstown). Jun. 2008;9(6):622-624. [pmid: 18475132].
657 Patel CT, Kinsey GC, Koperski-Moen KJ, Bungum LD. Vacuum-assisted wound closure. Am J Nurs. Dec. 2000;100(12):45-48. [pmid: 11202784].
658 Pattison PS, Gordon JK, Muto PM, Mallen JK, Hoerner J. Case report: using dual therapies-negative pressure wound therapy and modified silicone gel liner-to treat a limb postamputation and dehiscence. Wounds. Aug. 2005;17(8):233-240.
659 Penn E, Rayment S. Management of a dehisced abdominal wound with VAC therapy. Br J Nurs. 2004 Feb 26-Mar 10;13(4):194-201. [pmid: 15039618].
660 Petersson U, Acosta S, Bjorck M. Vacuum-assisted wound closure and mesh-mediated fascial traction--a novel technique for late closure of the open abdomen. World J Surg. Nov. 2007;31(11):2133-2137. [pmid: 17879112].
661 Petrie N, Potter M, Banwell P. The management of lower extremity wounds using topical negative pressure. Int J Low Extrem Wounds. Dec. 2003;2(4):198-206. [pmid: 15866848].
662 Petzina R, Ugander M, Gustafsson L, Engblom H, Hetzer R, Arheden H, Ingemansson R, Malmsjo M. Topical negative pressure therapy of a sternotomy wound increases sternal fluid content but does not affect internal thoracic artery blood flow: assessment using magnetic resonance imaging. J Thorac Cardiovasc Surg. May. 2008;135(5):1007-1013. [pmid: 18455577].
663 Petzina R, Ugander M, Gustafsson L, Engblom H, Sjogren J, Hetzer R, Ingemansson R, Arheden H, Malmsjo M. Hemodynamic effects of vacuum-assisted closure therapy in cardiac surgery: assessment using magnetic resonance imaging. J Thorac Cardiovasc Surg. May. 2007;133(5):1154-1162. [pmid: 17467423].
664 Phelps JR, Fagan R, Pirela-Cruz MA. A case study of negative pressure wound therapy to manage acute necrotizing fasciitis. Ostomy Wound Manage. Mar. 2006;52(3):54-59. [pmid: 16565526].
665 Philbeck TE Jr, Whittington KT, Millsap MH, Briones RB, Wight DG, Schroeder WJ. The clinical and cost effectiveness of externally applied negative pressure wound therapy in the treatment of wounds in home healthcare Medicare patients. Ostomy Wound Manage. Nov. 1999;45(11):41-50. [pmid: 10687657].
666 Philbeck TE, Schroeder WJ, Whittington KT. Vacuum-assisted closure therapy for diabetic foot ulcers: clinical and cost analyses. Home Health Care Consult. Mar. 2001;8(3):27-34.
667 Pirela-Cruz MA, Machen MS, Esquivel D. Management of large soft-tissue wounds with negative pressure therapy-lessons learned from the war zone. J Hand Ther. Apr-Jun. 2008;21(2):196-202. quiz 203. [pmid: 18436141].
668 Plikaitis CM, Molnar JA. Subatmospheric pressure wound therapy and the vacuum-assisted closure device: basic science and current clinical successes. Expert Rev Med Devices. Mar. 2006;3(2):175-184. [pmid: 16515384].
669 Pollak AN. Use of negative pressure wound therapy with reticulated open cell foam for lower extremity trauma. J Orthop Trauma. Nov-Dec. 2008;22(10 Suppl):S142-S145. [pmid: 19034161].
670 Poulakidas S, Cologne K, Kowal-Vern A. Treatment of frostbite with subatmospheric pressure therapy. J Burn Care Res. Nov-Dec. 2008;29(6):1012-1014. [pmid: 18849842].
671 Poulakidas S, Kowal-Vern A. Facilitating residual wound closure after partial graft loss with vacuum assisted closure therapy. J Burn Care Res. Jul-Aug. 2008;29(4):663-665. [pmid: 18535475].
672 Powell ET 4th. The role of negative pressure wound therapy with reticulated open cell foam in the treatment of war wounds. J Orthop Trauma. Nov-Dec. 2008;22(10 Suppl):S138-S141. [pmid: 19034160].
673 Principles of best practice: vacuum assisted closure: recommendations for use. A consensus document [internet]. The Medical Education Partnership (MEP). 2008. Jun. 10. Available: http://www.mepltd.co.uk/oneoffsdetail.html?p=vaccon.
674 Quah HM, Maw A, Young T, Hay DJ. Vacuum-assisted closure in the management of the open abdomen: a report of a case and initial experiences. J Tissue Viability. Apr. 2004;14(2):59-62. [pmid: 15114928].
675 Ramnarine IR, McLean A, Pollock JC. Vacuum-assisted closure in the paediatric patient with post-cardiotomy mediastinitis. Eur J Cardiothorac Surg. Dec. 2002;22(6):1029-1031. [pmid: 12467837].
676 Rapp SM. Negative pressure wound therapy reduces infections in lower extremity fractures. Orthop Today. Feb. 2008;28(2):54.
677 Reed SF, Novosel TJ, Weireter LJ, Collins JN, Britt RC, Alvey C, Merkh K, Britt LD. A novel technique for vacuum assisted closure on injured tissue or in confined spaces. J Trauma. May. 2008;64(5):1406-1407. [pmid: 18469668].
678 Reed T, Economon D, Wiersema-Bryant L. Colocutaneous fistula management in a dehisced wound: a case study. Ostomy Wound Manage. Apr. 2006;52(4):60-64. 66. [pmid: 16636363].
679 Reid DJ, Linneman P, Lentz CW. Negative pressure dressing to secure skin grafts. Surg Phys Assist. Feb. 2001:9-13.
680 Reisler T. A simple method of securing an interface dressing and vacuum-assisted closure foam pad to difficult wounds. Ann Plast Surg. Aug. 2007;59(2):230-231. [pmid: 17667424].
681 Reitsma AM, Rhodeheaver GT. Effectiveness of a new antimicrobial gauze dressing as a bacterial barrier [internet]. Charlottesville (VA). University of Virginia Health System. 2001. Sep. 1. Available: http://www.kendallhq.com/imageServer.aspx?contentID=7598&contenttype=application/pdf.
682 Renner R, Rogalski C, Friedlein H, Simon JC. [Vacuum therapy in dermatology: a review. J Dtsch Dermatol Ges. Jun. 2006;4(6):468-476. [pmid: 16734836].
683 Repta R, Ford R, Hoberman L, Rechner B. The use of negative-pressure therapy and skin grafting in the treatment of soft-tissue defects over the Achilles tendon. Ann Plast Surg. Oct. 2005;55(4):367-370. [pmid: 16186700].
684 Rhee P, Velmahos GC. Traumatic wounds. Ostomy Wound Manage. Apr. 2004;50(4A Suppl):22-25. [pmid: 15317241].
685 Robson MC, Cooper DM, Aslam R, Gould LJ, Harding KG, Margolis DJ, Ochs DE, Serena TE, Snyder RJ, Steed DL, Thomas DR, Wiersma-Bryant L. Guidelines for the treatment of venous ulcers. Wound Repair Regen. Nov-Dec. 2006;14(6):649-662. [pmid: 17199831].
686 Rosser CJ, Morykwas MJ, Argenta LC, Bare RL. A new technique to manage perineal wounds. Infect Urol. 2000:45-47.
687 Saad SA, Shakov E, Sebastian V, Saad A. The use of wound vacuum-assisted closure (VAC) system in the treatment of recurrent or complex pilonidal cystDisease: experience in 4 adolescent patients. Internet J Surg. Jan. 2007;11(1).
688 Sadat U, Chang G, Noorani A, Walsh SR, Hayes PD, Varty K. Efficacy of TNP on lower limb wounds: a meta-analysis. J Wound Care. Jan. 2008;17(1):45-48. [pmid: 18210955].
689 Saeed MU, Kennedy DJ. A retained sponge is a complication of vacuum-assisted closure therapy. Int J Low Extrem Wounds. Sep. 2007;6(3):153-154. [pmid: 17909174].
690 Saiki Y, Hata M, Akasaka J, Saito T, Tabayashi K. Vacuum-assisted closure system for the treatment of mediastinitis after total aortic arch replacement. Jpn J Thorac Cardiovasc Surg. Dec. 2005;53(12):638-640. [pmid: 16408469].
691 Salazard B, Niddam J, Ghez O, Metras D, Magalon G. Vacuum-assisted closure in the treatment of poststernotomy mediastinitis in the paediatric patient. J Plast Reconstr Aesthet Surg. 2008;61(3):302-305. [pmid: 17586108].
692 Saxena V, Orgill D, Kohane I. A set of genes previously implicated in the hypoxia response might be an important modulator in the rat ear tissue response to mechanical stretch. BMC Genomics. 2007;8:430. [pmid: 18034909].
693 Schaffzin DM, Douglas JM, Stahl TJ, Smith LE. Vacuum-assisted closure of complex perineal wounds. Dis Colon Rectum. Oct. 2004;47(10):1745-1748. [pmid: 15540310].
694 Scheufler O, Peek A, Kania NM, Exner K. Problem-adapted application of vacuum occlusion dressings: case report and clinical experience. Eur J Plastic Surg. Oct. 2000;23(7):386-390.
695 Schintler M, Maier A, Matzi V, Smolle-Juttner FM. Vacuum assisted closure system in the management of cervical anastomotic leakage after gastric pull-up. Interact Cardiovasc Thorac Surg. Mar. 2004;3(1):92-94. [pmid: 17670186].
696 Schintler M, Marschitz I, Trop M. The use of topical negative pressure in a paediatric patient with extensive burns. Burns. Dec. 2005;31(8):1050-1053. [pmid: 16308100].
697 Schipper J, Ridder GJ, Maier W, Teszler CB, Horch RE. Laryngotracheal reconstruction using prefabricated and preconditioned composite radial forearm free flaps. A report of two cases. Auris Nasus Larynx. Jun. 2007;34(2):253-258. [pmid: 17067769].
698 Schlatterer D, Webb LX. Orthopedic indications for negative pressure wound therapy. Ostomy Wound Manage. Feb. 2005;51(2A Suppl):27-28. [pmid: 15699561].
699 Schneider AM, Morykwas MJ, Argenta LC. A new and reliable method of securing skin grafts to the difficult recipient bed. Plast Reconstr Surg. Sep. 1998;102(4):1195-1198. [pmid: 9734445].
700 Schoemann MB, Lentz CW. Treating surgical wound dehiscence with negative pressure dressings. Ostomy Wound Manage. Feb. 2005;51(2A Suppl):15-20. [pmid: 15699559].
701 Schuster R, Moradzadeh A, Waxman K. The use of vacuum-assisted closure therapy for the treatment of a large infected facial wound. Am Surg. Feb. 2006;72(2):129-131. [pmid: 16536241].
702 Senchenkov A, Knoetgen J, Chrouser KL, Nehra A. Application of vacuum-assisted closure dressing in penile skin graft reconstruction. Urology. Feb. 2006;67(2):416-419. [pmid: 16461101].
703 Sentenac J. Facilitating wound healing with VAC therapy: a pharmacist's role. European Journal of Hospital Pharmacists. May. 2008;14(5):57-58.
704 Shirakawa M, Isseroff RR. Topical negative pressure devices: Use for enhancement of healing chronic wounds. Arch Dermatol. Nov. 2005;141(11):1449-1453. [pmid: 16301393].
705 Short B, Claxton M, Armstrong DG. How to use VAC therapy on chronic wounds. Podiatry Today. Jul. 2002;15(7):48-54.
706 Shvartsman HS, Langstein H, Worley C, Malpica A, Ramondetta LM. Use of a vacuum-assisted closure device in the treatment of recurrent Paget's disease of the vulva. Obstet Gynecol. Nov. 2003;102(5 Pt 2):1163-1166. [pmid: 14607043].
707 Silberstein J, Grabowski J, Parsons JK. Use of a Vacuum-Assisted Device for Fournier's Gangrene: A New Paradigm. Rev Urol. Winter. 2008;10(1):76-80. [pmid: 18470279].
708 Simek M, Nemec P, Zalesak B, Kalab M, Hajek R, Jecminkova L, Kolar M. Vacuum-assisted closure in the treatment of sternal wound infection after cardiac surgery. Biomed Pap Med Fac Univ Palacky Olomouc Czech Repub. Dec. 2007;151(2):295-299. [pmid: 18345267].
709 Simman R, Forte R, Silverberg B, Moriera-Gonzalez A, Williams F. A comparative histological study of skin graft take with tie-over bolster dressing versus negative pressure wound therapy in a pig model: a preliminary study. Wounds. Feb. 2004;16(2):76-80.
710 Simon DH, Key JJ, Blume PA. Lower extremity wounds respond to negative pressure. Biomechanics. Aug. 2008;15(8):53-59.
711 Simon S, Hammoudeh J, Low C, Nathan N, Armstrong M, Thaller S. Complex wound management with an artificial dermal regeneration template. Wounds. Nov. 2008;20(11):299-302.
712 Singh K, Samartzis D, Heller JG, An HS, Vaccaro AR. The management of complex soft-tissue defects after spinal instrumentation. J Bone Joint Surg Br. Jan. 2006;88(1):8-15. [pmid: 16365112].
713 Singh S, Mackey S, Soldin M. VAC it - Some techniques on the application of VAC dressings. Ann R Coll Surg Engl. Mar. 2008;90(2):161-162. [pmid: 18333292].
714 Sjogren J, Gustafsson R, Koul B, Ingemansson R. Selective mediastinal tamponade to control coagulopathic bleeding. Ann Thorac Surg. Apr. 2003;75(4):1311-1313. [pmid: 12683585].
715 Sjogren J, Gustafsson R, Wackenfors A, Malmsjo M, Algotsson L, Ingemansson R. Effects of vacuum-assisted closure on central hemodynamics in a sternotomy wound model. Interact Cardiovasc Thorac Surg. Dec. 2004;3(4):666-671. [pmid: 17670336].
716 Sjogren J, Malmsjo M, Gustafsson R, Ingemansson R. Poststernotomy mediastinitis: a review of conventional surgical treatments, vacuum-assisted closure therapy and presentation of the Lund University Hospital mediastinitis algorithm. Eur J Cardiothorac Surg. Dec. 2006;30(6):898-905. [pmid: 17056269].
717 Sjogren J, Mokhtari A, Gustafsson R, Malmsjo M, Nilsson J, Ingemansson R. Vacuum-assisted closure therapy for deep sternal wound infections: the impact of learning curve on survival and predictors for late mortality. Int Wound J. Jun. 2008;5(2):216-223. [pmid: 18494627].
718 Skillman J, Kirkpatrick N, Coombes A, Coghlan B, Waterhouse N, Joshi N, Kelly M. Vacuum Assisted Closure (VAC) dressing for skin graft application following exenteration of the orbit. Orbit. Mar. 2003;22(1):63-65. [pmid: 12759869].
719 Smith APS. A closer look at the potential of hyperbaric oxygen therapy. APMA News. May. 2005;26(5-Suppl):39-42.
720 Smith APS. Case study: treating a diabetic puncture wound. APMA News. May. 2005;26(5-Suppl):16-18.
721 Snyder N, Gould LJ. Scrotal and penile reconstruction using the vacuum-assisted closure device. Can J Plast Surg. Dec. 2005;13(4):205-206. [pmid: 24227934].
722 Stawicki SP, Grossman M. "Stretching" negative pressure wound therapy: Can dressing change interval be extended in patients with open abdomens. Ostomy Wound Manage. Jan. 2007;53(1):26-29. [pmid: 17264353].
723 Stawicki SP, Schwarz NS, Schrag SP, Lukaszczyk JJ, Schadt ME, Dippolito A. Application of vacuum-assisted therapy in postoperative ascitic fluid leaks: an integral part of multimodality wound management in cirrhotic patients. J Burns Wounds. Apr. 16. 2007;6:91-99. [pmid: 17505531].
724 Steed DL, Attinger C, Colaizzi T, Crossland M, Franz M, Harkless L, Johnson A, Moosa H, Robson M, Serena T, Sheehan P, Veves A, Wiersma-Bryant L. Guidelines for the treatment of diabetic ulcers. Wound Repair Regen. Nov. 2006;14(6):680-692. [pmid: 17199833].
725 Steenvoorde P, de Roo RA, Oskam J, Neijenhuis P. Negative pressure wound therapy to treat peri-prosthetic methicillin-resistant Staphylococcus aureus infection after incisional herniorrhaphy. A case study and literature review. Ostomy Wound Manage. Jan. 2006;52(1):52-54. [pmid: 16464991].
726 Steenvoorde P, Rozeboom Al, Melief P, Elzo Kraemer CV, Bonsing BA. Failure of the topical negative pressure abdominal dressing system in the"fat" open abdomen: report of a case and review of literature. Wounds. Feb. 2006;18(2):44-50.
727 Steenvoorde P, Slotema E, Adhin S, Oskam J. Deep infection after ilioinguinal node dissection: vacuum-assisted closure therapy. Int J Low Extrem Wounds. Dec. 2004;3(4):223-226. [pmid: 15866818].
728 Steenvoorde P, van Engeland A, Bonsing B, da Costa SA, Oskam J. Combining topical negative pressure and a Bogota bag for managing a difficult laparostomy. J Wound Care. Apr. 2004;13(4):142-143. [pmid: 15114824].
729 Steinberg JS. Exploring adjunctive combination therapy for wound bed preparation. APMA News. May. 2005;26(5 Suppl):24-26.
730 Stinson JA, Powell JL. Necrotizing fasciitis in women at a community teaching hospital. J Pelvic Med Surg. Jul-Aug. 2005;11(4):209-213.
731 Stokes TH, Follmar KE, Silverstein AD, Weizer AZ, Donatucci CF, Anderson EE, Erdmann D. Use of negative-pressure dressings and split-thickness skin grafts following penile shaft reduction and reduction scrotoplasty in the management of penoscrotal elephantiasis. Ann Plast Surg. Jun. 2006;56(6):649-653. [pmid: 16721079].
732 Summaries of current clinical evidence Engenex NPWT system. Skillman (NJ). ConvaTec, Inc. 3.
733 Sunog T. Closing time. Adv Nurs. Aug. 2003;18(34):39.
734 Svedmant, et al. A dressing system providing fluid supply and suction drainage used for continuous or intermittent irrigation. Ann Plast Surg. Aug. 1986;17(2):125-133. [pmid: 3273085].
735 Tan D, Rajanayagam J, Schwarz F. Treatment of long-standing, poor-healing diabetic foot ulcers with topical negative pressure in the Torres Strait. Aust J Rural Health. Aug. 2007;15(4):275-276. [pmid: 17617094].
736 Tang AT, Ohri SK, Haw MP. Novel application of vacuum assisted closure technique to the treatment of sternotomy wound infection. Eur J Cardiothorac Surg. Apr. 2000;17(4):482-484. [pmid: 10773574].
737 Tang AT, Okri SK, Haw MP. Vacuum-assisted closure to treat deep sternal wound infection following cardiac surgery. J Wound Care. May. 2000;9(5):229-230. [pmid: 11933333].
738 Tarkin IS. The versatility of negative pressure wound therapy with reticulated open cell foam for soft tissue management after severe musculoskeletal trauma. J Orthop Trauma. Nov-Dec. 2008;22(10 Suppl):S146-S151. [pmid: 19034162].
739 Taub PJ, Schulman MR, Sett S, Koch RM. Revisiting vascularized muscle flaps for complicated sternal wounds in children. Ann Plast Surg. Nov. 2005;55(5):535-537. [pmid: 16258310].
740 Terrazas SG. Adjuvant dressing for negative pressure wound therapy in burns. Ostomy Wound Manage. Jan. 2006;52(1):16. 18. [pmid: 16528843].
741 Thomas S. An introduction to the use of vacuum assisted closure. World Wide Wounds [serial online]. 2001. May. accessed 2001 Jun 11. [25 screens]. Available: http://www.worldwidewounds.com/2001/may/Thomas/Vacuum-Assisted-Closure.htm.
742 Thomas T. (Executive Director, Association for the Advancement of Wound Care. Malvern, PA). Personal communication - Full submission packet. Feb. 1. 2009:142.
743 Thompson JT, Marks MW. Negative pressure wound therapy. Clin Plast Surg. Oct. 2007;34(4):673-684. [pmid: 17967622].
744 Torbrand C, Ingemansson R, Gustafsson L, Paulsson P, Malmsjo M. Pressure transduction to the thoracic cavity during topical negative pressure therapy of a sternotomy wound. Int Wound J. Oct. 2008;5(4):579-584. [pmid: 18808433].
745 Torbrand C, Wackenfors A, Lindstedt S, Ekman R, Ingemansson R, Malmsjo M. Sympathetic and sensory nerve activation during negative pressure therapy of sternotomy wounds. Interact Cardiovasc Thorac Surg. Dec. 2008;7(6):1067-1070. [pmid: 18784122].
746 Trop M, Schintler M, Urban E, Roedl S, Stockenhuber A. Are 1:4 mesh and donor site contraindications for vacuum-assisted closure device. J Trauma. Nov. 2006;61(5):1267-1270. [pmid: 17099542].
747 Trueman P, Flack S, Loonstra A, Hauser T. The feasibility of using V.A.C. Therapy in home care patients with surgical and traumatic wounds in the Netherlands. Int Wound J. Jun. 2008;5(2):225-231. [pmid: 18494628].
748 Trueman P. Cost-effectiveness considerations for home health V.A.C. Therapy in the United States of America and its potential international application. Int Wound J. Jun. Suppl 2. 2008;5:23-26. [pmid: 18577135].
749 Uygur F, Duman H, Ulkur E, Ceikoz B. The role of the vacuum-assisted closure therapy in the salvage of venous congestion of the free flap: case report. Int Wound J. Mar. 2008;5(1):50-53. [pmid: 18179554].
750 Vallet C, Saucy F, Haller C, Meier P, Rafoul W, Corpataux JM. Vacuum-assisted conservative treatment for the management and salvage of exposed prosthetic hemodialysis access. Eur J Vasc Endovasc Surg. Oct. 2004;28(4):397-399. [pmid: 15350562].
751 Varker KA, Ng T. Management of empyema cavity with the vacuum-assisted closure device. Ann Thorac Surg. Feb. 2006;81(2):723-725. [pmid: 16427885].
752 Venturi ML, Attinger CE, Mesbahi AN, Hess CL, Graw KS. Mechanisms and clinical applications of the vacuum-assisted closure (VAC) Device: a review. Am J Clin Dermatol. 2005;6(3):185-194. [pmid: 15943495].
753 Verhaalen Al. Isolation of an entercutaneous fistula within a vacuum-assisted wound closure system. Gen Surg. Aug. 2006;33(8).
754 Verrillo SC. Negative pressure therapy for infected sternal wounds: a literature review. J Wound Ostomy Continence Nurs. Mar-Apr. 2004;31(2):72-74. [pmid: 15209429].
755 von Gossler CM, Horch RE. Rapid aggressive soft-tissue necrosis after beetle bite can be treated by radical necrectomy and vacuum suction-assisted closure. J Cutan Med Surg. Oct. 2000;4(4):219-222. [pmid: 11303487].
756 Wackenfors A, Gustafsson R, Sjogren J, Algotsson L, Ingemansson R, Malmsjo M. Blood flow responses in the peristernal thoracic wall during vacuum-assisted closure therapy. Ann Thorac Surg. May. 2005;79(5):1724-1730. discussion 1730-. [pmid: 15854963].
757 Wackenfors A, Sjogren J, Algotsson L, Gustafsson R, Ingemansson R, Malmsjo M. The effect of vacuum-assisted closure therapy on the pig femoral artery vasomotor responses. Wound Repair Regen. Mar-Apr. 2004;12(2):244-251. [pmid: 15086776].
758 Webb LX, Laver D, DeFranzo A. Negative pressure wound therapy in the management of orthopedic wounds. Ostomy Wound Manage. Apr. 2004;50(4A Suppl):26-27. [pmid: 15317242].
759 Webb LX, Pape HC. Current thought regarding the mechanism of action of negative pressure wound therapy with reticulated open cell foam. J Orthop Trauma. Nov-Dec. 2008;22(10 Suppl):S135-S137. [pmid: 19034159].
760 Webb LX. New techniques in wound management: vacuum-assisted wound closure. J Am Acad Orthop Surg. Sep-Oct. 2002;10(5):303-311. [pmid: 12374481].
761 Weinfeld AB, Kelley P, Yuksel E, Tiwari P, Hsu P, Choo J, Hollier LH. Circumferential negative-pressure dressing (VAC) to bolster skin grafts in the reconstruction of the penile shaft and scrotum. Ann Plast Surg. Feb. 2005;54(2):178-183. [pmid: 15655470].
762 Wessel LC, Cunningham BL. Patient with compartment syndrome of the lower extremity. J Wound Ostomy Continence Nurs. Jul. 2002;29(4):210-215. [pmid: 12114939].
763 Whelan C, Stewart J, Schwartz BF. Mechanics of wound healing and importance of Vacuum Assisted Closure in urology. J Urol. May. 2005;173(5):1463-1470. [pmid: 15821461].
764 White RA, Miki RA, Kazmier P, Anglen JO. Vacuum-assisted closure complicated by erosion and hemorrhage of the anterior tibial artery. J Orthop Trauma. Jan. 2005;19(1):56-59. [pmid: 15668586].
765 Whitney J, Phillips L, Aslam R, Barbul A, Gottrup F, Gould L, Robson MC, Rodeheaver G, Thomas D, Stotts N. Guidelines for the treatment of pressure ulcers. Wound Repair Regen. Nov-Dec. 2006;14(6):663-679. [pmid: 17199832].
766 Wilkes R, Zhao Y, Kieswetter K, Haridas B. Effects of Dressing Type on 3D Tissue Microdeformations During Negative Pressure Wound Therapy: A Computational Study. J Biomech Eng. Mar. 2009;131(3):031012. [pmid: 19154071].
767 Willy C, Voelker HU, Engelhardt M. Literature on the subject of vacuum therapy: review and update 2006. Eur J Trauma Emerg Surg. Feb. 2007;33(1):33-39.
768 Wiseman J, Cullington JR, Schaeferle M 3rd, Beckham PH, Salisbury M, Ersek RA. Aesthetic aspects of neurofibromatosis reconstruction with the vacuum-assisted closure system. Aesthetic Plast Surg. Sep-Oct. 2001;25(5):326-331. [pmid: 11692244].
769 Wolvos T. Wound instillation with negative pressure wound therapy. Ostomy Wound Manage. Feb. 2005;51(2A Suppl):21S-26S. [pmid: 15699560].
770 Wolvos T. Wound instillation--the next step in negative pressure wound therapy. Lessons learned from initial experiences. Ostomy Wound Manage. Nov. 2004;50(11):56-66. [pmid: 15545698].
771 Wong LK, Nesbit RD, Turner LA, Sargent LA. Management of a circumferential lower extremity degloving injury with the use of vacuum-assisted closure. South Med J. Jun. 2006;99(6):628-630. [pmid: 16800422].
772 Woo KY, Sibbald RG. Vacuum-assisted closure home care training: a process to link education to improved patient outcomes. Int Wound J. Jun. Suppl 2. 2008;5:1-9. [pmid: 18577132].
773 Wound wonder. Middle East Medical. May-Jun. 2003:61-65.
774 Wu S. Case study: treating a patient with a diabetic neuropathic ulceration. APMA News. May. 2005;26(5-Suppl):19.
775 Wu SC, Lavery LA, Armstrong DG. Closing difficult wounds. Podiatry Today. Mar. 2006;19(3):44-54.
776 Wu Sc, Yoon H, Armstrong DG. Therapy with advanced modalities: can it expedite healing?. Podiatry Today. Sep. 2005;18(9):18-24.
777 Wustmann O, Ulrich HC. German patent specification. Appliance for the drainage of wounds. No. 847 475 Class 30 K Group 17 04. 1952.
778 Yoong S, Dunne G, Cochrane J, Lee B, Lee J. Vacuum-assisted closure for the treatment of parastomal skin necrosis: a novel approach to an unusual complication. Report of a case. Dis Colon Rectum. Oct. 2008;51(10):1577-1579. [pmid: 18330646].
779 Yousaf M, Witherow A, Gardiner KR, Gilliland R. Use of vacuum-assisted closure for healing of a persistent perineal sinus following panproctocolectomy: report of a case. Dis Colon Rectum. Aug. 2004;47(8):1403-1407. discussion 1407-8. [pmid: 15484357].
780 Yuan-Innes MJ, Temple CL, Lacey MS. Vacuum-assisted wound closure: a new approach to spinal wounds with exposed hardware. Spine. Feb. 1. 2001;26(3):E30-E33. [pmid: 11224876].
781 Yuh DD, Albaugh M, Ullrich S, Conte JV. Treatment of ventricular assist device driveline infection with vacuum-assisted closure system. Ann Thorac Surg. Oct. 2005;80(4):1493-1495. [pmid: 16181898].
782 Zamierowski D. United States Patent. Wound dressing and treatment method. No. 4969880. 1990.
783 Zehnder SW, Place HM. Vacuum-assisted wound closure in postoperative spinal wound infection. Orthopedics. Apr. 2007;30(4):267-272. [pmid: 17424688].
784 Zutt M, Haas E, Kruger U, Distler M, Neumann C. Successful use of vacuum-assisted closure therapy for leg ulcers caused by occluding vasculopathy and inflammatory vascular diseases--a case series. Dermatology. 2007;214(4):319-324. [pmid: 17460403].
785 Argenta A, Webb K, Simpson J, Gordon S, Kortesis B, Wanner M, Kremers L, Morykwas M. Deformation of superficial and deep abdominal tissues with application of a controlled vacuum. European Tissue Repair Society, Focus group meeting Topical Negative Pressure (TNP) Therapy. London. 2003. December. 4-6.
786 Evidence summary. San Antonio (TX). Kinetic Concepts, Inc. 19.
787 Fruchterman T. (Senior Vice President, Research & Development & Chief Technology Officer). Kinetic Concepts, Inc. submission of information for use in review of Negative Pressure Wound Therapy (NPWT). Feb. 4. 2009:3.
788 KCI, Inc. ongoing clinical trials. San Antonio (TX). Kinetic Concepts, Inc. 1.
789 KCI, Inc. referenced data on file. San Antonio (TX). Kinetic Concepts, Inc. 1.
790 KCI, Inc. unpublished clinical trials. San Antonio (TX). Kinetic Concepts, Inc. 2.
791 Product labeling information. San Antonio (TX). Kinetic Concepts, Inc. 176.
792 Biblehimer HL. Dealing with a wound that drains 1.5 liters a day. RN. Aug. 1986;49(8):21-23. [pmid: 3640537].
793 Coleman D. No wound is too big for resourceful nurses. RN. Dec. 1988;51(12):22-25. [pmid: 3206127].
794 Garcia-Rinaldi R, Defore WW Jr, Green ZD, McBride C. Improving the efficiency of wound drainage catheters. Am J Surg. Sep. 1975;130(3):372-373. [pmid: 1166927].
795 Miller MS, Lowery CA. Negative pressure wound therapy: 'a rose by any other name'. Ostomy Wound Manage. Mar. 2005;51(3):44-46. 48. 49. [pmid: 15984398].
796 Q209 hospital purchasing manager survey. Charlotte (NC). Wachovia Capital Markets, LLC. Apr. 7. 2009:13.
797 Q2 2008 wound care nurse survey. Charlotte (NC). Wachovia Capital Markets, LLC. May. 21. 2008:13.
798 Q208 hospital purchasing manager survey. Charlotte (NC). Wachovia Capital Markets, LLC. Apr. 21. 2008:16.
799 Q4 2007 wound care nurse survey. Charlotte (NC). Wachovia Capital Markets, LLC. Dec. 6. 2007:11.
800 Q4 2008 wound care nurse survey. Charlotte (NC). Wachovia Capital Markets, LLC. Dec. 1. 2008:15.
801 RAFFL AB. The use of negative pressure under skin flaps after radical mastectomy. Ann Surg. Dec. 1952;136(6):1048. [pmid: 12986694].
802 Ramirez OM, Granick MS, Futrell JW. Optimal wound healing under Op-Site dressing. Plast Reconstr Surg. Mar. 1984;73(3):474-475. [pmid: 6701224].
803 Schwab PM, Kelly KA. Primary closure of the perineal wound after proctectomy. A new technique. Mayo Clin Proc. Mar. 1974;49(3):176-179. [pmid: 4592288].
804 VanDuren T. (Case Manager. University of Utah Health Plans & Healthy-U). Blue Sky Versatile One. Case study. University of Utah. Jan. 13. 2004:7.
805 Wolvos T. Feature: wound instillation-the next step in negative pressure wound therapy. Lessons learned from initial experiences. Ostomy Wound Manag. 2004;50(11):56-66.
806 Beninger P. (Director. Division of General and Restorative Devices. Office of Device Evaluation. Center for Devices and Radiological Health). 510(k) notification of intent to market VACPLUS. K945062. Mar. 14. 1995:50.
807 Bowman J. Personal Communication. FDA account of NPNT safety issues as summarized by CMS. 2005:1.
808 Dillard J. (Acting Director. Division of General and Restorative Devices. Office of Device Evaluation. Center for Devices and Radiological Health). Approval of 510(k) notification of intent to market. V.A.C. plus. K992448. Jan. 18. 2000:3.
809 Food and Drug Administration, Center for Devices and Radiological Health. Guidance document for powered suction pump 510(k)s. Rockville (MD). Food and Drug Administration, Center for Devices and Radiological Health. 1998:5.
810 Food and Drug Administration, Center for Devices and Radiological Health. 510(k) premarket notification database. Annelid. K940886 [internet]. Silver Spring (MD). Food and Drug Administration, Center for Devices and Radiological Health. Nov. 5. accessed 2002 Nov 5. 2002:1. [updated 2009 Jan 16]. Available: http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfPMN/pmn.cfm?ID=96760.
811 Food and Drug Administration, Center for Devices and Radiological Health. 510(k) premarket notification database. Vacuum assisted closure. K021500 [internet]. Silver Spring (MD). Food and Drug Administration, Center for Devices and Radiological Health. Dec. 20. accessed 2005 Nov 11. 2002:5. Available: http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfPMN/pmn.cfm?ID=8137.
812 Food and Drug Administration. 510 (k) summary statement. V.A.C. plus device, 510(k) No. K945062. [database online]. Silver Spring (MD). Food and Drug Administration. Jan. 18. 2000:2.
813 Hake C. (Director, CMS HCPCS Workgroup). Personal communication. Request to establish a code for portable powered suction pump, trade name: versatile wound vacuum system. 2005:2.
814 Hake C. (Director. CMS HCPCS Workgroup). Personal Communication. request to establish three new codes for negative pressure wound therapy (NPWT) pumps, canisters and dressings which provide wound site pressure feedback. 2006:2.
815 Hake C. Doctors interviewed by the house ways and means reportedly support foam as superior to gauze. 2008:3.
816 Harbour J. Kinetic Concepts, Inc. 510 (k) Summary. Ambulatory Suction Pump. May. 22. 1997:5.
817 Smith T. Kinetic Concepts patent not infringed. 2006:1.
818 United States patent and trademark office. V.A.C. United States Patent and Trademark Office. Jun. 25. 1996:33.
819 Wilson C. Personal communication. FW: Alliance for LTC on Wound VAC/NPWT. 2006:2.
820 Witten C. (Director. Division of General and Restorative Devices, Office of Device Evaluation, Center for Devices and Radiological Health). Approval of 510(k) notification of intent to market. AmbuVAC Device. May. 22. 1997:3.
821 Witten C. (Director. Division of General, Restorative and Neurological Devices, Office of Device Evaluation, Center for Devices and Radiological Health). Approval of 510(k) notification of intent to market. V.A.C. family of devices: mini V.A.C. V.A.C. Freedom V.A.C. ATS. K032310. Oct. 10. 2003:5.
822 Witten C. (Director. Division of General, Restorative and Neurological Devices. Office of Device Evaluation. Center for Devices and Radiological Health). 510(k) notification of intent to market Versatile 1 Wound Vaccum System. K042134. Nov. 15. 2004:7.
823 Witten C. (Director. Division of General, Restorative and Neurological Devices, Office of Device Evaluation, Center for Devices and Radiological Health). Approval of 510(k) notification of intent to marketV.AC. granufoam silver dressing. K041642. Jan. 25. 2005:3.
824 AllegroMedical.com. Invacare aspirator product description [internet]. Mesa (AZ). AllegroMedical.com. 2005. accessed 2005 Aug 15. Available: http://www.allegromedical.com/oxygen_therapy/nebulizers/invacare/aspirator.P189899.
825 BlueSky Medical Group, Inc. Negative pressure wound therapy. V1STA Versatile 1 portable. Carlsbad (CA). BlueSky Medical Group, Inc. 2005:4.
826 Hake C. (Director, CMS' HCPCS Workgroup). Personal communication. Negative pressure wound therapy devices. Jan. 23. 2008:5.
827 Kinetic Concepts, Inc. Advanced Dressings. Dedicated dressings for specific wound applications. San Antonio (TX). Kinetic Concepts, Inc. (KCI). 2005:6.
828 Kinetic Concepts, Inc. V.A.C. A portable system for advanced wound healing. San Antonio (TX). Kinetic Concepts, Inc. (KCI). 2005:6.
829 Lewis P. Smith & Nephews acquires bluesky medical group. Remington Rep. 2007.
830 Medela, Inc. Medela Clario home care pump. Product Description [internet]. MCHenry (IL). Medela, Inc. accessed 2005 Sep 16. 2005:1.
831 United Publications, Inc. Are negative pressure wound therapy codes created equal? [internet]. Yarmouth (ME). United Publications, Inc. accessed 2009 Jan 12. 2009:3.
832 Weston R. (President, BlueSky Medical). Personal Communication. BlueSky medical wound drainage kit. 2003:5.
833 Cynthia S. Hake. CMS meeting with KCI. 2005:68.
834 House small business subcommittee on rural and urban entrepreneurship. Statement by Linwood A. Staub, President, Global V.A.C. therapy, Kinetic Concepts, Inc. (KCI) on behalf of the Advanced Medical Technology Association (AdvaMed). Washington (DC). U.S. House of Representatives. May. 21. 2008:11. Also available: http://www.house.gov/smbiz/hearings/hearing-05-21-08-DME/Staub.pdf.
835 Kinetic Concepts, Inc. (KCL). Personal Communication. KCI comments on CMS' preliminary decision to include Blue Sky and KCI NPNT devices in the same code. 2005:20.
836 Kinetic Concepts, Inc. Personal communication. Comments following the June 23, 2005 CMS HCPCS workgroup meeting agenda item #11; HCPCS request #05.09. 2005:3.
837 Larichev A. Vacuum therapy in wounds and wound infection: negative pressure wound therapy. Carlsbad (CA). BlueSky Publication. 2005:2.
838 Matherne C. (Senior Attorney. LSU, Health Sciences Center). Personal Communication. V.A.C. System. Medical center of Louisiana. Sep. 21. 2001:1.
839 Morris S. (Vice President, Health policy & Government Affairs KCI). Personal communication. Public meeting registration for KCI. 2006:1.
840 Morris S. (Vice President, Reimbursement Policy and Compliance). Personal Communication. HCPCS code request for negative pressure wound therapy pumps. 2006:4.
841 Morris S. Additional V1 failures/VAC rescues. 2006:2.
842 Moton T. (Briefing Coordinator). Meeting with Kinetic Concepts Incorporated (KCL). 2006:30.
843 NPWT HCPCS coding: KCI V.A.C. therapy system. Update for the centers for Medicare and Medicaid services. San Antonio (TX). Kinetic Concepts, Inc. (KCI). 2006:173.
844 Quirk W. Personal Communication. VAC plus premarket notification No. K945062. Oct. 22. 2002:4.
845 Schroeder W. (Vice President, Medical Department, Kinetic Concepts, Inc.). Misuse of the V.A.C technology. Feb. 01. 2000:2.
846 Tarplin R. Letters that raise concerns about the CMS HCPCS coding decision. 2006:83.
847 Blue Sky Medical Group, Inc. HCPSC coding request versatile 1 wound vacuum system. Carlsbad (CA). Blue Sky Medical Group, Inc. 2005:5.
848 BlueSky Medical. Information for centers for medicare and medicaid services on negative pressure wound therapy. Baltimore (MD). BlueSky Medical. Oct. 25. 2002:45.
849 Guimond J. (Marketing & Sales. BlueSky Medical Group, Inc.). Personal Communication. BlueSky's product line, VISTA Versatile 1 portable. 2006:3.
850 Weston R. (President. BlueSky Medical Group, Inc.). Personal Communication. Petition and request to decrease reimbursement levels. Jun. 11. 2002:2.
851 Weston R. Personal communication. Blue Sky's 2005 HCPCS code request. 2004:5.
852 Engenex Advanced Negative Pressure Wound Therapy System. Instructions for use. Skillman (NJ). ConvaTec, Inc. Dec. 2008:33.
853 Rolley J. (Vice President, Global Government Affairs and Health Policy, ConvaTec). Personal communication. Feb. 6. 2009:3.
854 Andersen C. (Chief Vascular/Endovascular/LimbPreservation Surgery Service, Madigan Army Medical Center. Ft. Lewis, WA). Personal communication. Re: AHRQ review of NPWT. Feb. 6. 2009:2.
855 Annest S. (MD, FACS. Denver, CO). Personal communication. NPWT Comments from Annest. Feb. 3. 2009:1.
856 Arnold DA. (Midwest Hernia Institute, P.C.). Personal communication. Comments on NPWT from Midwest Hernia Institute. Jan. 30. 2009:1.
857 Bernstein BH. (DPM, FACFAS). Personal communication. Comparison of types of NPWT, limb salvage specialists point of view. Feb. 4. 2009:2.
858 Chaiken N. (Wound Ostomy Continence, Swedish Covenant Hospital). Personal communication. Comments on wound vacs. Feb. 3. 2009:1.
859 Clinical V.A.C. therapy slides from the practice of Dr. C. Douglas Fogg, MD, FACS. New Bedford (MA). New Bedford Rehabilitation Hospital Wound Care Center. 14.
860 Coliauta EA. Personal communication. Support of KCI wound VAC system. Feb. 6. 2009:1.
861 Cummings SF. (Director, Wound Recovery and Hyperbaric Medicine Service, Kent Hospital. Warwick, RI). Personal communication. NPWT Response from Kent Hospital. Jan. 30. 2009:1.
862 DosRemedios E. (Clinical Assistant Professor of Orthopaedic Surgery, Warren Alpert School of Medicine at Brown University. Providence, Rhode Island.). Personal communication. Comments on NPWT from Brown University. Feb. 2. 2009:1.
863 Fetterly MA. (RNFA, CPSN, CNOR. O Plastic & Reconstructive Surgery. Reno, NV). To AHRQ in regards to KCI VAC devices. Jan. 29. 2009:1.
864 Fleck T. (Department of Cardiothoracic Surgery, AKH Vienna, Medical University of Vienna). Response to the review of NPWT of the AHRQ. Jan. 29. 2009:1.
865 Fogg CD. (Medical Director, New Bedford Rehabilitation Hospital Wound Care Center). Advocacy for V.A.C. therapy. 1.
866 Gestring M, Manaker S, Wilson KC. Vacuum assisted wound closure [unpublished]. Apr. 10. 2008:7.
867 Marston WA. (Professor and Chief, Division of Vascular Surgery, Universtiy of North Carolia School of Medicine. Chapel Hill, NC). Personal communication. Review of Negative Pressure Wound Therapy devices. Feb. 3. 2009:1.
868 Mooney TM. (DPM, AACFAS, Western Nevada Foot & Ankle Center, LLC. Reno, NV). Personal communication. 2009:1.
869 Nelson G. (Program Coordinator, Advanced Wound Center, Rogue Valley Medical Center. Medford, OR). Personal communication. Concerns about negative pressure therapy. Feb. 5. 2009:2.
870 Pelham FR. (Department of Orthopedic Surgery, Musculoskeletal Research Center, New York University Hospital for Joint Diseases, New York, NY). Personal communication. Re: VAC therapy. Feb. 6. 2009:13.
871 Ritzman D. (Fremont-Rideout Home Health). Personal communication. HCPS code for KCI Wound Vac. Jan. 31. 2009:1.
872 Robins M. (Wound Care Clinic at Utah Valley Regional Medical Center). NPWT study. Feb. 6. 2009:4.
873 Schultz G. (Professor, Department of Obstetrics and Gynecology, Institute for Wound Research, University of Florida. Gainesville, FL). Personal communication. Re: scientific data on effects of NPWT. Feb. 6. 2009:1.
874 Snow R. (Director, Baptist Wound Care & Hyperbaric Medicine Program @ Princeton). Personal communication Re: negative pressure Rx. Feb. 3. 2009:1.
875 Tedford S. (WOCN Program Coordinator, Sutter VNA & Hospice). Personal communication. HCPCS code response from WOCN. Jan. 30. 2009:1.
876 Ward RS. (President, American Physical Therapy Association. Alexandria, VA). APTA's response to AHRQ's request for information on Negative Pressure Wound Therapy. Feb. 4. 2009:2.
877 Yee EM. (Sierra Infectious Diseases, Reno, NV). Personal communication. Comments on proposed code change. Jan. 30. 2009:1.
878 Best practice statement: gauze-based negative pressure wound therapy. HealthComm UK Limited. Nov. 2008:19.
879 Case study 2: Four challenging LE wounds: can these chronic wounds be healed with use of negative pressure wound therapy. McHenry (IL). Medela Healthcare, Inc. 1.
880 Case study: gauze-based NPWT: various wound types from different wound locations. McHenry (IL). Medela Healthcare, Inc. 1.
881 Comparative analysis of gauze-based NPWT systems versus foam-based NPWT systems. McHenry (IL). Medela Healthcare, Inc. 7.
882 Gauze based clinical study 1: Safety and effectiveness of the Invia (vacuum) wound care system versus a saline wet-to-dry gauze dressing. McHenry (IL). Medela Healthcare, Inc. 5.
883 Gauze based clinical study 2: Gauze versus foam for topical negative pressure wound therapy (NPWT) in postoperative subcutaneous wound infections after abdominal operations. First clinical observations. McHenry (IL). Medela Healthcare, Inc. 22.
884 Long C. (Director, Medela Healthcare. McHenry, IL). Submission letter from Medlea Healthcare regarding NPWT. Feb. 3. 2009:1.
885 Introduction to NPWT. McHenry (IL). Medela Healthcare. 2009:3.
886 Pre-clinical study: a comparison of various dressings combined with NPWT. McHenry (IL). Medela Healthcare, Inc. 2008:15. Also available: http://www.etrs.org/malta3.html.
887 The effect of an antimicrobial gauze dressing impregnated with 0.2% polyhexamethylene biguanide (PHMB) as a barrier to prevent pseudomonas aeruginosa wound invasion. McHenry (IL). Medela Healthcare, Inc. 7.
888 Advancing the art and science of NPWT. Fort Worth (TX). Prospera. 2008. CD-ROM.
889 Ahearn C. (Director of Clinical Services, Prospera). Prospera response to ECRI Institute's December 20, 2008 request for information regaring our Negative Pressure Wound Therapy system. Feb. 2. 2009:1.
890 Allison Hendrickson M, Reaves L, Ulbrich M. Optimizing wound care by integrating negative pressure wound therapy (NPWT), adjunctive topical treatments and surgical debridement. Grapevine (TX). Ethicus Long Term Acute Care Hospital. 1.
891 AMD antimicrobial gauze dressings [slide]. Fort Worth (TX). Prospera. 1.
892 Bonham PA, Ramundo JM. Commentary: surgical wound case studies with the Versatile 1 wound vacuum system for negative pressure wound therapy. J Wound Ostomy Continence Nurs. Mar-Apr. 2006;33(2):185-190.
893 Borgquist O, Torbrand C, Ingemansson R, Malmsjo M. Biological effects of negative pressure wound therapy (NPWT) at low levels of negative pressure - intermittent and variable NPWT [confidential info prepared for ECRI on behalf of AHRQ]. 2009. Feb. 5.
894 Borgquist O, Torbrand C, Ingemansson R, Malmsjo M. Biological effects of negative pressure wound therapy at low levels of negative pressure - intermittent and variable NPWT. 2.
895 Case studies: Prospera PRO-I negative pressure wound therapy [MR124-02/08]. Fort Worth (TX). Prospera. 2008:7.
896 Caudill T. Clinical and economic benefit to surgical patients with the use of an antimicrobial impregnated surgical dressing. 2.
897 Clinical and patient testimonials [Confidential info prepared for ECRI on behalf of AHRQ]. Fort Worth (TX). Prospera. Feb. 2009:5.
898 CPT - continuous pressure therapy [graph]. Fort Worth (TX). Prospera. 1.
899 Donahue K. (Administrative Assistant, Health Technology Assessment Information Service and Evidence-Based Practice Center, ECRI Institute. Plymouth Meeting, PA). ECRI Institute's request for submissions on NPWT from interested stakeholders. Dec. 30. 2008:2.
900 Eberlein T, Fedler H. Using a new technique of negative pressure wound therapy (NPWT): variable pressure therapy (VPT) for the management of chronic, non-healing wounds [poster]. Neuremberg, Germany. Gesundheits Manager Health and Wound Management. 1.
901 Eberlein T, Fendler H, Ahearn C. Using a new technique for negative pressure wound therapy (NPWT) for the management of chronic, non-healing wounds [poster]. Neuremberg, Germany. Gesundheits Manager Health and Wound Management. 1.
902 Eberlein T, Fendler H, Ahearn C. Using a new technique of negative pressure wound therapy (NPWT): variable pressure therapy (VPT) for the management of chronic, non-healing wounds. 4.
903 Etoz A, Ozgenel Y, Ozcan M. The use of negative pressure wound therapy on diabetic foot ulcers: a preliminary controlled trial. Wounds. Aug. 2004;16(8):264-269.
904 Guiding principles/documentation behind Prospera variable pressure therapy (VPT). Fort Worth (TX). Prospera. 1.
905 Guiding principles/documentation behind the use of Lower Pressure Settings. Fort Worth (TX). Prospera. 1.
906 Introducing the all-new PRO-II [MR-131-09/08]. Fort Worth (TX). Prospera. 2008:6.
907 Kairinos N, Solomons M, Hudson DA. The paradox of negative pressure wound therapy - in vitro studies. J Plast Reconstr Aesthet Surg. 2008. Nov. 24. Epub ahead of print. [pmid: 19036656].
908 Kirby M. Negative pressure wound therapy. Br J Diabetes Vasc Dis. Sep. 2007;7(5):230-234.
909 Malmsjo M, Ingemansson R, Martin R, Huddleston E. Negative pressure wound therapy using gauze or polyurethane open cell foam: similar effects on pressure transduction and wound contraction. Lund, Sweden. Lund University. 1.
910 Miller MS. Commentary: new microvascular blood flow research challenges practice protocols in negative pressure wound therapy. Wounds. 2005;17(10):290-294.
911 Molnar JA. The science behind negative pressure wound therapy. Ostomy Wound Manage. Apr. 2004;50(4A Suppl):2-5. [pmid: 15317235].
912 Motta GJ, Corbett LQ, Milne CT. Impact of an antimicrobial gauze upon bacterial colonies in wounds that require packing. 11.
913 NovaSpine LLC. 510(k) summary of safety and effectiveness. K062456. Rockville (MD). U.S. Food and Drug Administration. Sep. 27. 2006:5.
914 Price RD, Nagarajan M, Srinivasan JR. Local anesthetic for change of vacuum-assisted closure dressings. Plast Reconstr Surg. Jun. 2006;117(7):2537-2538. [pmid: 16772999].
915 PRO-I [MR-125-04/08]. Fort Worth (TX). Prospera. 2008:4.
916 Prospera overview [confidential info prepared for ECRI on behalf of AHRQ]. Forth Worth (TX). Prospera. Feb. 2009:1.
917 Rationale for the Choice AMD gauze dressing system. Fort Worth (TX). Prospera. 2.
918 Sargent RL, Mudro P, Mele J, Sons J. The use of antimicrobial gauze in a home care setting: a cost effective, proactive wound management plan. 2.
919 Shah CB, Swogger E, James G. Efficacy of AMD dressings against MRSA and VRE. Jul. 2006:4.
920 Similar physical properties of gauze and polyurethane foam in delivery of negative pressure wound therapy. St. Petersburg (FL). Smith & Nephew. 2008:2.
921 Tillery T. The use of a gauze-based dressing for negative pressure wound therapy (NPWT): clinical and financial outcomes. 2008:2.
922 Usupov YN, Yepifanov MV. [Active wound drainage] translated from Russian. Vestnik Khirurgii. 1987:42-45. (Rus).
923 VPT variable pressure therapy [graph]. Forth Worth (TX). Prospera. 1.
924 Baffie A, Fromantin L. Clinical case: V1STA. J Wound Tech. Jun. 2008;1:24.
925 Beneke MJ, Doner J. Observation of nosocomial surgical-site infection rates with utilization of antimicrobial gauze dressing in an acute care setting. Mansfield (MA). Tyco Healthcare. Jun. 2005:4.
926 BlueSky Medical Group, Inc. 510(k) summary for BlueSky VISTA Wound Vacuum System. K061367. Rockville (MD). U.S. Food and Drug Administration (FDA). Aug. 10. 2006:5.
927 BlueSky Medical Group, Inc. 510(k) summary for Versatile 1 EZCare Wound Vacuum System. K061919. Rockville (MD). U.S. Food and Drug Administration (FDA). Feb. 5. 2007:4.
928 Bogart A. The use of antimicrobial gauze dressing on an infected lower extremity vascular bypass wounds. Mansfield (MA). Tyco Healthcare. Oct. 2005:4.
929 Brooks B. (HCPCS Medical Analyst, SADMERC). Letter regarding the consensus coding decision of SADMERC and the four durable medical equipment regional carriers (DMERCs) for Kerlix A.M.D. antimicrobial Large roll and Kerlix A.M.D. antimicrobial super sponge. Sep. 23. 2002:1.
930 Brown C. (PDAC Medicare Pricing, Data Analysis, and Coding / Data Analyst, Noridian Administrative Services, Ltd.). Response to inquiry for coding verification of Renasys EZ (model # 66800059). Xref 7118176. Dec. 22. 2008:2.
931 Carson R. (Manager, Health Policy & Reimbursement, North America. Smith & Nephew Wound Management). Additional evidence for consideration in review of Negative Pressure Wound Therapy (NPWT). Feb. 5. 2009:3. binder of material p.
932 Case JM. Microbial challenge test for porous materials using methylicillin resistant staphylococcus aureus. Mansfield (MA). Tyco Healthcare. Jul. 2001:6.
933 Comstock M. Process improvement project: reduction of surgical site infections utilizing antimicrobial dressings. Mansfield (MA). Covidien. Sep. 2008:4.
934 Coutts P, Fierheller M, Broughton C, Sibbald RG. Effective wound management influences quality of life. Mansfield (MA). Covidien. Sep. 2008:1.
935 Davis S, Mertz P, Cazzaniga A, Serralta V, Orr R, Eaglstein W. The use of a new antimicrobial gauze dressing: effects on the rate of epithelization of partial thickness wounds. Mansfield (MA). Tyco Healthcare. Apr. 2001:4.
936 EZCARE negative pressure wound therapy. User guide. Smith & Nephew, Inc. 31.
937 Fierheller M, Coutts P, Sibbald RG. Holistic effect of an antimicrobial gauze dressing with Claggett's Window. Mansfield (MA). Covidien. Sep. 2008:1.
938 Findley RD, McGaha EC. The successful use of Negative Pressure Would Therapy after left above the knee amputation (AKA) revision, in a challenging patient.
939 Harris R. Analysis of surgical site infection rates and cost benefits associated with plain gauze dressings versus gauze dressings impregnated with polyhexamethylene biguanide (PHMB). Mansfield (MA). Covidien. 4.
940 Hoover J, Kent DJ. Polyhexamethylene biguanide (PHMB) impregnated gauze for use in treating a gunshot wound. Mansfiled (MA). Covidien. Sep. 2008:4.
941 Howe T, Graham R. The successful management and wound closure of a challenging patient with necrotizing fasciitis with enteric fistula using negative pressure wound therapy.
942 Hutton CL. The use of antimicrobial gauze packing in an infected coronary artery bypass graft surgical incision. Mansfield (MA). Tyco Healthcare. Jun. 2005:4.
943 Jonjo SF. Length of stay: reducing a "weighty" problem in wound care saving time and improving outcomes. Mansfield (MA). Tyco Healthcare. Apr. 2007:1.
944 LCD for negative pressure wound therapy pumps (L11489). Baltimore (MD). Centers for Medicare and Medicaid Services (CMS). 10.
945 LCD for negative pressure wound therapy pumps (L11500). Baltimore (MD). Centers for Medicare and Medicaid Services (CMS). 10.
946 LCD for negative pressure wound therapy pumps (L27025). Baltimore (MD). Centers for Medicare & Medicaid Services. 10.
947 LCD for negative pressure wound therapy pumps (L5008). Baltimore (MD). Centers for Medicare & Medicaid Services. 11.
948 Lovelace L. Antimicrobial dressing intervention associated with reduction in surgical site infection rate. Mansfield (MA). Tyco Healthcare. Jun. 2008:1.
949 Material safety data sheet for DeRoyal Solidifier, MSDS-002. Product numbers 71-1200, 71-1500, 71-2500, 71-3000, 71-9000, 71-18000, 71-0500, 71-1000. Powell (TN). DeRoyal Industries, Inc. Dec. 9. 2005:2.
950 Material safety data sheet for Flexible polyurethane foam. CAS # 9009-54-5. 2008:4.
951 Material safety data sheet for Kerlix AMD super sponges, Kerlix AMD rolls, Excilon AMD sponges, Telfa AMD sponges. Product numbers 6662,6665, 6660, 3331,3332,7088,7089,7662,7663,7665,7666,7667,7668. Mansfield (MA). Tyco Healthcare / Kendall. May. 14. 2004:6.
952 Material safety data sheet for Medical Adhesive Tape Technologies, product # 09-9000 blue tape. St. Hubert, Quebec. Medical Adhesive Tape Technologies. Sep. 3. 2008:2.
953 Material safety data sheet for negative pressure non-adherent gauze. Toronto (ON). Derma Sciences, Inc. May. 2. 2008:4.
954 Material safety data sheet for Skin Prep Wipes. Largo (FL). Smith & Nephew, Inc. Dec. 8. 2003:3.
955 Material safety data sheet for sodium chloride solution, 0.85% MSDS. Catalog code: SLS2752. Houston (TX). Sciencelab.com, Inc. Nov. 6. 2008:6.
956 Material safety data sheet for Styrene-acrylonitrile copolymer (SAN). CAS registry number: 9003-54-7. IRPC Public Company Limited. Dec. 2006:4.
957 McCullin C. The use of an antimicrobial dressing to help improve outcomes for patients with pressure ulcers in a skilled nursing facility. Mansfield (MA). Tyco Healthcare. Oct. 2005:1.
958 McKendrick C. Impact on surgical dressings on coronary artery bypass graft surgery with resultant influence on patient safety. Mansfield (MA). Covidien. 2008:4.
959 Mertz P, Cazzaniga A, Serralta V, Davis S, Orr R, Eaglstein W. The effect of an antimicrobial gauze dressing impregnated with 0.2% polyhexamethylene biguanide (PHMB) as a barrier to prevent pseudomonas aeruginosa wound invasion. Mansfield (MA). Tyco Healthcare. May. 2000:7.
960 Morehouse T, Hager J. Drainage management of enterocutaneous fistula within an abdominal wound.
961 Motta GJ, Trigilia D. Impact of antimicrobial drain sponge dressing upon specific bacterial isolates at tracheostomy sites. Mansfield (MA). Tyco Healthcare. May. 2003:8.
962 Mullaney B, Lane C. Antimicrobial efficacy by elution of gauze using methycillin resistant staphlococcus aureus (MRSA). Mansfield (MA). Tyco Healthcare. Jul. 2001:4.
963 Mullaney B, Lane C. Antimicrobial efficacy by elution of gauze using vancomycin resistant enterococcus faecalis. Mansfield (MA). Tyco Healthcare. Jul. 2001:4.
964 Neitzel PJ. Reduction of SSIs during a one year study of CABG procedures in a 393-bed acute care community hospital. Mansfield (MA). Tyco Healthcare. Jun. 2007:1.
965 O'Brien JA, Broderick GB, Lalikos JF, Ignotz R, Strom H, Dunn RM. Negative pressure wound therapy as dressing for split-thickness skin grafts: our experience. 2.
966 Orr R, Eggleston T, Shelanski MV. Determination of the irritating and sensitizing propensities of Kerlix A.M.D. antimicrobial gauze dressing on scarified human skin. Mansfield (MA). Tyco Healthcare. Jan. 2003:4.
967 Orr R. In vitro efficacy of Kerlix A.M.D. gauze when used with a primary dressing. Mansfield (MA). Tyco Healthcare. Nov. 2001:1.
968 PDAC Medicare pricing, data analysis and codinng for EZCARE system. model 66800187. [internet]. Fargo (ND). Noridian Adminstrative Services, Ltd. accessed 2009 Feb 4. 2008:1. Available: https://www.dmepdac.com/dmecsapp/do/productdetail?hcpcs_product_id=18187.
969 PDAC Medicare pricing, data analysis and codinng for VERSATILE 1 model number: 100.010. [internet]. Fargo (ND). Noridian Administrative Services, Ltd. accessed 2009 Feb 4. 2008:1. Available: http://www.dmepdac.com/dmecsapp/do/productdetail?hcpcs_product_id=8929.
970 Penn RG, Vyhlidal SK, Roberts S, Miller S. The reduction of vascular surgical site infections with the use of antimicrobial gauze dressing. Mansfield (MA). Tyco Healthcare. 2.
971 Product data sheet for PerfecForm 35858-W, Ionomer-based thermoforming film. Perfecseal, a Bemis Company. Dec. 14. 2005:2.
972 Published pricing for EZCare, V1STA, RENASYS-EZ, RENASYS-F, Supply kits. Jan. 1. 2009:1.
973 RENASYS EZ negative pressure wound therapy. Smith & Nephew, Inc. 22.
974 Russell F. The use of V1STA in open abdominal wounds and to facilitate fistulae management. 3.
975 Shah CB. Comparison of efficacy and safety of a new antimicrobial packing strip with PHMB to the current industry standard iodoform and plan packing strips. Mansfield (MA). Tyco Healthcare. 3.
976 Shah CB. Testing of antimicrobial efficacy of wound dressing by in vitro elution model. Mansfield (MA). Tyco Healthcare. 4.
977 Smith & Nephew labeling information. Smith & Nephew, Inc. 33.
978 Smith & Nephew, Inc. 510(k) premarket notification of intenet to market Renasys-F NPWT foam dressing kits. K082211. Rockville (MD). U.S. Food and Drug Administration (FDA). Nov. 14. 2008:2.
979 Smith & Nephew, Inc. 510(k) premarket notification of intent to market RENASYS EZ. K082426. Rockville (MD). U.S. Food and Drug Administration (FDA). Sep. 5. 2008:3.
980 Sutterfield R. Resolution of araplegic pressure ulcer within a challenging home setting.
981 V1STA negative pressure wound therapy. User guide. Smith & Nephew, Inc. 33.
982 Werthen M, Davoudi M, Sonesson A, Nitsche P, Morgelin M, Blom K, Schmidtchen A. Pseudomonas aeruginosa-induced infection and degradation of human wound fluid and skin proteins ex vivo are eradicated by a synthetic cationic polymer. J Antimicrob Chemother. 2004;54(4):772-779. [pmid: 15355938].
983 Zanotti EA, Rosenbloom RD. Use of negative pressure wound therapy over matrix regeneration grafts.
984 Spruce P. (Clinical Director, TVRE Consulting). AHRQ submission on behalf of Talley Group, Ltd. Feb. 5. 2009:1.
985 Submission of clinical evidence for the VENTURI negative pressure wound therapy system. United Kingdom: Talley Group, Ltd. 2009:31.
986 Venturi advanced vacuum system for negative pressure wound therapy. United Kingdom: Talley Group, Ltd. 2.